# Appendix E Quality Ratings

Appendix E Table 1 Quality Ratings for Randomized, Controlled Trials, Part 1

Author, Year, Program/Trial Name | Overall Quality Rating | Overall Rationale for Quality Rating | 1. Was method of randomization adequate? | 2. Was allocation concealment adequate? | 3. Were group characteris-tics balanced at baseline? | Bias arising from randomiza-tion or selection? | Comments
Barlow et al, 2007^104^ McIntosh et al, 2009^105^ (Family Partnership Model) | Fair^*^ | For abuse outcomes, the methods only state that “participating health visitors provided data relating to case conferences, children on the protection register, children removed from the home and child deaths.” Because health visitors had far more contact with the intervention group, it is unclear how this method is equally valid for each group. It is unclear where health visitors got the information about these outcomes (e.g., via health records or purely self-report). | Probably yes | Yes | Yes | Low | None
Barth, 1991^134^ (Child Parent Enrichment Program) | Poor | Randomization not maintained. No information given on missing data or attrition. | Probably yes | No information | Yes | High | Method of random assignment not described well: “random assignment occurred at the central office.” When families assigned to G2 refused services or accepted fewer than 5 visits (there were only 6 such families, and their mean number of visits was 2.1), they were reassigned to the control group.
Brayden et al, 1993^112^ | Good | Low potential bias arising from each domain. | Yes | Probably yes | Probably yes | Low | HR control and HR intervention groups were similar except HR intervention had mean age of 21.2 years; HR control was 22.4 years.
Brooten et al, 1986^113^ | Fair | Limited information about missing data | Probably yes | Probably yes | Yes | Low | None
Bugental and Schwartz, 2009^106^ (Healthy Start+) | Fair | Study groups were different at baseline and ITT analysis was not possible. | Probably yes | No information | No | Some concerns | The education level of mothers at intake was lower in G1 than in G2. In addition, there were significantly more immigrant families in G1 than in G2. To control for these differences, immigration status was included as a between-participants variable and maternal education as a covariate.
Caldera et al, 2007^92^ Duggan et al, 2007^91^ (Healthy Families Alaska [HFAK]) | Good | Low potential bias arising from each domain. | Yes | Probably yes | Yes | Low | At baseline, HFAK mothers were less likely than controls to have poor psychological resources and to have enrolled prenatally. However, this difference does not appear to be the result of poor or failed randomization and would bias the effect measure toward the null.
DePanfilis and Dubowitz, 2005^172^ (Family Connections) | Poor | Poorly specified intervention arm and high and uneven attrition. | Yes | Probably yes | Yes | Low | None
Dubowitz et al, 2009^148^ (SEEK) | Poor | Randomization problems and potential for contamination yield high risk of bias for between-group comparisons. | No | No | No | High | Two clinic days were randomly assigned to intervention and another two days were randomly assigned to be control clinics. There are many ways that group differences could be confounded by differences in clinic on those days of the week. G2 children were younger and their families had fewer children than G1.
Dubowitz et al, 2012^147^ (SEEK) | Poor | Potential bias caused by lack of randomization of two control practices, lack of blinding, possible effects of unblinding on outcome measures, as well as some concerns raised by missing information and attrition. | No | NA | No | High | Practices were randomized into SEEK or control groups, stratified by size, by drawing paper lots. One SEEK practice withdrew before recruitment. Another SEEK practice had a large number of health professionals, which created an imbalance between groups. As a result, two additional practices were assigned to the control group without randomization. Despite efforts to adjust for baseline variations using statistical analyses, large socioeconomic and child medical assistance differences are evident between groups, potentially caused by adding the two control practices. Allocation was not concealed to participants or health professionals due to nature of intervention.
Duggan et al, 1999^145^ Duggan et al, 2004^146^ | Poor | Low study attrition across 3 years of followup assessments. Sample size and the multiple followup points yielded substantial study power to detect group differences for nearly all outcomes. However, deviation from intended intervention (fidelity) significantly threatens validity. Because of the low intervention retention and lack of specificity regarding implemented components and the fidelity with which they were implemented, it is impossible to draw clear conclusions about the relationship between the intervention and the study outcomes. | Yes | Probably yes | Probably yes | Low | G1: higher maternal employment prior to enrollment (52% vs. 44%, p=0.05); poor maternal general mental health and partner violence less common in the HSP group than control group (43% vs. 50%., p=0.05; 43% vs. 52%, p=0.02).
DuMont et al, 2008^93^ DuMont et al, 2010^94^ (Healthy Families New York) | Good | Low potential bias arising from each domain. | Yes | No information | Yes | Low | None
Easterbrooks et al, 2013^107^ (Healthy Families Massachusetts) | Fair | Limited information about bias due to randomization, missing data departures from intended intervention | No information | No information | Probably yes | Uncertain because no information | None
Fergusson et al, 2005^108^ Fergusson et al, 2013^109^ (Early Start Program) | Fair | Some concerns regarding lack of blinding, potential bias in CAN self-report only data, and lack of information about intervention delivery and fidelity. | Yes | Probably yes | Yes | Low | None
Finello et al, 1998^114^ | Fair | Randomization not described, nonblinded, not powered adequately, significant differential attrition, skeletal information about the implementation of the HH, HV, and HH/HV interventions. | No information | No | Probably no | Some concerns | The authors report that at the first weekly discharge meeting following the infant’s birth, those infants meeting birth weight criteria for enrollment were discussed and assigned at random to one of the four groups. There was no attempt to assign infants by “‘risk” status to any particular group. However, the randomization process does not provide specific information about the randomization method.
Gray et al, 1977^136^ Gray et al, 1979^135^ | Poor | Half the sample is missing from the outcomes. | No information | No information | No information | Uncertain because no information | Baseline characteristics not reported so no ability to determine bias.
Guyer et al, 2003^115^ Minkovitz et al, 2007^116^ (Healthy Steps for Young Children) | Fair | This was a complex multisite study. The intervention entailed a defined core of interventions based on written protocols and guidelines. The program design provided for adapting elements of the package to the needs of the individual families. Some program components could have been implemented at control sites due to the spreading of best/new practices in the HS model. High attrition for longer-term outcomes | Yes | Yes | Yes | Low | None
Hardy and Streett, 1989^173^ | Poor | Issues with randomization, blinding, characterization of the intervention inputs. | Probably no | No | Yes | High | Assignment to intervention and control groups was based on odd/even digits of infant medical record numbers. Authors ascertained that the children in the two groups were comparable.
Infante-Rivard et al, 1989^174^ | Poor | High risk of bias for randomization and attrition. Several domains with little or no information. | No information | No information | No | High | Inadequate randomization scheme used. Authors state that a randomized block design was used, but there is no information on the methods for randomization itself. Also no allocation concealment. Baseline results suggest that randomization did not “work.” Mothers in G2 were slightly older than mothers in G1 and were more likely to live alone and to have no other children and were less likely to have a low educational level, to live below the poverty line, as well as less likely to be single or separated.
Kitzman et al, 1997^96^ Olds et al, 2007^97^ (The Memphis Trial) | Fair | Long-term attrition, lack of ITT analysis | Yes | Yes | Probably yes | Low | None
Koniak-Griffin et al, 2002^175^ Koniak-Griffin et al, 2003^171^ (Early Intervention Program) | Poor | High and differential attrition | Yes | Probably yes | Probably yes | Some concerns | Baseline characteristics only described for analysis sample after attrition
Lam et al, 2009^103^ | Fair | Several domains with little or no information | No information | No information | Yes | Low | No information on some items, but no signal of inadequate randomization
Larson, 1980^110^ | Fair | Differential attrition rates | no | No information | Yes | Some concerns | Assignment not fully random. Assignment to groups B (G3) and C (G1) was random, ended when 80 participants entered. Then group A (G2) mothers were entered until predetermined date; analysis in this review limited to randomized groups.
Lowell et al, 2011^117^ (Child FIRST) | Good | Low potential bias arising from each domain. In areas of some concern, the researchers made attempts to correct for potential bias. | Yes | No | Probably yes | Some concerns | The PI assigned families by coin toss, suggesting no concealment of allocation. Although there were some differences in maternal education and family CPW involvement history, differences do not appear to be the result of poor randomization.
Marcenko and Spence, 1994^118^ | Fair | Some concerns in the departures from intended intervention domain due to no information provided regarding outcome assessors, cross-overs, or contamination; also no mention of masking or blinding. Some concerns in the missing outcome data domain because ITT analysis was not used; differences in reasons for attrition and rates of attrition between arms. | No information | No information | Yes | Uncertain because no information | None
Mejdoubi et al, 2015^176^ (VoorZorg) | Poor | Bias due to missing outcome data because attrition was high and intent-to-treat analysis was not used. CPS reports were not available from some agencies, creating a potential for systematic differences in attrition. | Yes | NA | Yes | Low | None
Norr et al, 2003^177^ (REACH-Futures) | Poor | Randomization process was unlikely adequate given deviations, deviation from intended intervention is not reported but is probable given downsizing during the intervention, primary benefit outcome is not ascertained, and potential reporting bias. | Probably no | No information | Yes | Some concerns | Subjects assigned to treatment/control groups based on their medical record number. African American and Mexican American participants were supposedly randomized into treatment and control groups. but no further information was reported. Group characteristics were balanced within each ethnic group but not overall. Authors reported substantial background characteristics differences between African American and Mexican American participants at intake (mostly p<0.01). More African American women in treatment arm proportionately (56%) than Mexican American women (49%), unclear why.
Olds et al, 1986^98^ Olds et al, 1994^99^ Olds et al, 1997^100^ Eckenrode et al, 2000^101^ Zielinski et al, 2009^102^ (The Elmira Trial) | Fair | Some concern about potential deviation from the intervention during the study duration. | Probably yes | Probably no | Probably yes | Some concerns | Some randomization overridden to avoid having women in the same house have different treatment assignments.
Paradis et al, 2013^178^ (Building Healthy Children) | Poor | Critical information on study methods is missing or unclear for this preliminary analysis. Evaluation is ongoing for the trial. There is concern that this paper only reports on early completers who may be significantly different from the rest of the study population. It is also unclear who the analytic sample includes and how it is different from the enrolled sample. | Probably yes | Probably yes | Yes | Low | None
Quinlivan et al, 2003^119^ | Fair | Some baseline imbalance, details not reported | Yes | Yes | No | Some concerns | Authors note that the following factors seemed imbalanced between the two groups at baseline: ethnic origin, social isolation, involvement of the father of the baby, and homelessness. Analyses controlled for these factors.
Robling et al, 2016^90^ | Fair | No blinding to allocation, some attrition and no sensitivity analyses, usual care received co-interventions that diluted the effect of the active intervention, poor fidelity | Yes | No | Yes | Low | No blinding to allocation concealment, but given the negative results, it does not seem likely that even if they were unblinded, it had an effect on study results.
Sadler et al, 2013^95^ (Minding the Baby) | Fair | Attrition >20%, no imputation for missing data, unclear whether CPS outcome measurement was record-based or self-report | Probably yes | yes | Yes | Low | None
Siegel et al, 1980^89^ | Fair | High attrition | No information | No information | Probably yes | Some concerns | Method of randomization is not described. Baseline data are only shown for those who had 4- and 12-month assessments completed. However a larger group of participants was used for determining health outcomes, and their baseline data are not shown. Authors report that there were not significant differences. Also, the mothers in the intervention group had higher scores on the vocabulary test that was given. In addition, there was some concern about the 41 participants who did not receive the intervention. If they were randomized, they should have been included, but it is not clear whether they were randomized or not.
Silovsky et al, 2011^111^ (SafeCare+) | Fair | High attrition | Yes | Probably yes | Yes | Low | None
Wagner and Clayton, 1999^179^ (PAT: Salinas Valley) | Poor | High level of attrition from study intervention, medium level of attrition. | No information | No information | Yes | Uncertain because no information | No information
Wagner and Clayton, 1999^179^ (PAT: Teen) | Poor | High level of attrition from study evaluation and intervention. | No information | No information | Yes | Uncertain because no information | No information
Wiggins et al, 2005^121^, Wiggins et al, 2004^120^ (The Social Support and Family Health Study) | Fair | Some concerns about lack of blinding and poor uptake of second active intervention (CGS). Also CAN outcomes are based soley on parent self-report and not verified against medical records. Otherwise fair quality study. | Yes | Yes | Probably yes | Low | None

* Fair for abuse outcomes. Good for behavioral outcomes.

Abbreviations: CAN=Child abuse and neglect; CPS=Child Protective Services; CGS=Community group support; CPS= Child Protective Services; G=group; HFAK=Healthy Families Alaska; HH=health home; HR=hazard ratio; HSP= Healthy Start Home visitation program plus; HV=Home visits; IIT=intent to treat; PAT=Parents as Teachers; SEEK= Safe Environment for Every Kid; vs.=versus.

Appendix E Table 2 Quality Ratings for Randomized, Controlled Trials, Part 2

Author, Year, Program/Trial Name | 4. What was the overall attrition and attrition by group? Did attrition vary for different outcomes? | 5. Did the study have low attrition? | 6. Are the proportion of participants and reasons for missing data similar across interventions? | 7. For benefits outcomes, was intent-to-treat analysis used? | 8. Were appropriate statistical methods used to account for missing data? | Bias arising from missing outcome data? | Comments
Barlow et al, 2007^104^ McIntosh et al, 2009^105^ (Family Partnership Model) | Attrition at 12-month followup: Overall: 8.4% G1: 7.9% G2: 8.8% | Yes | No information | Probably no | Probably no | Low | Although methods state that intent-to-treat analysis was used, data tables report analytic samples with attrition and no description of handling missing data is given; however, attrition is low.
Barth, 1991^134^ (Child Parent Enrichment Program) | NR | No information | No information | No information | No information | Some concerns | No information about attrition
Brayden et al, 1993^112^ | Overall: 13.5% G1: 20.8% G2: 11.9% | Yes | Probably yes | Probably no | No information | Low | Participants were lost due to women not having a live infant at birth and women who delivered at another hospital. Sufficient information was available for 88% of HR intervention participants, 79% of HR control subjects, and 90% of LR control subjects. Scoring or randomization errors resulted in exclusion of data from 7 additional participants in the LR control group. Overall, attrition was low and no information was provided as to whether intent-to-treat analysis was used.
Brooten et al, 1986^113^ | No information | No information | No information | yes | No information | Uncertain because no information | No information provided regarding attrition
Bugental and Schwartz, 2009^106^ (Healthy Start+) | Overall: 7.2% G1: 3.4% G2: 11.8% | Yes | No information | No | No information | Some concerns | Completers of the program were significantly more likely to be immigrants compared with noncompleters. ITT analysis was not used.
Caldera et al, 2007^92^ Duggan et al, 2007^91^ (Healthy Families Alaska) | Overall: 15% G1: 14% G2: 15% | Yes | Probably no | Yes | Yes | Low | Families with versus those without a baseline interview were comparable on the Family Stress Checklist (FSC). However, in families followed up vs. those who withdrew, mothers were more likely to have worked before study enrollment (76% vs. 57%, p=0.01), more likely to be married or living with the child’s partner (56% vs. 34%, p<0.01), and less likely to have enrolled prenatally (44% vs. 66%, p=0.01).
DePanfilis and Dubowitz, 2005^172^ (Family Connections) | Overall: NR G1: 5% G2: 25% | No | No | Yes | Yes | High | Differential attribution
Dubowitz et al, 2009^148^ (SEEK) | Overall: 24% G1: 23% G2: 24% | No | Probably yes | yes | No | Some concerns | There was >20% attrition from the study sample. No information is given on how missing data were dealt with, but only those who completed the study protocol were used in the analysis. The article reported using ITT analysis because participants were retained in their randomized arms regardless of how much intervention they received.
Dubowitz et al, 2012^147^ (SEEK) | Practices: 1 INT practice/17 total practices (5.9%) withdrew before recruitment and after randomization Attrition at 6-month followup: Overall:19% G1: 22% G2: 17% Attrition at 12-month followup: Overall: 20% G1: 22% G2: 18% | Yes | No information | No | No information | Uncertain because no information | The overall attrition and attrition by group were low. Attrition did not vary much between outcomes. The proportion of participants with missing data is similar across interventions, but slightly higher among SEEK participants. Reasons for missing data or attrition are unknown. Intent-to-treat analysis was not used, and no information was provided on the use of statistical methods to account for missing data.
Duggan et al, 1999^145^ Duggan et al, 2004^146^ | Intervention attrition: 51% Followup attrition: 12% | No | Yes | Yes | Yes | High | About half of the enrolled families left the program within a year.^146^ But authors noted that all baseline participants were kept in the evaluation unless data were not available for specific outcomes. Reasons for attrition within the HSP group within the first year of the program included refusing service: 31%; moved: 11%; unable to contact: 4%; returned to work or school: 3%; became ineligible: 2%. Authors also noted that because families were identified through universal screening, attrition rate was expected to be higher. In addition, Hawaii suffered from a serious economic downturn. Budget cuts and funding leveling contributed to staff anxiety and turnover, which might have compromised service quality.
DuMont et al, 2008^93^ DuMont et al, 2010^94^ (Healthy Families New York) | Overall: 15.4% G1: 15% G2: 16% | Yes | No | Yes | Yes | Low | No information reported regarding whether attrition varied for different outcomes.
Easterbrooks et al, 2013^107^ (Healthy Families Massachusetts) | No Information | No information | No information | Yes | No information | Uncertain because no information | No information regarding attrition or missing data was reported.
Fergusson et al, 2005^108^ Fergusson et al, 2013^109^ (Early Start Program) | Attrition at 3-year followup: Overall: 11.7% G1: 7.2% G2: 16.4% Attrition at 6-year followup: Overall: 13.1% G1: 8.1% G2: 18.2% Attrition at 9-year followup:^*^ Overall: 16.5% G1: 10.7% G2: 22.3% | Yes | No information | Yes | Probably yes | Low | None
Finello et al, 1998^114^ | Overall attrition by outcomes: CPS abuse 6 m: 1/81,1% CPS abuse 12 m: 12/81, 15% CPS neglect 6 m: 1/81, 1% 12 m: 12/81, 15% ER 6 m: 6/81, 7% 12 m: 13/81, 16% Hosp <24h 6 m: 5/81, 6% 12 m: 11/81, 14% Hosp >24h 6 m: 4/81, 5% 12 m: 13/81, 16% Group attrition by outcomes: CPS abuse 6 m: G1 0/20, 0% G2 1/21, 5% G3 0/20, 0% G4 0/20, 0%; 12 m: G1 1/20, 5% G2 5/21, 24% G3 5/20, 25% G4 1/20, 5%; CPS neglect 6 m: G1 0/20, 0% G2 1/21, 5% G3 0/20, 0% G4 0/20, 0%; 12 m: G1 1/20, 5% G2 5/21, 24% G3 5/20, 25% G4 1/20, 5%; ER 6 m: G1 2/20, 10% G2 4/21, 19% G3 0/20, 0% G4 0/20, 0%; 12 m: G1 2/20, 10% G2 6/21, 29% G3 4/20, 20% G4 1/20, 5%; Hosp<24 6 m: G1 1/20, 5% G2 4/21, 19% G3 0/20, 0% G4 0/20, 0%; 12 m: G1 3/20, 15% G2 1/21, 5% G3 6/20, 30% G4 1/20, 5%; Hosp>24 6 m: G1 1/20, 5% G2 3/21, 14% G3 0/20, 0% G4 0/20, 0%; 12 m: G1 2/20, 10% G2 6/21, 29% G3 4/20, 20% G4 1/20, 5% | Probably no | Probably no | Probably yes | Probably no | Some concerns | G2 and G3 are missing >20% data for most 12-month outcomes
Gray et al, 1977^136^ Gray et al, 1979^135^ | No information | No information | No information | Yes | No information | High | Study did not report on attrition. Instead of analyzing all 150 participants, researchers took a random sample of 75 (25 in the high-risk intervention group, 25 in the high-risk nonintervention, and 25 in the low-risk control group) to conduct at-home visits and collect followup information). The 75 randomly selected participants were all included in the analyses.
Guyer et al, 2003^115^ Minkovitz et al, 2007^116^ (Healthy Steps for Young Children) | Overall attrition at 2- to 4-month followup: 12% Overall attrition at 30- to 33-month followup: 34% Overall attrition at 5- to 5.5-year followup: 43% | No | Probably yes | Yes | Yes | Some concerns | Missing data were purposefully not statistically adjusted for in the interest of an ITT analytic approach. High attrition. No information provided were missing data in control group vs. intervention group.
Hardy and Streett, 1989^173^ (Child and Youth Program) | Overall: <1% G1: 0% G2: 1% | Yes | Yes | NA | NA | Low | None
Infante-Rivard et al, 1989^174^ | Overall: 12-33% | Probably no | No information | Probably no | No information | High | 21% (n=17) mothers admitted to the study (n=73) did not actually participate. An additional 12% of subjects (n=9) lost to followup after the child was born. 26 dyads that were enrolled and had consented to participate (i.e., were randomized) were then dropped due to refusing after signing consent, experiencing post-natal exclusion criteria, moving, or not being able to be reached. This loss after randomization may account for some of differences in the experimental and control groups.) Authors noted that the choice of socially deprived mothers as a target group may have led to high dropout rate. Attrition in this study was highest among what has been referred to as attenuated nuclear families (only the mother and the children are present in the home). Unclear if ITT used.
Kitzman et al, 1997^96^ Olds et al, 2007^97^ (The Memphis Trial) | No information | Probably yes | Yes | Probably no | No information | Some concerns | Low attrition at 6-month followup. Attrition increased over time (9 years) but similar across groups. Lack of information on how missing data were handled.
Koniak-Griffin et al, 2002^175^ Koniak-Griffin et al, 2003^171^ (Early Intervention Program) | Overall: 29.9% G1: 37.5% G2: 22.2% | No | No | No | No information | High | High attrition and differential attrition, no ITT analysis.
Lam et al, 2009^103^ | Overall: 17% G1: NR G2: NR | Yes | No information | Probably yes | Yes | Some concerns | Small sample size, some missing data, use of multiple imputation stated in methods, but N for analysis not clearly specified.
Larson, 1980^110^ | Overall: 22% G1: 16% G2: 26% G3: 25% | No | Probably no | Probably yes | Probably no | Some concerns | Control group with lower attrition than either intervention group.
Lowell et al, 2011^117^ (Child FIRST) | Attrition at 6-month followup: Overall: NR G1: 15.5% G2: 17.9% Attrition at 12-month followup: Overall 25.5% G1: 25.3% G2: 25.6% | Probably yes | Yes | Yes | Probably yes | Low | Analyses of CPS involvement were conducted on the total number of participants randomized at enrollment (n=157). Participants who withdrew from the two groups were similar on all baseline characteristics.
Marcenko and Spence, 1994^118^ | Overall: 17% G1: 23% G2: 12% | Yes | No | No | No information | Some concerns | Intent-to-treat analysis was not used. Greater attrition in control group because participants not followed by the intervention team.
Mejdoubi et al, 2015^176^ (VoorZorg) | Attrition at 24 months after birth for female caregivers Overall: 52% G1: 58% G2: 45% | No | Yes | No | Yes | High | Missing outcome data raises some concerns due to relatively high attrition (52% overall) and high differential attrition, although researchers found no significant differences in baseline characteristics among completers and noncompleters assigned to the control and intervention groups.
Norr et al, 2003^177^ (REACH-Futures) | Children not retained sufficiently in the intervention (i.e., ≥10 months): G1: 10% G2: 8% | No information | No information | No | Probably yes | Uncertain because no information | Inclusion criteria are problematic because they comprise study retention (i.e., only families with a high level of program/study retention were included in the analysis). Even taking into account those lost to followup because they did not reach the 10-month minimum for inclusion, the study had remarkably low attrition for a home visiting effort, which is likely attributable to the home visiting program being an extension of a comprehensive primary care program. It seems that their analysis was not ITT, as the 27 participants that were excluded should have been included in the analysis.
Olds et al, 1986^98^ Olds et al, 1994^99^ Olds et al, 1997^100^ Eckenrode et al, 2000^101^ Zielinski et al, 2009^102^ (The Elmira Trial) | Overall 15-21% in the first 2 years of the children’s lives; nondifferential across treatments.^98^ Attrition at 15 years after birth:^100^ G1: 19.6% G2: 21.0% G3: 16.4% | Probably yes | Probably yes | Yes | No information | Uncertain because no information | Unclear how total N reduced from 314 to 237.
Paradis et al, 2013^178^ (Building Healthy Children) | No information^†^ | No information | No information | No information | No information | High | Evaluation is ongoing for the trial. There is concern that this paper only reports on early completers who may be significantly different from the rest of the study population. It is also unclear who the analytic sample includes and how it is different from the enrolled sample.
Robling et al, 2016^90^ | Overall: 78.3% G1 (usual care): 78.6% G2 (NFP): 78.1% For ED visits/hospitalizations: G1=753/822, G2=725/823; lower for other outcomes (<80%) | Probably no | Yes | No | No | Some concerns | ED/admission data did not use ITT, nor did they provide sensitivity analyses, but given negative results and similarity of dropout, not clear if failure to do ITT had an impact
Sadler et al, 2013^95^ (Minding the Baby) | Attrition at 12-month followup: Overall: 26% G1: 24% G2: 27% Attrition at 24-month followup: Overall: 29% G1: 31% G2: 27% | No | Yes | Probably no | Probably yes | Some concerns | High attrition; analyses do not appear to account for missing data.
Siegel et al, 1980^89^ | Data from 321 women were included in the analysis but unclear if the N randomized was the N eligible (525) or a smaller number. If the N randomized was 525, attrition could have been 38.9% | Probably no | Yes | No | Probably no | Some concerns | For the health outcomes, all 321 participants were used, so there is less bias for those than the attachment measures. Unclear whether N analyzed is N randomized
Silovsky et al, 2011^111^ (SafeCare+) | Attrition at 10-month followup: Overall: 16.2% G1: 21.1% G2: 10.4% Attrition at 17-month followup: Overall: 24.8% G1: 21.1% G2: 29.1% | no | Probably yes | Yes | Yes | Some concerns | High differential attrition at 17 months
Wagner and Clayton, 1999^179^ (PAT: Salinas Valley) | Overall: 27% (for emergency room visits) G1: 23% G2: 30% | No | Yes | Probably yes | Probably no | Some concerns | Somewhat high attrition; no description of handling missing data. Attrition from intervention was much higher than from evaluation.
Wagner and Clayton, 1999^179^ (PAT: Teen) | Overall: 48% (for emergency department visits, 15% for CPS) G1: 46% G2: 49% G3: 49% G4: 49% | No | Yes | Probably yes | Probably no | High | Very high attrition, no description of handling missing data. Attrition from intervention was much higher than from evaluation.
Wiggins et al, 2005^121^ Wiggins et al, 2004^120^ (The Social Support and Family Health Study) | Attrition at 12-month followup: Overall: NR G1: 10% G2: 11% G3: 10% Attrition at 18-month followup: Overall: NR G1: 18% G2: 15% G3: 20% | Yes | Probably yes | Yes | Probably yes | Low | Overall attrition for both followup time points was at or lower than 20% and there was no differential attribution between groups.

* Authors reported in Fergusson et al, 2013^109^ 11% attrition in the intervention group compared to 16% of attrition in the control at the 9-year followup. Author’s calculation omits the 2 cases in the control group and the 14 cases in the intervention group that declined participation within the first month after assignment.

† Evaluation is ongoing for the trial. Analyses were conducted on those who completed the study “to date,” which is only 43% of the 497 enrolled families. Abstract states that 85% of families remained enrolled by age 3 but paper only presents data on 43%, which appears to be those who completed the program.

Abbreviations: CPS=Child Protective Services; ER=emergency room; FSC=Family Stress Checklist; G=group; HR=hazard ratio; HSP= Healthy Start Home visitation program; ITT=intent to treat; LR=Low risk; N=number; NA=not applicable; NR=not reported; PAT=Parents as Teachers; SEEK= Safe Environment for Every Kid.

Appendix E Table 3 Quality Ratings for Randomized, Controlled Trials, Part 3

Author, Year, Program/Trial Name | 9. Were the patients unaware of their intervention status of participants? | 10. Were the trial personnel and clinicians unaware of the intervention status of participants? | 11. Were outcome assessors unaware of the intervention status of participants? | 12. Was intervention fidelity adequate? | 13. Were cross-overs or contamination minimal such that it would not raise concern for bias? | Bias arising from departures from intended interventions? | Comments
Barlow et al, 2007^104^ McIntosh et al, 2009^105^ (Family Partnership Model) | Probably no | Probably no | Yes | Probably yes | Probably yes | Low | None
Barth, 1991^134^ (Child Parent Enrichment Program) | No | No | No | Probably yes | No | Some concerns | Post-test measures were completed by interviewers who knew the client’s status, not blinded.
Brayden et al, 1993^112^ | No | No | Yes | Probably yes | Probably yes | Low | As a result of closer monitoring, an increased number of reports were made to DHS for physical abuse and neglect in the HR intervention group; analyses were run excluding these participants with no significant differences found.
Brooten et al, 1986^113^ | No | No | Probably yes | No information | Probably yes | Low | None
Bugental and Schwartz, 2009^106^ (Healthy Start+) | Probably no | No | No information | Probably yes | No information | Low | None
Caldera et al, 2007^92^ Duggan et al, 2007^91^ (Healthy Families Alaska) | Probably no | Probably no | Yes | Probably yes | Yes | Low | Because the foundation of the intervention was home visits, it is likely participants in the control and home visitation groups were aware of their intervention status. Similarly, personnel conducting the intervention were aware of the type of visitation to be conducted with each participating family. However, other study staff and outcome assessors were blinded. The nature of the intervention also limited the ability of participants to cross over.
DePanfilis and Dubowitz, 2005^172^ (Family Connections) | Probably no | No | Probably no | Probably no | Probably no | high | No blinding of intervention providers. Patients self-reported outcomes. “High-dose” group (FC9) was actually a combination of the FC9 and FC9+g groups of the original protocol design.
Dubowitz et al, 2009^148^ (SEEK) | Probably yes | Probably yes | No | Probably yes | No information | Some concerns | The study assessed the extent to which targeted problems were identified and addressed during intervention sessions via the medical chart review; however, they do not present results of this analysis. It is unclear how much contamination occurred and risk for contamination seems high.
Dubowitz et al, 2012^147^ (SEEK) | No | No | No | Probably yes | Probably yes | Some concerns | The reseachers adjusted for unknown differences and random effects from pracitices, which helps account for unintended exposure. Contamination and cross over were probably minimal due to private practice setting, trained health professionals, and on-site social worker, which were all out of access to the control group. However, caregivers, trial personnel and clinicians, and outcome assessors were aware of the intervention status of participants due to the nature of the SEEK program and use of PSQs. Although children <5 years were likely unaware of their intervention status, mothers’ unblinding may raise concern for bias and minimally affect the CTS, PC outcome measure.
Duggan et al, 1999^145^ Duggan et al, 2004^146^ | Probably no | No | Yes | No | No information | High | Authors reported several issues regarding fidelity: 1) agencies taking part in the evaluation varied greatly in family retention rates, home visit frequency, and home visitor ratings likely reflecting differences in philosophy (i.e., whether the entire family is the primary client or just the index child); 2) intervention model seemed to be applied differently in different settings by different agencies; 3) home visitors likely lacked sufficient expertise and supervision to address family risks for abuse, motivate families to change, and link families with professional services; 4) program’s management information system had incomplete data for monitoring service delivery.
DuMont et al, 2008^93^ DuMont et al, 2010^94^ (Healthy Families New York) | Probably no | No | Yes | No information | Probably yes | Some concerns | Likely patients were not blinded and clinicians were not blinded. No information on fidelity.
Easterbrooks et al, 2013^107^ (Healthy Families Massachusetts) | Probably no | Probably no | No information | No information | No information | Uncertain because no information | No information
Fergusson et al, 2005,^108^ Fergusson et al, 2013^109^ (Early Start Program) | Probably no | Probably no | Probably no | No information | No information | Some concerns | No blinding to group assignment was undertaken. Although fidelity data not provided, authors report level of participation in the intervention, with fairly high rates (59.5% of participants active in the program at the 3-year followup).
Finello et al, 1998^114^ | No | No information | No information | No information | No information | Some concerns | The different interventions were “systems” interventions already in place at the hospital. There is very limited information provided about the intended intervention and no information about implementation.
Gray et al, 1977^136^ Gray et al, 1979^135^ | No | No | No information | No information | Probably yes | Uncertain because no information | Patients and investigators not blinded to group assignment due to the nature of the study. No information about whether assessors were blinded to participants’ assigned group.
Guyer et al, 2003^115^ Minkovitz et al, 2007^116^ (Healthy Steps for Young Children) | Probably yes | Probably no | Yes | Yes | No information | Some concerns | Authors noted that the sites participating in this clinical trial might not be comparable to all pediatric practices and cautioned that the randomization design might introduce possible spillover effects. HS incorporated into its package of services a number of strategies that were already in use in pediatric practices or other agencies in the community. The evaluation gathered information on the number of duplicate services as well as changing practice patterns that might have influenced the findings.
Hardy and Streett, 1989^173^ (Child and Youth Program) | Probably no | No | No information | No information | No information | Some concerns | The intervention was developed for the purpose of this small, single study and delivered by exactly one home visitor, which is an unusual model and one that raises concerns about any bias that one provider may have brought to the intervention. No information reported on intervention fidelity. Analyses present the findings from the home visiting effort, without taking into account intervention considerations associated with the comprehensive care services.
Infante-Rivard et al, 1989^174^ | No information | No information | No information | No information | Probably yes | Uncertain because no information | No information
Kitzman et al, 1997^96^ Olds et al, 2007^97^ (The Memphis Trial) | No | Probably no | Probably yes | Probably yes | Probably yes | Some concerns | Clinicians who treated the participants were aware of assignments and did some of the outcome assessments. It was not possible to blind participants in this kind of intervention. Outcome assessors extracting data from medical records were blinded. Interviewers were mostly unaware of treatment assignment in both studies. Those coding interview data were blinded. Teachers, who completed evaluations when children were age 9, were probably blinded.
Koniak-Griffin et al, 2002^175^ Koniak-Griffin et al, 2003^171^ (Early Intervention Program) | No | No | Yes | Probably yes | Yes | Low | None
Lam et al, 2009^103^ | No information | Probably no | No information | Yes | No information | Uncertain because no information | Unclear whether outcome assessors were masked.
Larson, 1980^110^ | Probably no | Probably no | Yes | No information | Probably yes | Low | None
Lowell et al, 2011^117^ (Child FIRST) | No | Probably No | Probably no | Probably yes | Probably yes | Low | Some concerns were raised in this domain due to the lack of blinding among participants. Efforts were made to keep the research assistants unaware of group status, although they frequently learned about participants’ status during followup interviews. Researchers attempted to mask the effect of unblinding by ensuring research assistants are trained to administer and assess items in a standard fashion. This section was given a low bias rating because the impact of unblinding on participant outcomes is likely minimal.
Marcenko and Spence, 1994^118^ | Probably no | Probably no | No information | Probably yes | No information | Some concerns | No information provided regarding outcome assessors, cross-overs, or contamination; also no mention of masking or blinding.
Mejdoubi et al, 2015^176^ (VoorZorg) | No | No | Yes | No information | Yes | Some concerns | No information
Norr et al, 2003^177^ (REACH-Futures) | No information | No information | Yes | Probably no | No information | Some concerns | No information on whether the participants and trained interviewers knew of the intervention status of the mothers. Analysis took into account all baseline differences between the African American and Mexican American mothers and presumably between intervention and control group participants within each racial group. Authors noted that downsizing during the program likely affected program delivery to Mexican Americans more than African Americans, because as a group they were recruited into the study later.
Olds et al, 1986^98^ Olds et al, 1994^99^ Olds et al, 1997^100^ Eckenrode et al, 2000^101^ Zielinski et al, 2009^102^ (The Elmira Trial) | Yes | Probably yes | No | No information | Probably yes | Some concerns | A few cases of mothers inadvertently revealing that they were visited by a nurse, but the staff gathering the data were told that the 15-year followup study was designed to assess the long-range effect of prenatal and early childhood services, including home visitations by nurses.^100^ The principal investigators and statisticians had access to the families’ treatment assignments.
Paradis et al, 2013^178^ (Building Healthy Children) | Probably no | Probably no | No information | No information | No information | Some concerns | No discussion of blinding or intervention fidelity.
Robling et al, 2016^90^ | No | No | Probably yes | Probably yes | Probably no | Some concerns | Usual care received more frequent home visiting services than intervention arm, likely washing out the intervention effect. Only CATI outcomes were collected by blinded assessors. Field assessors were not blinded. This is less of an issue for ED visits/hospitalizations than it would be for some of the behavioral outcomes
Sadler et al, 2013^95^ (Minding the Baby) | Probably no | Probably no | Probably yes | Yes | No information | Low | None
Siegel et al, 1980^89^ | No | No | Yes | Probably yes | Yes | Low | None
Silovsky et al, 2011^111^ (SafeCare+) | Probably no | Probably no | Probably no | Yes | No information | Low | None
Wagner and Clayton, 1999^179^ (PAT: Salinas Valley) | Probably no | Probably no | Yes | No | Probably yes | Some concerns | Does not specify how training accomplished for the parent educators providing the intervention; large variation of education with some with bachelor’s degrees and others without.
Wagner and Clayton, 1999^179^ (PAT: Teen) | Probably no | Probably no | Yes | No | Probably yes | Some concerns | Does not specify how training accomplished for the parent educators providing the intervention; large variation of education with some with bachelor’s degrees and others without.
Wiggins et al, 2005^121^ Wiggins et al, 2004^120^ (The Social Support and Family Health Study) | No | No | No^*^ | Probably yes | Probably yes | Some concerns | Because of the nature of the interventions, it was not possible for either the trial participants or the researchers to be blinded to group allocation. Authors noted that potential confounders were balanced in randomization. However, authors did note poor uptake of CGS intervention.

* Data entry staff were blind to allocation at the second followup but not the first followup when the questionnaires contained additional sections for the two intervention arms of the trial.

Abbreviations: CGS=community group support; CTSPC=Conflict Tactics Scale (Parent-Child); DHS=Department of Health Services; FC9=Family Connections for 9 months; HR=hazard ratio; PAT=Parents as Teachers; PSQ=Parent Screening Questionnaire; SEEK= Safe Environment for Every Kid.

Appendix E Table 4 Quality Ratings for Randomized, Controlled Trials, Part 4

Author, Year, Program/Trial Name | 14. Were benefit outcomes (e.g., abuse) adequately described, prespecified, valid, and reliable? | 15. Were similar techniques used among groups to ascertain benefit outcomes? | 16. Was the duration of followup adequate to assess benefit outcomes? | Bias arising from measurement of benefit outcomes? | Comments
Barlow et al, 2007^104^ McIntosh et al, 2009^105^ (Family Partnership Model) | No information | Probably no | Yes | Some concerns | For abuse outcomes, the methods only state that “participating health visitors provided data relating to case conferences, children on the protection register, children removed from the home and child deaths.” Because health visitors had far more contact with the intervention group, it is unclear how this method is equally valid for each group. It is unclear where health visitors got the information about these outcomes (e.g., via health records or purely self-report). Behavioral outcomes appear to have low concern for bias.
Barth, 1991^134^ (Child Parent Enrichment Program) | Probably yes | Yes | Yes | Low | Outcomes were not well described, but most are objective and based on reports and so likely valid and reliable.
Brayden et al, 1993^112^ | Yes | Yes | No information | Low | It is possible that one unintended effect of the intervention was increased surveillance leading to closer contact with the health care system, which may have led to increased identification of maltreatment, leading to detection of maltreatment that would have otherwise been unrecognized. To control for this, the 6 physical abuse reports made by the hospital were removed and the differences between the groups were nonsignificant
Brooten et al, 1986^113^ | No information | Probably yes | Yes | Uncertain because no information | No information about how the 2 reports of child abuse were described or assessed.
Bugental and Schwartz, 2009^106^ (Healthy Start+) | Yes | Yes | Yes | Low | None
Caldera et al, 2007^92^ Duggan et al, 2007^91^ (Healthy Families Alaska) | Probably yes | Yes | Yes | Low | This study assessed a number of outcome measures to ascertain child maltreatment. While some measures were adequately described, others were limited in their description, especially those derived from scales and subscales; cutoff measures were not specified for continuous measures.
DePanfilis and Dubowitz, 2005^172^ (Family Connections) | Yes | Yes | Yes | Low | None
Dubowitz et al, 2009^148^ (SEEK) | Yes | Yes | Probably yes | Low | None
Dubowitz et al, 2012^147^ (SEEK) | Probably yes | Yes | Yes | Low | None
Duggan et al, 1999^145^ Duggan et al, 2004^146^, | Yes | Yes | Yes | Low | None
DuMont et al, 2008^93^ DuMont et al, 2010^94^ (Healthy Families New York) | Yes | Yes | Yes | Low | None
Easterbrooks et al, 2013^107^ (Healthy Families Massachusetts) | Yes | Yes | Yes | Low | None
Fergusson et al, 2005^108^ Fergusson et al, 2013^109^ (Early Start Program) | Probably yes | Yes | Yes | Low | Authors reported that “no blinding to assignment was undertaken,” which suggests that study personnel, assessors, and participants were not blinded. Child abuse and neglect outcomes only assessed via parent report using severe/very severe assault subscale of the Parent-Child Tactics Scale and parent report of involvement with CPS. The latter is subject to bias without confirmatory data from child welfare records. Authors provide additional CAN data: 7 children were admitted to the hospital for child abuse and neglect (5 from control group and 2 from Early Start group).
Finello et al, 1998^114^ | Yes | Yes | Yes | Low | None
Gray et al, 1977^136^ Gray et al, 1979^135^ | No information | Probably yes | Yes | Uncertain because no information | Children were assessed for the presence of incidents of “abnormal parenting practices” including verified reports of abuse and neglect to the Central Child Abuse registry, injury secondary to lack of adequate care/surgery or suspicious for inflicted trauma, failure to thrive thought secondary to deprivation, relinquishments, foster care placements, parental kidnappings. More specific information about outcomes not specified.
Guyer et al, 2003^115^ Minkovitz et al, 2007^116^ (Healthy Steps for Young Children) | Yes | Yes | Yes | Low | None
Hardy and Streett, 1989^173^ (Child and Youth Program) | Yes | Yes | Probably yes | Low | None
Infante-Rivard et al, 1989^174^ | Probably no | Yes | Probably yes | Some concerns | Outcome information obtained during followup visit. Authors did not mention whether outcomes are ascertained by review of medical records and it sounds like they asked mothers about health outcomes “at the 15-month visit, information on the child’s disease status and immunization during the preceding year was obtained.”
Kitzman et al, 1997^96^ Olds et al, 2007^97^ (The Memphis Trial) | Yes | Yes | Yes | Low | None
Koniak-Griffin et al, 2002^175^ Koniak-Griffin et al, 2003^171^ (Early Intervention Program) | Yes | Yes | Yes | Low | None
Lam et al, 2009^103^ | Yes | Yes | Probably yes | Low | None
Larson, 1980^110^ | Yes | Yes | Yes | Low | None
Lowell et al, 2011^117^ (Child FIRST) | Yes | Yes | Yes | Low | None
Marcenko and Spence, 1994^118^ | Probably yes | Yes | Yes | Low | None
Mejdoubi et al, 2015^176^ (VoorZorg) | Yes | Yes | Yes | Low | None
Norr et al, 2003^177^ (REACH-Futures) | Yes | No | Probably yes | Some concerns | Primary benefit outcome is reported abuse or neglect, which were not verified against official CPS records. Authors noted potential underestimate because only more serious cases tend to be reported and families may want to conceal these incidents during self-report.
Olds et al, 1986^98^ Olds et al, 1994^99^ Olds et al, 1997^100^ Eckenrode et al, 2000^101^ Zielinski et al, 2009^102^ (The Elmira Trial) | Yes | Yes | Yes | Low | None
Paradis et al, 2013^178^ (Building Healthy Children) | Yes | Probably yes | Probably yes | Low | None
Robling et al, 2016^90^ | Yes | Yes | Yes | Low | None
Sadler et al, 2013^95^ (Minding the Baby) | Probably yes | Probably yes | Yes | Some concerns | No information on how CPS outcomes were measured: unclear whether record-based or self-report.
Siegel et al, 1980^89^ | Probably yes | Yes | Yes | Low | None
Silovsky et al, 2011^111^ (SafeCare+) | Yes | Yes | Yes | Low | None
Wagner and Clayton, 1999^179^ (PAT: Salinas Valley) | Yes | Yes | Yes | Low | None
Wagner and Clayton, 1999^179^ (PAT: Teen) | Yes | Yes | Yes | Low | None
Wiggins et al, 2005^121^ Wiggins et al, 2004^120^ (The Social Support and Family Health Study) | Probably no | NA | Probably yes | Some concerns | All outcomes are based on parent self-report and not verified against medical records.

Abbreviations: CAN=Child abuse and neglect; CPS=child protective services; NA=not applicable; PAT=Parents as Teachers.

Appendix E Table 5 Quality Ratings for Randomized, Controlled Trials, Part 5

Author, Year, Program/Trial Name | 20. Is the reported effect estimate unlikely to be selected, on the basis of the results, from multiple outcomes measurements within the domain, multiple analyses, or different subgroups?^*^ | Bias arising from selection of reported results? | Comments
Barlow et al, 2007^104^ McIntosh et al, 2009^105^ (Family Partnership Model) | Probably yes | Low | None
Barth, 1991^134^ (Child Parent Enrichment Program) | Yes | Low | None
Brayden et al, 1993^112^ | Yes | Low | None
Brooten et al, 1986^113^ | Yes | Low | None
Bugental and Schwartz, 2009^106^ (Healthy Start+) | Probably yes | Low | None
Caldera et al, 2007^92^ Duggan et al, 2007^91^ (Healthy Families Alaska) | Yes | Low | None
DePanfilis and Dubowitz, 2005^172^ (Family Connections) | Probably yes | Low | None
Dubowitz et al, 2009^148^ (SEEK) | Probably yes | Low | None
Dubowitz et al, 2012^147^ (SEEK) | Yes | Low | None
Duggan et al, 1999^145^ Duggan et al, 2004^146^ | Yes | Low | None
DuMont et al, 2008^93^ DuMont et al, 2010^94^ (Healthy Families New York) | Yes | Low | None
Easterbrooks et al, 2013^107^ (Healthy Families Massachusetts) | Yes | Low | None
Fergusson et al, 2005^108^ Fergusson et al, 2013^109^ (Early Start Program) | Probably yes | Low | None
Finello et al, 1998^114^ | Probably yes | Low | None
Gray et al, 1977^136^ Gray et al, 1979^135^ | Yes | Low | None
Guyer et al, 2003^115^ Minkovitz et al, 2007^116^ (Healthy Steps for Young Children) | Yes | Low | None
Hardy and Streett, 1989^173^ (Child and Youth Program) | Yes | Low | None
Infante-Rivard et al, 1989^174^ | Probably yes | Low | None
Kitzman et al, 1997^96^ Olds et al, 2007^97^ (The Memphis Trial) | Yes | Low | None
Koniak-Griffin et al, 2002^175^ Koniak-Griffin et al, 2003^171^ (Early Intervention Program) | Probably yes | Low | None
Lam et al, 2009^103^ | Yes | Low | None
Larson, 1980^110^ | Yes | Low | None
Lowell et al, 2011^117^ (Child FIRST) | Yes | Low | None
Marcenko and Spence, 1994^118^ | Probably yes | Low | None
Mejdoubi et al, 2015^176^ (VoorZorg) | Yes | Low | None
Norr et al, 2003^177^ (REACH-Futures) | Probably no | Some concerns | This publication appears to be a subgroup analysis of the larger REACH-Futures study, which is a program run by the University of Illinois at Chicago through its community clinics. A separate publication reported program results on 666 study participants (including African American, Latina, and other ethnic groups). The relationship between the two studies is unclear. Cannot identify the mother study protocol to determine if there is indeed a reporting bias.
Olds et al, 1986^98^ Olds et al, 1994^99^ Olds et al, 1997^100^ Eckenrode et al, 2000^101^ Zielinski et al, 2009^102^ (The Elmira Trial) | Yes | Low | None
Paradis et al, 2013^178^ (Building Healthy Children) | Probably no | Some concerns | Unclear whether they are reporting on all of their prespecified outcomes of interest
Robling et al, 2016^90^ | Probably yes | Low | None
Sadler et al, 2013^95^ (Minding the Baby) | Yes | Low | None
Siegel et al, 1980^89^ | Probably yes | Low | None
Silovsky et al, 2011^111^ (SafeCare+) | Yes | Low | None
Wagner and Clayton, 1999^179^ (PAT: Sallinas Valley) | Yes | Low | None
Wagner and Clayton, 1999^179^ (PAT: Teen) | Yes | Low | None
Wiggins et al, 2005^121^ Wiggins et al, 2004^120^ (The Social Support and Family Health Study) | Yes | Low | None

* Questions 17 through 19 in the EPC’s risk of bias assessment form pertain to bias from measurement of harm outcomes, which are not applicable to included studies.

Abbreviations: REACH=Resources, Education and Care in the Home; PAT=Parents as Teachers.