# Appendix D Evidence Tables

Appendix D Table 1 Characteristic of Randomized, Controlled Trials Included in the Main Analysis for Child Maltreatment Prevention Benefits and Harms (KQs 1 and 2): Program Name, Funding Source, and Design

Appendix D Table 2 Characteristic of Randomized, Controlled Trials Included in the Main Analysis for Child Maltreatment Prevention Benefits and Harms (KQs 1 and 2): Study Arm 1 and Study Arm 2

Appendix D Table 3 Characteristic of Randomized, Controlled Trials Included in the Main Analysis for Child Maltreatment Prevention Benefits and Harms (KQs 1 and 2): Study Arm 3 and Study Arm 4

Appendix D Table 4 Characteristic of Randomized, Controlled Trials Included in the Main Analysis for Child Maltreatment Prevention Benefits and Harms (KQs 1 and 2): Population, Inclusion and Exclusion, and Risk Factors

Appendix D Table 5 Characteristic of Randomized, Controlled Trials Included in the Main Analysis for Child Maltreatment Prevention Benefits and Harms (KQs 1 and 2): Demographics

Appendix D Table 6 Characteristic of Randomized, Controlled Trials Included in the Sensitivity Analysis for Child Maltreatment Prevention Benefits and Harms (KQs 1 and 2): Program Name, Funding Source, and Design

Appendix D Table 7 Characteristic of Randomized, Controlled Trials Included in the Sensitivity Analysis for Child Maltreatment Prevention Benefits and Harms (KQs 1 and 2): Study Arm 1 and Study Arm 2

Appendix D Table 8 Characteristic of Randomized, Controlled Trials Included in the Sensitivity Analysis for Child Maltreatment Prevention Benefits and Harms (KQs 1 and 2): Study Arm 3 and Study Arm 4

Appendix D Table 9 Characteristic of Randomized, Controlled Trials Included in the Sensitivity Analysis for Child Maltreatment Prevention Benefits and Harms (KQs 1 and 2): Population, Inclusion and Exclusion, and Risk Factors

Appendix D Table 10 Characteristic of Randomized, Controlled Trials Included in the Sensitivity Analysis for Child Maltreatment Prevention Benefits and Harms (KQs 1 and 2): Demographics

Appendix D Table 11 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Main Analysis (KQ 1): Child Protective Services Reports and Actions, Categorical Outcomes

Appendix D Table 12 Benefits of Primary Care Interventions for Child Maltreatment Prevention from Randomized, Controlled Trials in the Sensitivity Analysis (KQ 1): Child Protective Services Reports and Actions, Categorical Outcomes

Appendix D Table 13 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Main Analysis (KQ 1): Child Protective Services Reports and Actions, Continuous Outcomes

Appendix D Table 14 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Main Analysis (KQ 1): Removal of Child from Home, Categorical Outcomes

Appendix D Table 15 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Sensitivity Analysis (KQ 1): Removal of Child From Home, Categorical Outcomes

Appendix D Table 16 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Main Analysis (KQ 1): Other Measures of Abuse or Neglect, Categorical Outcomes

Appendix D Table 17 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in Main Analysis (KQ 1): Other Measures of Abuse or Neglect, Continuous Outcomes

Appendix D Table 18 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Main Analysis (KQ 1): Injuries With a High Specificity for Abuse, Categorical Outcomes

Appendix D Table 19 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Sensitivity Analysis (KQ 1): Injuries With a High Specificity for Abuse, Categorical Outcomes

Appendix D Table 20 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Main Analysis (KQ 1): Emergency Department Visits, Categorical Outcomes

Appendix D Table 21 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Sensitivity Analysis (KQ 1): Emergency Department Visits, Categorical Outcomes

Appendix D Table 22 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Main Analysis (KQ 1): Emergency Department Visits, Continuous Outcomes

Appendix D Table 23 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Sensitivity Analysis (KQ 1): Emergency Department Visits, Continuous Outcomes

Appendix D Table 24 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Main Analysis (KQ 1): Hospitalization, Categorical Outcomes

Appendix D Table 25 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Sensitivity Analysis (KQ 1): Hospitalization, Categorical Outcomes

Appendix D Table 26 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Main Analysis (KQ 1): Hospitalization Continuous Outcomes

Appendix D Table 27 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Sensitivity Analysis (KQ 1): Hospitalization, Continuous Outcomes

Appendix D Table 28 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Main Analysis (KQ 1): Failure to Thrive, Categorical Outcomes

Appendix D Table 29 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Sensitivity Analysis (KQ 1): Failure to Thrive, Categorical Outcomes

Appendix D Table 30 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Main Analysis (KQ 1): Delayed or No Immunization, Categorical Outcomes

Appendix D Table 31 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Sensitivity Analysis (KQ 1): Delayed or No Immunization, Categorical Outcomes

Appendix D Table 32 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Main Analysis (KQ 1): Decreased Internalizing, Externalizing, or Internalizing and Externalizing Behaviors, Categorical Outcome

Appendix D Table 33 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Sensitivity Analysis (KQ 1): Decreased Internalizing, Externalizing, or Internalizing and Externalizing Behaviors, Categorical

Appendix D Table 34 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Main Analysis (KQ 1): Decreased Internalizing, Externalizing, or Internalizing and Externalizing Behaviors, Continuous Outcome

Appendix D Table 35 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Sensitivity Analysis (KQ 1): Decreased Internalizing, Externalizing, or Internalizing and Externalizing Behaviors, Continuous Outcome

Appendix D Table 36 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Main Analysis (KQ 1): Other Social, Emotional, and Developmental Problems Not Otherwise Categorized, Categorical Outcome

Appendix D Table 37 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Main Analysis (KQ 1): Other Social, Emotional, and Developmental Problems Not Otherwise Categorized, Continuous Outcomes

Appendix D Table 38 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Main Analysis (KQ 1)” Healthy Social-Emotional Development Based on Bayley Scales of Infant Development, Categorical Outcome

Appendix D Table 39 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Main Analysis (KQ 1): Healthy Social-Emotional Development Based on Bayley Scales of Infant Development, Continuous Outcome

Appendix D Table 40 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Sensitivity Analysis (KQ 1): Healthy Social-Emotional Development Based on Bayley Scales of Infant Development, Continuous Outcome

Appendix D Table 41 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Main Analysis (KQ 1): Other Measures of Healthy Social-Emotional Development and Developmental Delays, Categorical Outcome

Appendix D Table 42 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Sensitivity Analysis (KQ 1): Other Measures of Healthy Social-Emotional Development and Developmental Delays, Categorical Outcome

Appendix D Table 43 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Main Analysis (KQ 1): Other Measures of Healthy Social-Emotional Development and Developmental Delays, Continuous Outcome

Appendix D Table 44 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Main Analysis (KQ 1): School Attendance and Performance, Categorical Outcome

Appendix D Table 45 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Main Analysis (KQ 1): School Attendance and Performance, Continuous Outcomes

Appendix D Table 46 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Main Analysis (KQ 1): Mortality, Categorical Outcome

Appendix D Table 47 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Sensitivity Analysis (KQ 1): Mortality, Categorical Outcome

Appendix D Table 48 Benefits of Primary Care Interventions for Child Maltreatment Prevention From Randomized, Controlled Trials in the Main Analysis (KQ 1): Combination Adverse Neonatal Outcomes, Categorical Outcome