# Appendix C Excluded Studies

## Appendix C Reasons for Exclusion

Exclusion Codes:

- EX1: Ineligible publication type
- EX 2: Ineligible population
- EX 3: Ineligible/no intervention
- EX 4: Ineligible/no comparison
- EX 5: Ineligible/no outcomes
- EX 6: Ineligible/nonclinical setting
- EX 7: Ineligible study design
- EX 8: Ineligible country/region
- EX 9: Not in English
- EX 10: Systematic reviews used for handsearch
- EX 11: Ongoing studies with no publications
- EX 12: Irretrievable
- EX 13: Poor quality

1 Allen KA. The neonatal nurse’s role in preventing abusive head trauma. Adv Neonatal Care. 2014 Oct;14(5):336–42. doi: 10.1097/ANC.0000000000000117. PMID: 25137601. Exclusion Code: X4.25137601
2 Altman RL, Canter J, Patrick PA, . Parent education by maternity nurses and prevention of abusive head trauma. Pediatrics. 2011 Nov;128(5):e1164–72. doi: 10.1542/peds.2010-3260. PMID: 22025587. Exclusion Code: X7.22025587
3 Anderson CL. The parenting profile assessment: screening for child abuse. Appl Nurs Res. 1993 Feb;6(1):31–8. PMID: 8439176. Exclusion Code: X3.8439176
4 Anderst J, Teran P, Dowd MD, . The association of the rapid assessment of supervision scale score and unintentional childhood injury. Child Maltreat. 2015 May;20(2):141–5. doi: 10.1177/1077559514566450. PMID: 25601937. Exclusion Code: X3.25601937
5 Appleyard K, Berlin LJ, Rosanbalm KD, . Preventing early child maltreatment: implications from a longitudinal study of maternal abuse history, substance use problems, and offspring victimization. Prev Sci. 2011 Jun;12(2):139–49. doi: 10.1007/s11121-010-0193-2 [doi]. PMID: 21240556. Exclusion Code: X3.21240556
6 Armstrong K, Morris J. Promoting secure attachment, maternal mood and child health in a vulnerable population: a randomized controlled trial. J Paediatr Child Health. 2000;36(6):555–62. Exclusion Code: X5.11115031
7 Armstrong KL, Fraser JA, Dadds MR, . A randomized, controlled trial of nurse home visiting to vulnerable families with newborns. J Paediatr Child Health. 1999 Jun;35(3):237–44. PMID: 10404442. Exclusion Code: X5.10404442
8 Avellar SA, Supplee LH. Effectiveness of home visiting in improving child health and reducing child maltreatment. Pediatrics. 2013 Nov;132: Suppl 2:S90–9. doi: 10.1542/peds.2013-1021G. PMID: 24187128. Exclusion Code: X5.24187128
9 Ayerle GM, Makowsky K, Schucking BA. Key role in the prevention of child neglect and abuse in Germany: continuous care by qualified family midwives. Midwifery. 2012 Aug;28(4):E469–77. doi: 10.1016/j.midw.2011.05.009. PMID: 21782297. Exclusion Code: X4.21782297
10 Barlow A, Mullany B, Neault N, . Effect of a paraprofessional home-visiting intervention on American Indian teen mothers’ and infants’ behavioral risks: a randomized controlled trial. Am J Psychiatry. 2013 Jan;170(1):83–93. doi: 10.1176/appi.ajp.2012.12010121 [doi]. PMID: 23409290. Exclusion Code: X5.23409290
11 Barlow A, Varipatis-Baker E, Speakman K, . Home-visiting intervention to improve child care among American Indian adolescent mothers: a randomized trial. Arch Pediatr Adolesc Med. 2006 Nov;160(11):1101–7. doi: 10.1001/archpedi.160.11.1101. PMID: 17088511. Exclusion Code: X5.17088511
12 Barlow J, Sembi S, Gardner F, . An evaluation of the parents under pressure programme: a study protocol for an RCT into its clinical and cost effectiveness. Trials. 2013;14:210. doi: 10.1186/1745-6215-14-210. PMID: 23841920. Exclusion Code: X5.23841920
13 Barnes J, Aistrop D, Allen E, . First steps: study protocol for a randomized controlled trial of the effectiveness of the Group Family Nurse Partnership (gFNP) program compared to routine care in improving outcomes for high-risk mothers and their children and preventing abuse. Trials. 2013;14:285. doi: 10.1186/1745-6215-14-285. PMID: 24011061. Exclusion Code: X5.24011061
14 Barth RP. An experimental evaluation of in-home child abuse prevention services. Child Abuse Negl. 1991;15(4):363–75. PMID: 1959070. Exclusion Code: X13.1959070
15 Bartu A, Sharp J, Ludlow J, . Postnatal home visiting for illicit drug‐using mothers and their infants: A randomised controlled trial. Aust N Z J Obstet Gynaecol. 2006;46(5):419–26. Exclusion Code: X5.16953857
16 Ben-Arieh A, McDonell J. Child safety measure as a proxy for child maltreatment: Preliminary evidence for the potential and validity of using ICD-9 coded hospital discharge data at the community level. Children and Youth Services Review. 2009;31(8):873–8. doi: 10.1016/j.childyouth.2009.04.004. Exclusion Code: X3.
17 Berlin LJ, Shanahan M, Appleyard Carmody K. Promoting supportive parenting in new mothers with substance-use problems: A pilot randomized trial of residential treatment plus an attachment-based parenting program. Infant Mental Health Journal. 2014;35(1):81–5. Exclusion Code: X5.25424409
18 Bernard K, Dozier M, Bick J, . Enhancing attachment organization among maltreated children: results of a randomized clinical trial. Child Dev. 2012 Mar–Apr;83(2):623–36. doi: 10.1111/j.1467-8624.2011.01712.x [doi]. PMID: 22239483. Exclusion Code: X2.22239483
19 Bernard K, Frost A, Bennett CB, . Maltreatment and diurnal cortisol regulation: A meta-analysis. Psychoneuroendocrinology. 2017 Apr;78:57–67. doi: 10.1016/j.psyneuen.2017.01.005. PMID: 28135879. Exclusion Code: X3.28167370
20 Black MM, Bentley ME, Papas MA, . Delaying second births among adolescent mothers: a randomized, controlled trial of a home-based mentoring program. Pediatrics. 2006;118(4):e1087–e99. Exclusion Code: X5.17015500
21 Black MM, Nair P, Kight C, . Parenting and early development among children of drug-abusing women - effects of home intervention. Pediatrics. 1994 Oct;94(4):440–8. PMID: WOS:A1994PK84000005. Exclusion Code: X5.7936850
22 Blumberg EJ, Chadwick MW, Fogarty LA, . The Touch Discrimination Component of Sexual Abuse Prevention Training Unanticipated Positive Consequences. Journal of Interpersonal Violence. 1991;6(1):12–28. Exclusion Code: X6.
23 Bogat GA, McGrath MP. Preschoolers’ cognitions of authority, and its relationship to sexual abuse education. Child Abuse Negl. 1993;17(5):651–62. Exclusion Code: X6.8221219
24 Bonuck K. Birth to Three: a pragmatic clinical trial for child maltreatment prevention Albert Einstein College of Medicine, Department of Family and Social Medicine. 2012. Exclusion Code: X11.
25 Boston Medical Center. A Pilot Intervention With Families of Children With Special Health Care Needs. In: ClinicalTrials.gov [Internet]. Bethesda, MD: National Library of Medicine. [cited 2016]. https://ClinicalTrials.gov/show/NCT02742831. NLM Identifier: NCT02742831. Exclusion Code: X11.
26 Boston Medical Center. A Medical Home-Based Intervention to Prevent Child Neglect in High-Risk Families. In: ClinicalTrials.gov [Internet]. Bethesda, MD: National Library of Medicine. [cited 2016]. https://ClinicalTrials.gov/show/NCT02857673. NLM Identifier: NCT02857673. Exclusion Code: X11.
27 Britner PA, Reppucci ND. Prevention of child maltreatment: Evaluation of a parent education program for teen mothers. Journal of Child and Family Studies. 1997;6(2):165–75. Exclusion Code: X7.
28 Bröning S, Wiedow A, Wartberg L, . Targeting children of substance-using parents with the community-based group intervention TRAMPOLINE: a randomised controlled trial-design, evaluation, recruitment issues. BMC Public Health. 2012;12((Bröning S.) University Medical Centre Hamburg-Eppendorf, Centre for Psychosocial Medicine, German Centre for Addiction Research in Childhood and Adolescence, Hamburg, Germany.):223. Exclusion Code: X5.22439919
29 Brunk M, Henggeler SW, Whelan JP. Comparison of multisystemic therapy and parent training in the brief treatment of child abuse and neglect. J Consult Clin Psychol. 1987 Apr;55(2):171–8. PMID: 3571669. Exclusion Code: X2.3571669
30 Bugental DB, Ellerson PC, Lin EK, . A cognitive approach to child abuse prevention. J Fam Psychol. 2002 Sep;16(3):243–58. PMID: 12238408. Exclusion Code: X5.12238408
31 Byrne S, Rodrigo MJ, Maiquez ML. Patterns of individual change in a parenting program for child maltreatment and their relation to family and professional environments. Child Abuse Negl. 2014 Mar;38(3):457–67. doi: 10.1016/j.chiabu.2013.12.008. PMID: 24518441. Exclusion Code: X4.24518441
32 Caron EB, Weston-Lee P, Haggerty D, . Community implementation outcomes of Attachment and Biobehavioral Catch-up. Child Abuse Negl. 2016;53((Caron E.B.; Haggerty D.; Dozier M.) Department of Brain and Psychological Sciences, University of Delaware, Newark, United States):128–37. Exclusion Code: X2.26746112
33 Casillas KL, Fauchier A, Derkash BT, . Implementation of evidence-based home visiting programs aimed at reducing child maltreatment: A meta-analytic review. Child Abuse Negl. 2016;53((Casillas K.L.; Fauchier A.; Derkash B.T.; Garrido E.F.) Kempe Center for the Prevention and Treatment of Child Abuse and Neglect, University of Colorado School of Medicine, United States):64–80. Exclusion Code: X10.26724823
34 Center on Child Abuse Prevention Research. Intensive home visitation: A randomized trial, follow-up, and risk assessment study of Hawaii’s Healthy Start program Final report prepared for the National Center on Child Abuse and Neglect, United States Department of Health and Human Services (NCCAN Grant #90-CA-1511). Chicago, IL: National Committee to Prevent Child Abuse, Center on Child Abuse Prevention Research; June 1996. Exclusion Code: X12.
35 Centers for Disease Control and Prevention. Children Benefit When Parents Have Safe, Stable, Nurturing Relationships. Atlanta, GA: Centers for Disease Control and Prevention. http://www.cdc.gov/violenceprevention/pdf/ssnrs-for-parents.pdf. Accessed February 10, 2016. Exclusion Code: X1.
36 Centers for Disease Control and Prevention. Guide to Community Preventive Services. Violence Prevention: Early Childhood Home Visitation. Atlanta, GA: Centers for Disease Control and Prevention; 2010. Exclusion Code: X12.
37 Centers for Disease Control and Prevention. Child Abuse and Neglect Prevention. Atlanta, GA: Centers for Disease Control and Prevention; 2015. http://www.cdc.gov/violenceprevention/childmaltreatment. Accessed August 3, 2017. Exclusion Code: X1.
38 Cerny JE, Inouye J. Utilizing the child abuse potential inventory in a community health nursing prevention program for child abuse. J Community Health Nurs. 2001 Winter;18(4):199–211. doi: 10.1207/S15327655JCHN1804_01. PMID: 11775554. Exclusion Code: X3.11775554
39 Cesario SK, Nava A, Bianchi A, . Functioning outcomes for abused immigrant women and their children 4 months after initiating intervention. Rev Panam Salud Publica. 2014 Jan;35(1):8–14. doi: [pii]. PMID: 24626442. Exclusion Code: X4.24626442
40 Chaffin M, Bard D, Bigfoot DS, . Is a structured, manualized, evidence-based treatment protocol culturally competent and equivalently effective among American Indian parents in child welfare? Child Maltreat. 2012 Aug;17(3):242–52. doi: 10.1177/1077559512457239. PMID: 22927674. Exclusion Code: X2.22927674
41 Chaffin M, Silovsky JF, Funderburk B, . Parent-child interaction therapy with physically abusive parents: efficacy for reducing future abuse reports. J Consult Clin Psychol. 2004 Jun;72(3):500–10. doi: 10.1037/0022-006x.72.3.500. PMID: 15279533. Exclusion Code: X2.15279533
42 Chavis A, Hudnut-Beumler J, Webb MW, . A brief intervention affects parents’ attitudes toward using less physical punishment. Child Abuse Negl. 2013 Dec;37(12):1192–201. doi: 10.1016/j.chiabu.2013.06.003. PMID: 23859768. Exclusion Code: X5.23859768
43 Chen M, Chan KL. Effects of Parenting Programs on Child Maltreatment Prevention: A Meta-Analysis. Trauma Violence Abuse. 2016 Jan;17(1):88–104. doi: 10.1177/1524838014566718. Exclusion Code: X8.25573846
44 Chen YC, Fortson BL, Tseng KW. Pilot evaluation of a sexual abuse prevention program for Taiwanese children. J Child Sex Abus. 2012;21(6):621–45. doi: 10.1080/10538712.2012.726699 [doi]. PMID: 23194138. Exclusion Code: X3.23194138
45 Cheng S, Kondo N, Aoki Y, . The effectiveness of early intervention and the factors related to child behavioural problems at age 2: a randomized controlled trial. Early Hum Dev. 2007 Oct;83(10):683–91. doi: 10.1016/j.earlhumdev.2007.01.008. PMID: 17317044. Exclusion Code: X5.17317044
46 Christensen ML, Schommer BL, Velasquez J. Part I: An Interdisciplinary Approach To Preventing Child Abuse. MCN: The American Journal of Maternal/Child Nursing. 1984;9(2):108–12. Exclusion Code: X1.
47 Chu JT, Bullen P, Farruggia SP, . Parent and adolescent effects of a universal group program for the parenting of adolescents. Prev Sci. 2015 May;16(4):609–20. doi: 10.1007/s11121-014-0516-9 [doi]. PMID: 25373684. Exclusion Code: X5.25373684
48 Cohen JA, Mannarino AP, Iyengar S. Community treatment of posttraumatic stress disorder for children exposed to intimate partner violence: a randomized controlled trial. Arch Pediatr Adolesc Med. 2011 Jan;165(1):16–21. doi: 10.1001/archpediatrics.2010.247. PMID: 21199975. Exclusion Code: X5.21199975
49 Crooks CV, Scott K, Ellis W, . Impact of a universal school-based violence prevention program on violent delinquency: distinctive benefits for youth with maltreatment histories. Child Abuse Negl. 2011 Jun;35(6):393–400. doi: 10.1016/j.chiabu.2011.03.002. PMID: 21652072. Exclusion Code: X6.21652072
50 Dagenais C, Dutil J. Action in Childcare Settings training programme: development of an evidence-based training programme for the prevention of child maltreatment. Glob Health Promot. 2011 Mar;18(1):66–8. PMID: 21721305. Exclusion Code: X5.21721305
51 Daigneault I, Hebert M, McDuff P, . Evaluation of a sexual abuse prevention workshop in a multicultural, impoverished urban area. Journal of child sexual abuse. 2012;21(5):521–42. Exclusion Code: X6.22994691
52 Dakof GA, Cohen JB, Henderson CE, . A randomized pilot study of the Engaging Moms Program for family drug court. J Subst Abuse Treat. 2010 Apr;38(3):263–74. doi: 10.1016/j.jsat.2010.01.002. PMID: 20116961. Exclusion Code: X6.20116961
53 Dale R, Shanley DC, Zimmer-Gembeck MJ, . Empowering and protecting children by enhancing knowledge, skills and well-being: A randomized trial of Learn to BE SAFE with Emmy™. Child Abuse Negl. 2016;51((Dale R.; Shanley D.C.; Zimmer-Gembeck M.J.; White C.) School of Applied Psychology; Menzies Health Institute of Queensland, Griffith University, Gold Coast, Australia):368–78. Exclusion Code: X3.26360708
54 Dalziel K, Segal L. Home visiting programmes for the prevention of child maltreatment: cost-effectiveness of 33 programmes. Arch Dis Child. 2012 Sep;97(9):787–98. doi: 10.1136/archdischild-2011-300795. PMID: 22764090. Exclusion Code: X5.22764090
55 Damato EG, Dill PZ, Gennaro S, . The association between CNS direct care time and total time and very low birth weight infant outcomes. Clin Nurse Spec. 1993;7:75-. Exclusion Code: X4.8364834
56 Daro D, Dodge KA. Creating community responsibility for child protection: possibilities and challenges. Future Child. 2009 Fall;19(2):67–93. PMID: 19719023. Exclusion Code: X1.19719023
57 Daro D, McCurdy K. Interventions to prevent child maltreatment. In: Doll LS, ed Handbook of Injury and Violence Prevention Intervention. New York: Springer Publishers; 2007:137–56. Exclusion Code: X4.
58 Dawson P, van Doorninck WJ, Robinson JL. Effects of home-based, informal social support on child health. J Dev Behav Pediatr. 1989 Apr;10(2):63–7. PMID: 2708538. Exclusion Code: X7.2708538
59 del Campo SA, López SF. Evaluation of school-based child sexual abuse prevention program. Psicothema. 2006;18(1):1–8. Exclusion Code: X9.
60 DePanfilis D, Dubowitz H. Family connections: a program for preventing child neglect. Child Maltreat. 2005 May;10(2):108–23. doi: 10.1177/1077559505275252. PMID: 15798007. Exclusion Code: X13.15798007
61 Diamond G, Creed T, Gillham J, . Sexual trauma history does not moderate treatment outcome in Attachment-Based Family Therapy (ABFT) for adolescents with suicide ideation. J Fam Psychol. 2012 Aug;26(4):595–605. doi: 10.1037/a0028414. PMID: 22709259. Exclusion Code: X5.22709259
62 Dias MS, Smith K, DeGuehery K, . Preventing abusive head trauma among infants and young children: a hospital-based, parent education program. Pediatrics. 2005 Apr;115(4):e470–7. doi: 10.1542/peds.2004-1896. PMID: 15805350. Exclusion Code: X7.15805350
63 Dishion TJ, Mun CJ, Drake EC, . A transactional approach to preventing early childhood neglect: The Family Check-Up as a public health strategy. Dev Psychopathol. 2015 Nov;27(4 Pt 2):1647–60. doi: 10.1017/S0954579415001005. PMID: 26535950. Exclusion Code: X5.26535950
64 Dodge KA. Community prevention of child maltreatment Duke University, Center for Child and Family Policy. 2012. Exclusion Code: X11.
65 Dodge KA, Bierman KL, Coie JD, . Impact of early intervention on psychopathology, crime, and well-being at age 25. Am J Psychiatry. 2015;172(1):59–70. Exclusion Code: X2.25219348
66 Doom JR, Cicchetti D, Rogosch FA. Longitudinal patterns of cortisol regulation differ in maltreated and nonmaltreated children. J Am Acad Child Adolesc Psychiatry. 2014 Nov;53(11):1206–15. doi: 10.1016/j.jaac.2014.08.006. PMID: 25440310. Exclusion Code: X3.25440310
67 Dorsey S, Kerns SEU, Trupin EW, . Child Welfare Caseworkers as Service Brokers for Youth in Foster Care: Findings From Project Focus. Child Maltreatment. 2012;17(1):22–31. Exclusion Code: X2.22222293
68 Dorsey S, Pullmann MD, Berliner L, . Engaging foster parents in treatment: A randomized trial of supplementing trauma-focused cognitive behavioral therapy with evidence-based engagement strategies. Child Abuse Negl. 2014;38(9):1508–20. Exclusion Code: X2.24791605
69 Dubowitz H. The Safe Environment for Every Kid (SEEK) Model: helping promote children’s health, development, and safety: SEEK offers a practical model for enhancing pediatric primary care. Child Abuse Negl. 2014 Nov;38(11):1725–33. doi: 10.1016/j.chiabu.2014.07.011. PMID: 25443526. Exclusion Code: X1.25443526
70 Dubowitz H, Feigelman S, Lane W, . Pediatric primary care to help prevent child maltreatment: the Safe Environment for Every Kid (SEEK) Model. Pediatrics. 2009 Mar;123(3):858–64. doi: 10.1542/peds.2008-1376. PMID: 19255014. Exclusion Code: X13.19255014
71 Dubowitz H, Lane WG, Semiatin JN, . The SEEK model of pediatric primary care: can child maltreatment be prevented in a low-risk population? Acad Pediatr. 2012 Jul–Aug;12(4):259–68. doi: 10.1016/j.acap.2012.03.005. PMID: 22658954. Exclusion Code: X13.22658954
72 Duggan A, McFarlane E, Fuddy L, . Randomized trial of a statewide home visiting program: impact in preventing child abuse and neglect. Child Abuse Negl. 2004 Jun;28(6):597–622. doi: 10.1016/j.chiabu.2003.08.007. PMID: 15193851. Exclusion Code: X13.15193851
73 Duggan A, Windham A, McFarlane E, . Hawaii’s healthy start program of home visiting for at-risk families: evaluation of family identification, family engagement, and service delivery. Pediatrics. 2000 Jan;105(1 Pt 3):250–9. PMID: 10617732. Exclusion Code: X5.10617732
74 Duggan AK, McFarlane EC, Windham AM, . Evaluation of Hawaii’s Healthy Start Program. Future Child. 1999 Spring–Summer;9(1):66–90; discussion 177–8. PMID: 10414011. Exclusion Code: X13.10414011
75 Duke University. Durham Connects RCT Evaluation. In: ClinicalTrials.gov [Internet]. Bethesda, MD: National Library of Medicine. [cited 2011]. https://ClinicalTrials.gov/show/NCT01406184. NLM Identifier: NCT01406184. Exclusion Code: X3.
76 Duke University. Durham Connects RCT Evaluation II. In: ClinicalTrials.gov [Internet]. Bethesda, MD: National Library of Medicine. [cited 2013]. https://ClinicalTrials.gov/show/NCT01843036. NLM Identifier: NCT01843036. Exclusion Code: X3.
77 El-Kamary SS, Higman SM, Fuddy L, . Hawaii’s healthy start home visiting program: determinants and impact of rapid repeat birth. Pediatrics. 2004;114(3):e317–e26. Exclusion Code: X5.15342892
78 El-Mohandes AA, Katz KS, El-Khorazaty MN, . The effect of a parenting education program on the use of preventive pediatric health care services among low-income, minority mothers: a randomized, controlled study. Pediatrics. 2003 Jun;111(6 Pt 1):1324–32. PMID: 12777548. Exclusion Code: X5.12777548
79 El-Mohandes AA, Kiely M, Blake SM, . An intervention to reduce environmental tobacco smoke exposure improves pregnancy outcomes. Pediatrics. 2010 Apr;125(4):721–8. doi: 10.1542/peds.2009-1809. PMID: 20211945. Exclusion Code: X5.20211945
80 Eunice Kennedy Shriver National Institute of Child Health and Human Development. Health Behavior in School-Age Children: NEXT Longitudinal Study 2009-2013. In: ClinicalTrials.gov [Internet]. Bethesda, MD: National Library of Medicine. [cited 2009]. https://ClinicalTrials.gov/show/NCT01031160. NLM Identifier: NCT01031160. Exclusion Code: X3.
81 Euser S, Alink LR, Stoltenborgh M, . A gloomy picture: a meta-analysis of randomized controlled trials reveals disappointing effectiveness of programs aiming at preventing child maltreatment. BMC Public Health. 2015;15:1068. doi: 10.1186/s12889-015-2387-9. PMID: 26476980. Exclusion Code: X10.26476980
82 Faulkner A. Outside the box. Ment Health Today. 2015 May–Jun:15. PMID: 26529954. Exclusion Code: X1.26529954
83 Feigelman S, Dubowitz H, Lane W, . Training pediatric residents in a primary care clinic to help address psychosocial problems and prevent child maltreatment. Acad Pediatr. 2011 Nov–Dec;11(6):474–80. doi: 10.1016/j.acap.2011.07.005. PMID: 21959095. Exclusion Code: X2.21959095
84 Fergusson DM, Grant H, Horwood LJ, . Randomized trial of the Early Start program of home visitation: parent and family outcomes. Pediatrics. 2006 Mar;117(3):781–6. doi: 10.1542/peds.2005-1517. PMID: 16510658. Exclusion Code: X5.16510658
85 Field T, Widmayer S, Greenberg R, . Effects of parent training on teenage mothers and their infants. Pediatrics. 1982;69(6):703–7. Exclusion Code: X5.7079035
86 Finello KM, Litton KM, deLemos R, . Very low birth weight infants and their families during the first year of life: comparisons of psychosocial outcomes based on after-care services. J Perinatol. 1997;18(4):266–71. Exclusion Code: X2.
87 Firk C, Dahmen B, Lehmann C, . A mother-child intervention program in adolescent mothers and their children to improve maternal sensitivity, child responsiveness and child development (the TeeMo study): study protocol for a randomized controlled trial. Trials. 2015;16:230. doi: 10.1186/s13063-015-0747-5. PMID: 26012585. Exclusion Code: X5.26012585
88 Flynn L. The adolescent parenting program: improving outcomes through mentorship. Public Health Nurs. 1999 Jun;16(3):182–9. PMID: 10388335. Exclusion Code: X7.10388335
89 Fonseca A, Lopes C, Loureiro M, . How resilience really works: A review of evidence-based programs. Aten Primaria. 2013;45((Fonseca A., amdagf@gmail.com; Lopes C.; Loureiro M.; Colaco A.; Pereira A.; Eusebio J.; Colaco L.; Simoes C.; Lebre P.) UTL/FMH/Aventura Social, UNL/IHMT/CMDT, Portugal):17. Exclusion Code: X1.
90 Forman-Hoffman V, Knauer S, McKeeman J, . Child and adolescent exposure to trauma: comparative effectiveness of interventions addressing trauma other than maltreatment or family violence (Provisional abstract). Database of Abstracts of Reviews of Effects. 2013(2):1. PMID: DARE-12013015930. Exclusion Code: X3.
91 Fraser JA, Armstrong KL, Morris JP, . Home visiting intervention for vulnerable families with newborns: follow-up results of a randomized controlled trial. Child Abuse Negl. 2000 Nov;24(11):1399–429. PMID: 11128173. Exclusion Code: X5.11128173
92 George Mason University. Parent-Adolescent Interactions and Adolescent Development (PAIT). In: ClinicalTrials.gov [Internet]. Bethesda, MD: National Library of medicine. [cited 2012]. https://ClinicalTrials.gov/show/NCT01572441. NLM Identifier: NCT01572441. Exclusion Code: X5.
93 Gessner BD. The effect of Alaska’s home visitation program for high-risk families on trends in abuse and neglect. Child Abuse Negl. 2008;32(3):317–33. Exclusion Code: X7.18377990
94 Ghosh Ippen C, Harris WW, Van Horn P, . Traumatic and stressful events in early childhood: can treatment help those at highest risk? Child Abuse Negl. 2011 Jul;35(7):504–13. doi: 10.1016/j.chiabu.2011.03.009. PMID: 21816474. Exclusion Code: X5.21816474
95 Gillies D, Maiocchi L, Bhandari AP, . Psychological therapies for children and adolescents exposed to trauma. Cochrane Database Syst Rev. 2016 Oct 11;10:Cd012371. doi: 10.1002/14651858.cd012371. PMID: 27715713. Exclusion Code: X5.27726123
96 Goldman Fraser J, Lloyd SW, Murphy RA, . Child exposure to trauma: comparative effectiveness of interventions addressing maltreatment (Provisional abstract). Database of Abstracts of Reviews of Effects: Agency for Healthcare Research and Quality; 2013. p. 1. Exclusion Code: X2.
97 Goltz HH, Mena KC, Swank PR. Using growth curve analysis to examine challenges in instrumentation in longitudinal measurement in home visiting. J Evid Based Soc Work. 2014;11(1–2):127–38. doi: 10.1080/15433714.2013.845025 [doi]. PMID: 24405137. Exclusion Code: X5.24405137
98 Goyal NK, Teeters A, Ammerman RT. Home visiting and outcomes of preterm infants: a systematic review. Pediatrics. 2013 Sep;132(3):502–16. doi: 10.1542/peds.2013-0077. PMID: 23940238. Exclusion Code: X5.23940238
99 Graham AM, Yockelson M, Kim HK, . Effects of maltreatment and early intervention on diurnal cortisol slope across the start of school: a pilot study. Child Abuse Negl. 2012 Sep;36(9):666–70. doi: 10.1016/j.chiabu.2012.07.006. PMID: 22964372. Exclusion Code: X2.22964372
100 Gray JD, Cutler CA, Dean JG, . Prediction and prevention of child abuse and neglect. Child Abuse Negl. 1977;1(1):45–58. Exclusion Code: X13.
101 Gray JD, Cutler CA, Dean JG, . Prediction and prevention of child abuse. Semin Perinatol. 1979 Jan;3(1):85–90. PMID: 482971. Exclusion Code: X13.482971
102 Green AE, Trott E, Willging CE, . The role of collaborations in sustaining an evidence-based intervention to reduce child neglect. Child Abuse Negl. 2016 Mar;53:4–16. doi: 10.1016/j.chiabu.2015.11.013. PMID: 26712421. Exclusion Code: X5.26712422
103 Guterman NB, Tabone JK, Bryan GM, . Examining the effectiveness of home-based parent aide services to reduce risk for physical child abuse and neglect: six-month findings from a randomized clinical trial. Child Abuse Negl. 2013 Aug;37(8):566–77. doi: 10.1016/j.chiabu.2013.03.006. PMID: 23623622. Exclusion Code: X5.23623622
104 Hardy JB, Streett R. Family support and parenting education in the home: an effective extension of clinic-based preventive health care services for poor children. J Pediatr. 1989;115(6):927–31. Exclusion Code: X13.2585229
105 Hazzard A, Webb C, Kleemeier C, . Child sexual abuse prevention: evaluation and one-year follow-up. Child Abuse Negl. 1991;15(1–2):123–38. Exclusion Code: X6.2029665
106 Hébert M, Lavoie F, Piché C, . Proximate effects of a child sexual abuse prevention program in elementary school children☆,☆☆. Child Abuse Negl. 2001;25(4):505–22. Exclusion Code: X6.11370723
107 Helie S, Laurier C, Pineau-Villeneuve C, . A developmental approach to the risk of a first recurrence in child protective services. Child Abuse Negl. 2013 Dec;37(12):1132–41. doi: 10.1016/j.chiabu.2013.05.001. PMID: 23768933. Exclusion Code: X2.23768933
108 Hoft M, Haddad L. Screening Children for Abuse and Neglect: A Review of the Literature. J Forensic Nurs. 2017 Jan/Mar;13(1):26–34. doi: 10.1097/jfn.0000000000000136. PMID: 28192770. Exclusion Code: X3.28212197
109 Howard KS, Brooks-Gunn J. The role of home-visiting programs in preventing child abuse and neglect. The future of Children. 2009;19(2):119–46. Exclusion Code: X1.19719025
110 Hugo W. Moser Research Institute at Kennedy Krieger, Inc. FamilyLive Feasibility and Effectiveness Study. In: ClinicalTrials.gov [Internet]. Bethesda, MD: National Library of Medicine. [cited 2012]. https://ClinicalTrials.gov/show/NCT01524185. NLM Identifier: NCT01524185. Exclusion Code: X2.
111 Hurlburt MS, Nguyen K, Reid J, . Efficacy of the Incredible Years group parent program with families in Head Start who self-reported a history of child maltreatment. Child Abuse Negl. 2013 Aug;37(8):531–43. doi: 10.1016/j.chiabu.2012.10.008. PMID: 23306144. Exclusion Code: X5.23306144
112 Huxley P, Warner R. Primary prevention of parenting dysfunction in high-risk cases. Am J Orthopsychiatry. 1993;63(4):582. Exclusion Code: X7.8267098
113 Infante-Rivard C, Filion G, Baumgarten M, . A public health home intervention among families of low socioeconomic status. Child Health Care. 1989;18(2):102–7. Exclusion Code: X13.
114 Jacobsen SL, McKinney CH, Holck U. Effects of a dyadic music therapy intervention on parent-child interaction, parent stress, and parent-child relationship in families with emotionally neglected children: a randomized controlled trial. J Music Ther. 2014 Winter;51(4):310–32. doi: 10.1093/jmt/thu028. PMID: 25504176. Exclusion Code: X2.25504176
115 Johnston BD, Huebner CE, Anderson ML, . Healthy steps in an integrated delivery system: child and parent outcomes at 30 months. Arch Pediatr Adolesc Med. 2006 Aug;160(8):793–800. doi: 10.1001/archpedi.160.8.793. PMID: 16894077. Exclusion Code: X5.16894077
116 Jones CH, Erjavec M, Viktor S, . Outcomes of a Comparison Study into a Group-Based Infant Parenting Programme. J Child Fam Stud. 2016;25(11):3309–21. doi: 10.1007/s10826-016-0489-3. PMID: 27795658. Exclusion Code: X7.27795658
117 Jordan B, Tseng YP, Coombs N, . Improving lifetime trajectories for vulnerable young children and families living with significant stress and social disadvantage: the early years education program randomised controlled trial. BMC Public Health. 2014;14:965. doi: 10.1186/1471-2458-14-965. PMID: 25230995. Exclusion Code: X5.25230995
118 Jouriles EN, McDonald R, Rosenfield D, . Improving parenting in families referred for child maltreatment: a randomized controlled trial examining effects of Project Support. J Fam Psychol. 2010 Jun;24(3):328–38. doi: 10.1037/a0019281. PMID: 20545406. Exclusion Code: X2.20545406
119 Kan ML, Feinberg ME. Can a family-focused, transition-to-parenthood program prevent parent and partner aggression among couples with young children? Violence Vict. 2014;29(6):967–80. PMID: 25905139. Exclusion Code: X5.25905139
120 Katzev A, Pratt C, Henderson T, . Oregon’s Healthy Start Effort: 1997-98 Status Report. Corvalis, OR: Oregon State University Family Policy Program; 1999. Exclusion Code: X12.
121 Keenan HT, Leventhal JM. A case-control study to evaluate Utah’s shaken baby prevention program. Acad Pediatr. 2010 Nov–Dec;10(6):389–94. doi: 10.1016/j.acap.2010.08.005. PMID: 21075319. Exclusion Code: X7.21075319
122 Kelleher K, Gardner W, Coben J, . Co-Occurring Intimate Partner Violence and Child Maltreatment: Local Policies/Practices and Relationships to Child Placement, Family Services, and Residence. Final report to the National Institute of Justice; 2006. Exclusion Code: X3.
123 Kelley ML, Bravo AJ, Braitman AL, . Behavioral Couples Treatment for Substance Use Disorder: Secondary Effects on the Reduction of Risk for Child Abuse. J Subst Abuse Treat. 2016 Mar;62:10–9. doi: 10.1016/j.jsat.2015.11.008. PMID: 26726964. Exclusion Code: X7.26742725
124 Kiely M, El-Mohandes AA, El-Khorazaty MN, . An integrated intervention to reduce intimate partner violence in pregnancy: a randomized controlled trial. Obstet Gynecol. 2010 Feb;115(2 Pt 1):273–83. doi: 10.1097/AOG.0b013e3181cbd482. PMID: 20093899. Exclusion Code: X5.20093899
125 Kitzman H, Olds DL, Sidora K, . Enduring effects of nurse home visitation on maternal life course: a 3-year follow-up of a randomized trial. JAMA. 2000 Apr 19;283(15):1983–9. PMID: 10789666. Exclusion Code: X5.10789666
126 Kolko DJ, Baumann BL, Herschell AD, . Implementation of AF-CBT by community practitioners serving child welfare and mental health: a randomized trial. Child Maltreat. 2012 Feb;17(1):32–46. doi: 10.1177/1077559511427346. PMID: 22278087. Exclusion Code: X2.22278087
127 Kolko DJ, Moser JT, Hughes J. Classroom training in sexual victimization awareness and prevention skills: An extension of the Red Flag/Green Flag people program. Journal of Family Violence. 1989;4(1):25–45. Exclusion Code: X6.
128 Koniak-Griffin D, Anderson NL, Brecht M-L, . Public health nursing care for adolescent mothers: impact on infant health and selected maternal outcomes at 1 year postbirth. J Adolesc Health. 2002;30(1):44–54. Exclusion Code: X13.
129 Koniak-Griffin D, Verzemnieks IL, Anderson NL, . Nurse visitation for adolescent mothers: two-year infant health and maternal outcomes. Nurs Res. 2003 Mar–Apr;52(2):127–36. PMID: 12657988. Exclusion Code: X13.12657988
130 Korfmacher J. The Kempe Family Stress Inventory: a review. Child Abuse Negl. 2000 Jan;24(1):129–40. PMID: 10660015. Exclusion Code: X3.10660015
131 Kowalik J, Weller J, Venter J, . Cognitive behavioral therapy for the treatment of pediatric posttraumatic stress disorder: A review and meta-analysis. J Behav Ther Exp Psychiatry. 2011;42(3):405–13. Exclusion Code: X2.21458405
132 Koziol-McLain J, Vandal AC, Nada-Raja S, . A web-based intervention for abused women: the New Zealand isafe randomised controlled trial protocol. BMC Public Health. 2015;15:56. doi: 10.1186/s12889-015-1395-0. PMID: 25637195. Exclusion Code: X2.25637195
133 Kraizer S, Witte SS, FRYER G. Child sexual abuse prevention programs: what makes them effective in protecting children. Child Today. 1989;18(5):23–7. Exclusion Code: X1.
134 Kralik SF, Yasrebi M, Supakul N, . Diagnostic Performance of Ultrafast Brain MRI for Evaluation of Abusive Head Trauma. AJNR Am J Neuroradiol. 2017 Apr;38(4):807–13. doi: 10.3174/ajnr.A5093. PMID: 28167370. Exclusion Code: X3.28183837
135 Lanier P. (SDAS) Preventing maltreatment and promoting healthy infant development with high-risk maternal and child populations: an effectiveness study of nurse home visiting University of North Carolina at Chapel Hill, School of Social Work. 2014. Exclusion Code: X11.
136 LeCroy CW, Krysik J. Randomized trial of the healthy families Arizona home visiting program. Children and Youth Services Review. 2011 10//;33(10):1761–6. doi: 10.1016/j.childyouth.2011.04.036. Exclusion Code: X5.
137 Lee YK-s, Tang CS-k. Evaluation of a sexual abuse prevention program for female Chinese adolescents with mild mental retardation. American journal on mental retardation. 1998;103(2):105–16. Exclusion Code: X6.9779279
138 Leventhal JM, Pew MC, Berg AT, . Use of health services by children who were identified during the postpartum period as being at high risk of child abuse or neglect. Pediatrics. 1996 Mar;97(3):331–5. PMID: 8604265. Exclusion Code: X7.8604265
139 Lieberman AF, Chu A, Van Horn P, . Trauma in early childhood: empirical evidence and clinical implications. Dev Psychopathol. 2011 May;23(2):397–410. doi: 10.1017/S0954579411000137. PMID: 23786685. Exclusion Code: X1.23786685
140 Lindberg DM. Using clinical design support to improve child physical abuse testing University of Colorado Denver, Anschutz Medical Campus, School of Medicine, Department of Emergency Medicine / (720) 848-6777 2016. Exclusion Code: X3.
141 Love JM, Kisker EE, Ross C, . The effectiveness of early head start for 3-year-old children and their parents: lessons for policy and programs. Dev Psychol. 2005;41(6):885. Exclusion Code: X5.16351335
142 Lutzker JR, Rice JM. Project 12-ways: measuring outcome of a large in-home service for treatment and prevention of child abuse and neglect. Child Abuse Negl. 1984;8(4):519–24. Exclusion Code: X2.6542822
143 Macdonald G, Lewis J, Macdonald K, . THE SAAF STUDY: evaluation of the Safeguarding Children Assessment and Analysis Framework (SAAF), compared with management as usual, for improving outcomes for children and young people who have experienced, or are at risk of, maltreatment: study protocol for a randomised controlled trial. Trials. 2014;15:453. doi: 10.1186/1745-6215-15-453. PMID: 25413974. Exclusion Code: X2.25413974
144 MacMillan HL, Canadian Task Force on Preventive Health C. Preventive health care, 2000 update: prevention of child maltreatment. CMAJ. 2000 Nov 28;163(11):1451–8. PMID: 11192650. Exclusion Code: X1.11192650
145 MacMillan HL, Thomas BH, Jamieson E, . Effectiveness of home visitation by public-health nurses in prevention of the recurrence of child physical abuse and neglect: a randomised controlled trial. Lancet. 2005 May 21–27;365(9473):1786–93. doi: 10.1016/s0140-6736(05)66388-x. PMID: 15910951. Exclusion Code: X2.15910951
146 Margolis PA, Stevens R, Bordley WC, . From concept to application: the impact of a community-wide intervention to improve the delivery of preventive services to children. Pediatrics. 2001;108(3):e42–e. Exclusion Code: X7.11533360
147 Marshall E. An experiment in zero parenting. Science. 2014 Aug 15;345(6198):752–4. doi: 10.1126/science.345.6198.752. PMID: 25124426. Exclusion Code: X1.25124426
148 Martinello E. Reviewing strategies for risk reduction of sexual abuse of children with intellectual disabilities: a focus on early intervention (Provisional abstract). Database of Abstracts of Reviews of Effects; 2014. p. 167–74. Exclusion Code: X1.
149 McCormick E, Kerns SE, McPhillips H, . Training pediatric residents to provide parent education: a randomized controlled trial. Acad Pediatr. 2014 Jul–Aug;14(4):353–60. doi: 10.1016/j.acap.2014.03.009. PMID: 24976347. Exclusion Code: X5.24976347
150 McFarlane E, Burrell L, Crowne S, . Maternal relationship security as a moderator of home visiting impacts on maternal psychosocial functioning. Prev Sci. 2013 Feb;14(1):25–39. doi: 10.1007/s11121-012-0297-y [doi]. PMID: 23104075. Exclusion Code: X5.23104075
151 McGrath PJ, Sourander A, Lingley-Pottie P, . Remote population-based intervention for disruptive behavior at age four: study protocol for a randomized trial of Internet-assisted parent training (Strongest Families Finland-Canada). BMC Public Health. 2013;13((McGrath P.J.; Sourander A.; Lingley-Pottie P.; Ristkari T.; Cunningham C.; Huttunen J.; Filbert K.; Aromaa M.; Corkum P.; Hinkka-Yli-Salomäki S.; Kinnunen M.; Lampi K.; Penttinen A.; Sinokki A.; Unruh A.; Vuorio J.; Watters C.) Centre for Research in Family Health, IWK Health Centre, 5850/5980 University Avenue, P,O, Box 9700, Halifax, Nova Scotia B3K 6R8, Canada. patrick.mcgrath@iwk.nshealth.ca):985. Exclusion Code: X5.24139323
152 McGuigan WM, Vuchinich S, Pratt CC. Domestic violence, parents’ view of their infant, and risk for child abuse. J Fam Psychol. 2000 Dec;14(4):613–24. PMID: 11132484. Exclusion Code: X7.11132484
153 McMahon-Howard J, Reimers B. An evaluation of a child welfare training program on the commercial sexual exploitation of children (CSEC). Eval Program Plann. 2013 Oct;40:1–9. doi: 10.1016/j.evalprogplan.2013.04.002. PMID: 23689077. Exclusion Code: X3.23689077
154 McWhirter PT. Differential therapeutic outcomes of community-based group interventions for women and children exposed to intimate partner violence. J Interpers Violence. 2011 Aug;26(12):2457–82. doi: 10.1177/0886260510383026. PMID: 20889533. Exclusion Code: X5.20889533
155 Mejdoubi J, van den Heijkant S, Struijf E, . Addressing risk factors for child abuse among high risk pregnant women: design of a randomised controlled trial of the nurse family partnership in Dutch preventive health care. BMC Public Health. 2011;11:823. doi: 10.1186/1471-2458-11-823. PMID: 22017924. Exclusion Code: X5.22017924
156 Mejdoubi J, van den Heijkant SC, van Leerdam FJ, . The effect of VoorZorg, the Dutch nurse-family partnership, on child maltreatment and development: a randomized controlled trial. PLoS One. 2015;10(4):e0120182. doi: 10.1371/journal.pone.0120182. PMID: 25830242. Exclusion Code: X13.25830242
157 Miyamoto S, Dharmar M, Boyle C, . Impact of telemedicine on the quality of forensic sexual abuse examinations in rural communities. Child Abuse Negl. 2014 Sep;38(9):1533–9. doi: 10.1016/j.chiabu.2014.04.015. PMID: 24841062. Exclusion Code: X2.24841062
158 Molnar BE, Buka SL, Brennan RT, . A multilevel study of neighborhoods and parent-to-child physical aggression: results from the project on human development in Chicago neighborhoods. Child Maltreat. 2003 May;8(2):84–97. PMID: 12735711. Exclusion Code: X4.12735711
159 Moyer VA. Primary care interventions to prevent child maltreatment: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2013 Aug 20;159(4):289–95. doi: 10.7326/0003-4819-159-4-201308200-00667. PMID: 23752681. Exclusion Code: X10.23752681
160 Mulsow MH, Murry VM. Parenting on edge: economically stressed, single, African American adolescent mothers. Journal of Family Issues. 1996;17(5):704–21. Exclusion Code: X7.
161 Multisite Violence Prevention Project. Mediators of effects of a selective family-focused violence prevention approach for middle school students. Prev Sci. 2012 Feb;13(1):1–14. doi: 10.1007/s11121-011-0245-2 [doi]. PMID: 21932067. Exclusion Code: X5.21932067
162 Nair P, Schuler ME, Black MM, . Cumulative environmental risk in substance abusing women: early intervention, parenting stress, child abuse potential and child development. Child Abuse Negl. 2003;27(9):997–1017. Exclusion Code: X5.14550328
163 National Survey of Child and Adolescent Well-Being. Child Well-Being Spotlight. Washington, DC: Administration for Children and Families, U.S. Department of Health and Human Services; 2012. http://www.acf.hhs.gov/sites/default/files/opre/youth_spotlight_v7.pdf. Accessed February 10, 2016. Exclusion Code: X2.
164 Niccols A, Milligan K, Smith A, . Integrated programs for mothers with substance abuse issues and their children: a systematic review of studies reporting on child outcomes (Structured abstract). Child Abuse Negl. 2012(4):308–22. PMID: DARE-12012020731. Exclusion Code: X5.
165 Norr KF, Crittenden KS, Lehrer EL, . Maternal and infant outcomes at one year for a nurse-health advocate home visiting program serving African Americans and Mexican Americans. Public Health Nurs. 2003 May–Jun;20(3):190–203. PMID: 12716399. Exclusion Code: X13.12716399
166 Oldfield D, Hays BJ, Megel ME. Evaluation of the effectiveness of Project Trust: an elementary school-based victimization prevention strategy. Child Abuse Negl. 1996;20(9):821–32. Exclusion Code: X6.8886466
167 Olds D, Henderson CR, Jr., Kitzman H, . Effects of prenatal and infancy nurse home visitation on surveillance of child maltreatment. Pediatrics. 1995 Mar;95(3):365–72. PMID: 7862474. Exclusion Code: X2.7862474
168 Olds DL, Kitzman H, Cole R, . Effects of nurse home-visiting on maternal life course and child development: age 6 follow-up results of a randomized trial. Pediatrics. 2004 Dec;114(6):1550–9. doi: 10.1542/peds.2004-0962. PMID: 15574614. Exclusion Code: X5.15574614
169 Olds DL, Kitzman H, Hanks C, . Effects of nurse home visiting on maternal and child functioning: age-9 follow-up of a randomized trial. Pediatrics. 2007 Oct;120(4):e832–45. doi: 10.1542/peds.2006-2111. PMID: 17908740. Exclusion Code: X2.17908740
170 Olds DL, Robinson J, O’Brien R, . Home visiting by paraprofessionals and by nurses: a randomized, controlled trial. Pediatrics. 2002;110(3):486–96. Exclusion Code: X5.12205249
171 Olds DL, Robinson J, Pettitt L, . Effects of home visits by paraprofessionals and by nurses: age 4 follow-up results of a randomized trial. Pediatrics. 2004;114(6):1560–8. Exclusion Code: X5.15574615
172 Oveisi S, Ardabili HE, Dadds MR, . Primary prevention of parent-child conflict and abuse in Iranian mothers: a randomized-controlled trial. Child Abuse Negl. 2010 Mar;34(3):206–13. doi: 10.1016/j.chiabu.2009.05.008. PMID: 20207004. Exclusion Code: X8.20207004
173 Overbeek MM, de Schipper JC, Lamers-Winkelman F, . The effectiveness of a trauma-focused psycho-educational secondary prevention program for children exposed to interparental violence: study protocol for a randomized controlled trial. Trials. 2012;13:12. doi: 10.1186/1745-6215-13-12. PMID: 22309641. Exclusion Code: X5.22309641
174 Overbeek MM, de Schipper JC, Lamers-Winkelman F, . Effectiveness of specific factors in community-based intervention for child-witnesses of interparental violence: a randomized trial. Child Abuse Negl. 2013 Dec;37(12):1202–14. doi: 10.1016/j.chiabu.2013.07.007. PMID: 23948313. Exclusion Code: X5.23948313
175 Palmer R, Nascimento LN, Fonagy P. The State of the Evidence Base for Psychodynamic Psychotherapy for Children and Adolescents. Child Adolesc Psychiatr Clin N Am. 2013;22(2):149–214. Exclusion Code: X5.23538010
176 Paradis HA, Sandler M, Manly JT, . Building healthy children: evidence-based home visitation integrated with pediatric medical homes. Pediatrics. 2013 Nov;132: Suppl 2:S174–9. doi: 10.1542/peds.2013-1021R. PMID: 24187121. Exclusion Code: X13.24187121
177 Pereira M, Negrao M, Soares I, . Decreasing harsh discipline in mothers at risk for maltreatment: a randomized control trial. Infant Ment Health J. 2014 Nov–Dec;35(6):604–13. doi: 10.1002/imhj.21464 [doi]. PMID: 25798509. Exclusion Code: X5.25798509
178 Poole MK, Seal DW, Taylor CA. A systematic review of universal campaigns targeting child physical abuse prevention. Health Educ Res. 2014 Jun;29(3):388–432. doi: 10.1093/her/cyu012. PMID: 24711483. Exclusion Code: X3.24711483
179 Prinz RJ. Concurrent treatment of substance abuse and child maltreatment University of South Carolina, College of Arts and Sciences, Department of Psychology. 2012. Exclusion Code: X11.
180 Prinz RJ, Sanders MR, Shapiro CJ, . Addendum to “Population-Based Prevention of Child Maltreatment: The U.S. Triple P System Population Trial”. Prev Sci. 2016 Apr;17(3):410–6. doi: 10.1007/s11121-016-0631-x. PMID: 26774533. Exclusion Code: X3.26780665
181 Prosman GJ, Lo Fo Wong SH, van der Wouden JC, . Effectiveness of home visiting in reducing partner violence for families experiencing abuse: a systematic review. Fam Pract. 2015 Jun;32(3):247–56. doi: 10.1093/fampra/cmu091. PMID: 25947931. Exclusion Code: X2.25947931
182 Putnam FW. Ten-year research update review: child sexual abuse. J Am Acad Child Adolesc Psychiatry. 2003 Mar;42(3):269–78. doi: 10.1097/00004583-200303000-00006. PMID: 12595779. Exclusion Code: X1.12595779
183 Randolph M, Gold C. Child sexual abuse prevention: Evaluation of a teacher training program. School Psych Rev. 1994;23(3):485–95. Exclusion Code: X6.
184 Rapee RM. Family factors in the development and management of anxiety disorders. Clin Child Fam Psychol Rev. 2012 Mar;15(1):69–80. doi: 10.1007/s10567-011-0106-3 [doi]. PMID: 22116624. Exclusion Code: X1.22116624
185 Reedtz C, Handegard BH, Morch WT. Promoting positive parenting practices in primary pare: outcomes and mechanisms of change in a randomized controlled risk reduction trial. Scand J Psychol. 2011 Apr;52(2):131–7. doi: 10.1111/j.1467-9450.2010.00854.x. PMID: 21121925. Exclusion Code: X5.21121925
186 Repetti RL, Taylor SE, Seeman TE. Risky families: family social environments and the mental and physical health of offspring. Psychol Bull. 2002 Mar;128(2):330–66. PMID: 11931522. Exclusion Code: X1.11931522
187 Retzlaff R, von Sydow K, Beher S, . The efficacy of systemic therapy for internalizing and other disorders of childhood and adolescence: a systematic review of 38 randomized trials. Fam Process. 2013 Dec;52(4):619–52. doi: 10.1111/famp.12041 [doi]. PMID: 24329407. Exclusion Code: X2.24329407
188 Roberts I, Kramer MS, Suissa S. Does home visiting prevent childhood injury? A systematic review of randomised controlled trials. BMJ. 1996;312(7022):29–33. Exclusion Code: X5.8555855
189 Robinson JL. Our new venture into Eco-Paediatrics. Evid Based Child Health. 2013 Mar 7;8(2):253–4. doi: 10.1002/ebch.1908 [doi]. PMID: 23877881. Exclusion Code: X1.23877881
190 Roggman LA, Cook GA. Attachment, aggression, and family risk in a low-income sample. Family Science. 2010;1(3–4):191–204. Exclusion Code: X5.
191 Saldana L. An Integrated Intervention to Address the Comorbid Needs of Families Referred to Child Welfare for Substance Use Disorders and Child Neglect: FAIR Pilot Outcomes. Child Welfare. 2015;94(5):167–86. PMID: 26827470. Exclusion Code: X2.26827470
192 Sanapo MS, Nakamura Y. Gender and physical punishment: The Filipino children’s experience. Child Abuse Review. 2011;20(1):39–56. Exclusion Code: X3.
193 Sanders MR, Baker S, Turner KM. A randomized controlled trial evaluating the efficacy of Triple P Online with parents of children with early-onset conduct problems. Behav Res Ther. 2012 Nov;50(11):675–84. doi: 10.1016/j.brat.2012.07.004. PMID: 22982082. Exclusion Code: X5.22982082
194 Sanders MR, Dittman CK, Farruggia SP, . A comparison of online versus workbook delivery of a self-help positive parenting program. J Prim Prev. 2014 Jun;35(3):125–33. doi: 10.1007/s10935-014-0339-2 [doi]. PMID: 24500106. Exclusion Code: X5.24500106
195 Sarno JA, Wurtele SK. Effects of a personal safety program on preschoolers’ knowledge, skills, and perceptions of child sexual abuse. Child Maltreatment. 1997;2(1):35–45. Exclusion Code: X6.
196 Scheeringa MS, Weems CF, Cohen JA, . Trauma-focused cognitive-behavioral therapy for posttraumatic stress disorder in three-through six year-old children: a randomized clinical trial. Journal of child psychology and psychiatry, and allied disciplines. 2011;52(8):853–60. Exclusion Code: X2.
197 Schilling RF, Schinke SP. Personal coping and social support for parents of handicapped children. Children and Youth Services Review. 1984;6(3):195–206. Exclusion Code: X4.
198 Schofield TJ, Lee RD, Merrick MT. Safe, stable, nurturing relationships as a moderator of intergenerational continuity of child maltreatment: a meta-analysis. J Adolesc Health. 2013 Oct;53:(4 Suppl):S32–8. doi: 10.1016/j.jadohealth.2013.05.004. PMID: 24059937. Exclusion Code: X3.24059937
199 Scholer SJ, Hudnut-Beumler J, Dietrich MS. The effect of physician-parent discussions and a brief intervention on caregivers’ plan to discipline: is it time for a new approach? Clin Pediatr (Phila). 2011 Aug;50(8):712–9. doi: 10.1177/0009922811400730. PMID: 21393318. Exclusion Code: X5.21393318
200 Scholer SJ, Hudnut-Beumler J, Dietrich MS. Why parents value a brief required primary care intervention that teaches discipline strategies. Clin Pediatr (Phila). 2012 Jun;51(6):538–45. doi: 10.1177/0009922812439241. PMID: 22496174. Exclusion Code: X5.22496174
201 Schuler ME, Nair P, Black MM, . Mother-infant interaction: effects of a home intervention and ongoing maternal drug use. J Clin Child Psychol. 2000;29(3):424–31. Exclusion Code: X5.10969426
202 Schwartz KA, Preer G, McKeag H, . Child maltreatment: a review of key literature in 2013. Curr Opin Pediatr. 2014 Jun;26(3):396–404. doi: 10.1097/MOP.0000000000000102 [doi]. PMID: 24786369. Exclusion Code: X1.24786369
203 Segal L, Sara Opie R, Dalziel K. Theory! The missing link in understanding the performance of neonate/infant home-visiting programs to prevent child maltreatment: a systematic review. Milbank Q. 2012 Mar;90(1):47–106. doi: 10.1111/j.1468-0009.2011.00655.x [doi]. PMID: 22428693. Exclusion Code: X2.22428693
204 Self-Brown S, Whitaker D, Berliner L, . Disseminating child maltreatment interventions: research on implementing evidence-based programs. Child Maltreat. 2012 Feb;17(1):5–10. doi: 10.1177/1077559511436211. PMID: 22353672. Exclusion Code: X1.22353672
205 Selph SS, Bougatsos C, Blazina I, . Behavioral interventions and counseling to prevent child abuse and neglect: a systematic review to update the US Preventive services task force recommendation. Ann Intern Med. 2013 Feb 5;158(3):179–90. doi: 10.7326/0003-4819-158-3-201302050-00590. PMID: 23338775. Exclusion Code: X10.23338775
206 Shapiro CJ, Prinz RJ, Sanders MR. Facilitators and barriers to implementation of an evidence-based parenting intervention to prevent child maltreatment: the Triple P-Positive Parenting Program. Child Maltreat. 2012 Feb;17(1):86–95. doi: 10.1177/1077559511424774. PMID: 22089827. Exclusion Code: X2.22089827
207 Shaw DS, Dishion TJ, Supplee L, . Randomized trial of a family-centered approach to the prevention of early conduct problems: 2-year effects of the family check-up in early childhood. J Consult Clin Psychol. 2006 Feb;74(1):1–9. doi: 10.1037/0022-006x.74.1.1. PMID: 16551138. Exclusion Code: X5.16551138
208 Shirk SR, Deprince AP, Crisostomo PS, . Cognitive behavioral therapy for depressed adolescents exposed to interpersonal trauma: an initial effectiveness trial. Psychotherapy (Chic). 2014 Mar;51(1):167–79. doi: 10.1037/a0034845. PMID: 24377410. Exclusion Code: X2.24377410
209 Simon Fraser University. BC Healthy Connections Project (BCHCP). In: ClinicalTrials.gov [Internet]. Bethesda, MD: National Library of Medicine. [cited 2012]. https://ClinicalTrials.gov/show/NCT01672060. NLM Identifier: NCT01672060. Exclusion Code: X11.
210 Sittig JS, Uiterwaal CS, Moons KG, . Value of systematic detection of physical child abuse at emergency rooms: a cross-sectional diagnostic accuracy study. BMJ Open. 2016 Mar 22;6(3):e010788. doi: 10.1136/bmjopen-2015-010788. PMID: 26978697. Exclusion Code: X3.26978697
211 Skeen S, Tomlinson M. A public health approach to preventing child abuse in low- and middle-income countries: a call for action. Int J Psychol. 2013;48(2):108–16. doi: 10.1080/00207594.2012.737467 [doi]. PMID: 23597010. Exclusion Code: X8.23597010
212 Spieker SJ, Oxford ML, Kelly JF, . Promoting First Relationships: Randomized Trial of a Relationship-Based Intervention for Toddlers in Child Welfare. Child Maltreatment. 2012;17(4):271–86. Exclusion Code: X2.22949743
213 Spilsbury J. Neighborhood factors and child maltreatment: a mixed-method study Case Western Reserve University, School of Medicine, Center for Clinical Investigation. 2013. Exclusion Code: X11.
214 St. Pierre RG, Layzer JI. Using home visits for multiple purposes: the Comprehensive Child Development Program. The Future of children. 1999:134–51. Exclusion Code: X5.10414014
215 Stanger C, Ryan SR, Fu H, . Parent training plus contingency management for substance abusing families: A Complier Average Causal Effects (CACE) analysis. Drug Alcohol Depend. 2011;118(2–3):119–26. Exclusion Code: X2.21466925
216 Stark L, Landis D. Violence against children in humanitarian settings: A literature review of population-based approaches. Soc Sci Med. 2016;152((Stark L., ls2302@cumc.columbia.edu; Landis D.) Program on Forced Migration and Health, Mailman School of Public Health, Columbia University, United States):125–37. Exclusion Code: X3.26854623
217 Stevens-Simon C, Barrett J. A comparison of the psychological resources of adolescents at low and high risk of mistreating their children. J Pediatr Health Care. 2001 Nov–Dec;15(6):299–303. doi: 10.1067/mph.2001.114385. PMID: 11717686. Exclusion Code: X3.11717686
218 Stoll B, Anderson JK. Prevention of abusive head trauma: a literature review. Pediatr Nurs. 2013 Nov–Dec;39(6):300–8. PMID: 24640317. Exclusion Code: X5.24640317
219 Subramanian S, Katz KS, Rodan M, . An integrated randomized intervention to reduce behavioral and psychosocial risks: pregnancy and neonatal outcomes. Matern Child Health J. 2012 Apr;16(3):545–54. doi: 10.1007/s10995-011-0875-9 [doi]. PMID: 21931956. Exclusion Code: X5.21931956
220 Suchman NE, Decoste C, Rosenberger P, . Attachment-based intervention for substance-using mothers: A preliminary test of the proposed mechanisms of change. Infant Mental Health Journal. 2012;33(4):360–71. Exclusion Code: X5.23024442
221 Swenson CC, Schaeffer CM, Henggeler SW, . Multisystemic Therapy for Child Abuse and Neglect: a randomized effectiveness trial. J Fam Psychol. 2010 Aug;24(4):497–507. doi: 10.1037/a0020324. PMID: 20731496. Exclusion Code: X2.20731496
222 Tarren-Sweeney M. Setting the bar higher: what information do we need to establish the effectiveness of mental health interventions for children with complex attachment- and trauma-related difficulties? Clin Child Psychol Psychiatry. 2013 Jan;18(1):3–6. doi: 10.1177/1359104512467406. PMID: 23324850. Exclusion Code: X1.23324850
223 Taussig HN, Culhane SE, Garrido E, . RCT of a mentoring and skills group program: Placement and permanency outcomes for foster youth. Pediatrics. 2012;130(1):e33–e9. Exclusion Code: X2.22689870
224 Taylor JE, Harvey ST. A meta-analysis of the effects of psychotherapy with adults sexually abused in childhood. Clin Psychol Rev. 2010 Aug;30(6):749–67. doi: 10.1016/j.cpr.2010.05.008. PMID: 20579790. Exclusion Code: X2.20579790
225 Telljohann SK, Everett SA, Price JH. Evaluation of a third grade sexual abuse curriculum. J Sch Health. 1997;67(4):149–53. Exclusion Code: X6.9130194
226 The Multisite Violence Prevention P. Implementation and process effects on prevention outcomes for middle school students. J Clin Child Adolesc Psychol. 2014;43(3):473–85. doi: 10.1080/15374416.2013.814540 [doi]. PMID: 23845010. Exclusion Code: X5.23845010
227 Thomas R, Zimmer-Gembeck MJ. Accumulating evidence for parent-child interaction therapy in the prevention of child maltreatment. Child Dev. 2011 Jan–Feb;82(1):177–92. doi: 10.1111/j.1467-8624.2010.01548.x [doi]. PMID: 21291436. Exclusion Code: X2.21291436
228 Thomas R, Zimmer-Gembeck MJ. Parent-child interaction therapy: an evidence-based treatment for child maltreatment. Child Maltreat. 2012 Aug;17(3):253–66. doi: 10.1177/1077559512459555. PMID: 22942167. Exclusion Code: X2.22942167
229 Tooten A, Hoffenkamp HN, Hall RA, . The effectiveness of video interaction guidance in parents of premature infants: a multicenter randomised controlled trial. BMC Pediatr. 2012;12:76. doi: 10.1186/1471-2431-12-76. PMID: 22709245. Exclusion Code: X5.22709245
230 Toth SL, Sturge-Apple ML, Rogosch FA, . Mechanisms of change: Testing how preventative interventions impact psychological and physiological stress functioning in mothers in neglectful families. Dev Psychopathol. 2015 Nov;27(4 Pt 2):1661–74. doi: 10.1017/S0954579415001017. PMID: 26535951. Exclusion Code: X5.26535951
231 Tutty LM. The ability of elementary school children to learn child sexual abuse prevention concepts. Child Abuse Negl. 1992;16(3):369–84. Exclusion Code: X6.1617471
232 Tutty LM. Child sexual abuse prevention programs: evaluating Who Do You Tell. Child Abuse Negl. 1997;21(9):869–81. Exclusion Code: X6.9298264
233 University of Delaware. Intervening Early With Neglected Children. In: ClinicalTrials.gov [Internet]. Bethesda, MD: National Library of Medicine. [cited 2014]. https://ClinicalTrials.gov/show/NCT02093052. NLM Identifier: NCT02093052. Exclusion Code: X2.
234 University of Konstanz. Prevention of Violence Against Children. In: ClinicalTrials.gov [Internet]. Bethesda, MD: National Library of Medicine. [cited 2017]. https://ClinicalTrials.gov/show/NCT03051854. NLM Identifier: NCT03051854. Exclusion Code: X8.
235 University of Oregon. Coaching Alternative Parenting Strategies (CAPS) Study. In: ClinicalTrials.gov [Internet]. Bethesda, MD: National Library of Medicine. [cited 2016]. https://ClinicalTrials.gov/show/NCT02684903. NLM Identifier: NCT02684903. Exclusion Code: X2.
236 University of Toronto. Cluster RCT of Embedded Parenting Intervention to Prevent Recurrence and Reduce Impairment in Young Children Exposed to Domestic Violence. In: ClinicalTrials.gov [Internet]. Bethesda, MD: National Library of Medicine. [cited 2017]. https://ClinicalTrials.gov/show/NCT03198429. NLM Identifier: NCT03198429. Exclusion Code: X5.
237 University of Utah. Collaborative Care for Infants at Risk. In: ClinicalTrials.gov [Internet]. Bethesda, MD: National Library of Medicine. [cited 2017]. https://ClinicalTrials.gov/show/NCT03199326. NLM Identifier: NCT03199326. Exclusion Code: X2.
238 van der Oord S, Prins PJ, Oosterlaan J, . The adolescent outcome of children with attention deficit hyperactivity disorder treated with methylphenidate or methylphenidate combined with multimodal behaviour therapy: results of a naturalistic follow-up study. Clin Psychol Psychother. 2012;19(3):270–8. Exclusion Code: X5.21404369
239 van Rosmalen-Nooijens K, Lo Fo Wong S, Prins J, . Young People, Adult Worries: Randomized Controlled Trial and Feasibility Study of the Internet-Based Self-Support Method “Feel the ViBe” for Adolescents and Young Adults Exposed to Family Violence. J Med Internet Res. 2017 Jun 12;19(6):e204. doi: 10.2196/jmir.6004. PMID: 28606501. Exclusion Code: X2.28606893
240 van Rosmalen-Nooijens KA, Prins JB, Vergeer M, . "Young people, adult worries": RCT of an internet-based self-support method “Feel the ViBe” for children, adolescents and young adults exposed to family violence, a study protocol. BMC Public Health. 2013;13:226. doi: 10.1186/1471-2458-13-226. PMID: 23497359. Exclusion Code: X5.23497359
241 Velasquez J, Christensen ML, Schommer BL. Part II: Intensive Services Help Prevent Child Abuse. MCN: The American Journal of Maternal/Child Nursing. 1984;9(2):113–7. Exclusion Code: X7.
242 Wagner MM, Clayton SL. The Parents as Teachers program: Results from two demonstrations. The Future of Children. 1999:91–115. Exclusion Code: X13.10414012
243 Walsh K, Zwi K, Woolfenden S, . School-based education programmes for the prevention of child sexual abuse. Cochrane Database Syst Rev. 2015(4):CD004380. doi: 10.1002/14651858.CD004380.pub3 [doi]. PMID: 25876919. Exclusion Code: X3.25876919
244 Whitaker DJ. Comparative effectiveness trial to reduce child maltreatment, improve client outcomes, and examine client burden Georgia State University, School of Public Health, Center for Healthy Development. 2015. Exclusion Code: X11.
245 Winokur M, Ellis R, Drury I, . Answering the big questions about differential response in Colorado: safety and cost outcomes from a randomized controlled trial. Child Abuse Negl. 2015 Jan;39:98–108. doi: 10.1016/j.chiabu.2014.06.005. PMID: 24997071. Exclusion Code: X2.24997071
246 Winters KC, Fahnhorst T, Botzet A, . Brief intervention for drug-abusing adolescents in a school setting: Outcomes and mediating factors. J Subst Abuse Treat. 2012;42(3):279–88. Exclusion Code: X5.22000326
247 Wurtele SK, Owens JS. Teaching personal safety skills to young children: An investigation of age and gender across five studies. Child Abuse Negl. 1997 1997/08/01;21(8):805–14. doi: 10.1016/S0145-2134(97)00040-9. Exclusion Code: X6.9280384