# Appendix B Detailed Methods

## Appendix B1 Relationship of Current Included Studies to Previous AHRQ Evidence Reviews

Included in Nelson et al, 2013 and/or Nelson et al, 2004 | | Included in Viswanathan et al, 2018
Records excluded in Viswanathan et al, 2018, with reason | Records included in Viswanathan et al, 2018 (11 RCTs in 16 publications) | New studies identified from electronic search (1 RCT in 1 publication) | New studies identified from hand search (2 RCTs in 2 publications) | Old studies identified from our hand search not captured in prior review (7 RCTs in 9 publications)
Ineligible or no population: Olds et al, 1995^153^ Olds et al, 2007^154^ Taylor et al, 2010^155^ Ineligible or no intervention: Anderson, 1993^141^ Cerny and Inouye, 2001^138^ Korfmacher, 2000^144^ Stevens-Simon and Barrett, 2001^156^ Ineligible or no outcome: Armstrong et al, 1999^151^ Black et al, 1994^157^ Bugental et al, 2002^158^ Duggan et al, 2000^159^ El-Mohandes et al, 2003^160^ Fraser et al, 2000^161^ El-Mohandes et al, 2010^162^ Kiely et al, 2010^163^ Olds et al, 2004^164^ Ineligible study design: Dawson et al, 1989^165^ Flynn, 1999^166^ Leventhal et al, 1996^167^ McGuigan et al, 2000^168^ Irretrievable: Katsev et al, 1999^169^ CCAPR, 1996^170^ Poor quality: Barth, 1991^134^ Dubowitz et al, 2009^148^ Duggan et al, 1999^145^ Duggan et al, 2004^146^ Gray et al, 1979^135^ Koniak-Griffin et al, 2003^171^ | Lowell et al, 2011^117^ Barlow et al, 2007^104^ Fergusson et al, 2005^108^ Brayden et al, 1993^112^ Brooten et al, 1986^113^ Bugental and Schwartz, 2009^106^ Duggan et al, 2007^91^ DuMont et al, 2008^93^ Marcenko and Spence, 1994^118^ Kitzman et al, 1997^96^ Olds et al, 2007^97^ Olds et al, 1986^98^ Olds et al, 1994^99^ Olds et al, 1997^100^ Eckenrode et al, 2000^101^ Siegel et al, 1980^89^ | Easterbrooks et al, 2013^107^ | Sadler et al, 2013^95^ Robling et al, 2016^90^ | Lam et al, 2009^103^ Silovsky et al, 2011^111^ Guyer et al, 2003^115^ Minkovitz et al, 2007^116^ Finello et al, 1998^114^ Wiggins et al, 2005^121^ Wiggins et al, 2004^120^ Larson, 1980^110^ Quinlivan et al, 2003^119^

Abbreviations: AHRQ=Agency for Healthcare Research and Quality; CCAPR=Center on Child Abuse Prevention Research; RCT=randomized, controlled trial.

## Appendix B2 Search Strategies

KQ 1 and KQ 2 PubMed (January 1, 2011 through August 2, 2016)

| Terms | Results
#4 | Search (“Child Abuse”[Mesh]) OR “Shaken Baby Syndrome”[Mesh] | 26291
#6 | Search “Child, Abandoned”[Mesh] OR “emotional abuse”[tw] | 1762
#8 | Search “Domestic Violence”[Mesh] | 38014
#9 | Search “Domestic Violence”[Mesh] Filters: Child: birth-18 years | 28626
#11 | Search (#4 OR#6 OR#9) | 30620
#12 | Search (((“Single-Blind Method”[Mesh]) OR “Double-Blind Method”[Mesh]) OR “Random Allocation”[Mesh]) OR (“Randomized Controlled Trials as Topic”[Mesh] OR “Randomized Controlled Trial” [Publication Type]) | 610171
#14 | Search (#11 AND#12) | 605
#17 | Search (“Cohort Studies”[Mesh]) OR “Prospective Studies”[Mesh] OR (prospective AND cohort) | 1559045
#18 | Search (#11 AND#17) | 3746
#19 | Search (#4 OR#6 OR#9) Filters: Systematic Reviews | 638
#20 | Search (#19 OR#18 OR#14) Filters: Systematic Reviews | 638
#21 | Search (#19 OR#18 OR#14) | 4771
#22 | Search (#19 OR#18 OR#14) Filters: Child: birth-18 years | 4697
#23 | Search (#19 OR#18 OR#14) Filters: Humans; Child: birth-18 years | 4695
#24 | Search (#19 OR#18 OR#14) Filters: Humans; English; Child: birth-18 years | 4476
#25 | Search (#19 OR#18 OR#14) Filters: Publication date from 2011/01/01; Humans; English; Child: birth-18 years | 1447

PubMed=1447

Cochrane

Child AND (abuse OR neglect OR maltreatment)=9=0 New

EMBASE

Child AND (abuse OR neglect OR maltreatment)=305=197 New

ClinicalTrials.gov

Child AND (abuse OR neglect OR maltreatment)=25

HSRProj

Child AND (abuse OR neglect OR maltreatment)=9

Cochrane Clinical Trials Registry

Child AND (abuse OR neglect OR maltreatment)=37=8 New

WHO ICTRP

Child AND (abuse OR neglect OR maltreatment)=8=0 New

Total Database=1661

Both Databases KQ 1 and KQ 2=1661

KQ 1 and KQ 2 PubMed (August 3, 2016 through December 18, 2017)

| Terms | Results
#1 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Child Abuse”[Mesh]) OR “Shaken Baby Syndrome”[Mesh] | 27580
#2 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Child, Abandoned”[Mesh] OR “emotional abuse”[tw] | 2022
#3 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Domestic Violence”[Mesh] | 39977
#4 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Domestic Violence”[Mesh] Filters: Child: birth-18 years | 30107
#5 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 OR #2 OR #4) | 32294
#6 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((“Single-Blind Method”[Mesh]) OR “Double-Blind Method”[Mesh]) OR “Random Allocation”[Mesh]) OR (“Randomized Controlled Trials as Topic”[Mesh] OR “Randomized Controlled Trial” [Publication Type]) | 659186
#7 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #6) | 660
#8 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Cohort Studies”[Mesh]) OR “Prospective Studies”[Mesh] OR (prospective AND cohort) | 1715795
#9 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #8) | 4044
#10 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 OR #2 OR #4) Filters: Systematic Reviews | 733
#11 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 OR #9 OR #10) | 5204
#12 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 OR #9 OR #10) Filters: Child: birth-18 years | 5102
#13 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 OR #9 OR #10) Filters: Humans; Child: birth-18 years | 5100
#14 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 OR #9 OR #10) Filters: Humans; English; Child: birth-18 years | 4867
#15 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 OR #9 OR #10) Filters: Publication date from 2016/01/01; Humans; English; Child: birth-18 years | 325

PubMed=325=306 New

Cochrane

Child AND (abuse OR neglect OR maltreatment)=4=3 New

EMBASE

Child AND (abuse OR neglect OR maltreatment)=76=24 New

ClinicalTrials.gov

Child AND (abuse OR neglect OR maltreatment)=32 =27 New

HSRProj

Child AND (abuse OR neglect OR maltreatment)=1

Cochrane Clinical Trials Registry

Child AND (abuse OR neglect OR maltreatment)=29=18 New

WHO ICTRP

Child AND (abuse OR neglect OR maltreatment)=2=2 New

Total Database=381 New

## Appendix B3 Eligibility Criteria for Study Selection

Include or Exclude Question | Exclusion Code | Reason for Exclusion | Inclusion Criteria | Exclusion Criteria
1. Does the article represent original research? | X1 | Ineligible publication type | Original research and systematic reviews | Editorials, commentaries, or narrative reviews
2. Does the study report on the population of interest? | X2 | Ineligible or no population | Children and adolescents (birth through age 18 years) with no known exposure to maltreatment and no signs or symptoms of current or past maltreatment (but may have known risk factors that lead to inclusion in trials) | Symptomatic children and adolescents undergoing diagnostic evaluation for conditions related to abuse or neglect (e.g., those presenting with a broken bone or other signs of physical abuse or neglect, trauma symptoms associated with domestic violence exposure), asymptomatic children with known exposure to child maltreatment, perpetrators of maltreatment, and children who have maltreatment perpetrated against them by a caregiver
3. Does the study include an intervention of interest? | X3 | Ineligible or no intervention | Services that could result from a referral by a primary care provider; services may be implemented by a nonclinician and may include home visiting programs, primary care–based programs, respite care, parent education programs, and family support and family strengthening programs Family-focused interventions may be directed at the caregiver and may or may not include components directed at the child | Community-wide interventions only, such as public awareness campaigns or public service announcements, without specific interventions linked to clinical settings
4. Does the study use a comparator of interest? | X4 | Ineligible or no comparison | Usual care, delayed intervention, or active interventions that allow for assessment of the independent contribution of the primary care–feasible or referable preventive intervention (e.g., clinical interventions plus media campaigns vs. media campaigns) | Comparators that do not allow for assessment of the independent contribution of the primary-care–feasible or referable preventive intervention (e.g., clinical interventions plus media campaigns vs. usual care)
5. Does the study report on outcomes of interest? | X5 | Ineligible or no outcome | KQ 1:[underlined: Direct or proxy measures of abuse or neglect (required]): Physical, sexual, or emotional abuse perpetrated by a parent or caregiver against a child^*^ Physical (e.g., failure to thrive), emotional, dental/medical (e.g., lack of immunizations or well-child visits), or educational neglect Reports to child protective services Removal of the child from the home Injuries such as broken bones, bruises, burns, and other injuries with a high specificity for abuse Visits to the emergency department Hospitalizations [underlined: Behavioral, emotional, mental, or physical well-being]: Decreased internalizing behaviors (depression, anxiety) Decreased externalizing behaviors (disruptive, aggressive, or delinquent behavior) Healthy social-emotional development (e.g., attachment problems, peer relationships); reduced developmental delays (language, cognitive) Decreased incidence of reactive attachment disorder, disinhibited social engagement disorder, acute stress disorder, or posttraumatic stress disorder Decreased incidence of traumatic stress symptoms, such as impairments in attachment, self-regulation, under- or overcontrolling behaviors (e.g., irritable/angry outbursts, self-destructive behavior, food hoarding), executive functioning, and self-concept; hypervigilance; exaggerated startle response; dissociation; concentration problems; somatic problems (e.g., headaches, gastrointestinal problems); sleep disturbances; and nightmares Decreased suicidality and self-injurious behaviors Improved school attendance and performance Reduced risky behaviors and outcomes (e.g., sexually transmitted diseases) Mortality KQ 2: Any harms that result as an effect of the intervention (e.g., stigma, labeling, legal risks, risk of further harm to the child, dissolution of the family); worsening of outcomes listed for KQ 1 | KQ 1: Outcomes not otherwise specified; studies without direct or proxy measures of abuse or neglect KQ 2: None *Note: Studies reporting behavioral, emotional, mental, or physical well-being outcomes included on the left for KQ 1 that do not also report at least one child maltreatment outcomes will be excluded.
6. Is the study conducted in a clinical setting of interest? | X4 | Ineligible or nonclinical setting | Primary-care feasible or referable: pediatric, primary care, family medicine, school-based clinic, or other settings where primary care services are offered; services that could result from an assessment by a clinician (including delivery hospitals, in-home settings, and nonspecialist settings) | Not a primary-care feasible or referable setting; populations or services/interventions that are not applicable to U.S. practice
7. Does the study use a study design of interest? | X7 | Ineligible study design | KQ 1: Randomized, controlled trials; systematic reviews KQ 2: Randomized, controlled trials, controlled clinical trials, systematic reviews, cohort trials with a control group; and case-control studies | KQ 1: Nonrandomized cohort trials, case-control studies, case series, or case studies KQ 2: Case series or case studies
8. Does the study include countries with an HDI similar to the United States? | X8 | Ineligible country or region | Research conducted in the United States or in populations similar to U.S. populations, with services and interventions applicable to U.S. practice (i.e., conducted in countries categorized as “very high” on the Human Development Index [as defined by the United Nations Development Programme]) | Research not relevant to the United States (i.e., conducted in countries not categorized as “very high” on the Human Development Index)
9. Is article published in English? | X9 | Not published in English | Studies published in English | Studies published in any language other than English

Note: Four additional exclusion codes not specified in the work plan were later applied to studies for systematic reviews that were used in hand search, ongoing studies with no publication, publications that were irretrievable, and studies that were rated poor in quality.

* Self-reported measures of child abuse or neglect are not included in the report as eligible outcomes. They are summarized in a contextual question.

Abbreviations: HDI=Human Development Index; KQ=key question; U.S.=United States.

## Appendix B4 Eligibility Criteria for Study Selection

### RCTs and Cohort Studies

- Initial assembly of comparable groups:
  ○ For RCTs: Adequate randomization, including first concealment and whether potential confounders were distributed equally among groups
  ○ For cohort studies: Consideration of potential confounders, with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, cross-overs, adherence, contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: Equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- All important outcomes considered
- Analysis: Adjustment for potential confounders for cohort studies or intention-to-treat analysis for RCTs

### Definition of ratings based on above criteria

Good: Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to all groups; interventions are spelled out clearly; all important outcomes are considered; and appropriate attention is given to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.

Fair: Studies are graded “fair” if any or all of the following problems occur, without the fatal flaws noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains whether some (although not major) differences occurred with followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is used for RCTs.

Poor: Studies are graded “poor” if any of the following fatal flaws exists: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

Source: [underlined: U.S. Preventive Services Task Force Procedure Manual.] Appendix VI. Criteria for Assessing Internal Validity of Individual Studies. Available at: https://www.uspreventiveservicestaskforce.org/Page/Name/methods-and-processes

## Appendix B5 Risk of Bias Assessment Form