# Appendix A Supplementary Background Materials

## Appendix A1 Types of Abuse and Neglect

The Child Welfare Information Gateway, a service of the Children’s Bureau of the U.S. Department of Health and Human Services, Administration for Children and Families, provides a summary of State civil definitions of child abuse and neglect that determine the grounds for intervention by State child protective agencies.^129^ These definitions address the following types of maltreatment:

### Physical Abuse

Physical abuse includes any nonaccidental physical injury to the child and can include striking, kicking, burning, or biting the child or any action that results in physical harm of the child. As of April 2016, in 38 States, the definition includes acts or circumstances that threaten the child with harm or create a substantial risk of harm to the child’s health or welfare.^129^ Seven States include in their definitions of physical abuse the crime of human trafficking, including labor trafficking, involuntary servitude, and trafficking of minors.^129^ Physical abuse does not include physical discipline, as long as it does not cause bodily injury to the child.^130^

### Neglect

Neglect is the failure of a parent or other person with responsibility for the child to provide needed food, clothing, shelter, medical care, or supervision to the degree that the child’s health, safety, and well-being are threatened with harm. Half the States include failure to educate the child as required by law in their definition of neglect. Ten States specifically define medical neglect as failing to provide any special medical treatment or mental health care needed by the child, and four define it as withholding medical treatment or nutrition from disabled infants with life-threatening conditions.^129^

### Sexual Abuse or Exploitation

The Federal CAPTA specifies a definition of sexual abuse as:

“The employment, use, persuasion, inducement, enticement, or coercion of any child to engage in, or assist any other person to engage in, any sexually explicit conduct or simulation of such conduct for the purpose of producing a visual depiction of such conduct; or

“The rape, and in cases of caretaker or interfamilial relationships, statutory rape, molestation, prostitution, or other form of sexual exploitation of children, or incest with children.”^5,^ ^p. 2^

CAPTA offers a relatively specific definition as guidance to the States; however, some States provide further specification of sexual abuse in their statutes. Most States include sexual exploitation in their definition, which includes allowing the child to engage in prostitution or in the production of child pornography.^129^ Twenty-one States specify human trafficking, including sex trafficking or trafficking of children for sexual purposes, in their definition of sexual abuse.^129^

### Emotional Abuse

Nearly all States include emotional maltreatment in their definitions of abuse and neglect. Emotional abuse can include inattention to child’s emotional needs, failure to provide psychological care, or permitting the child to use alcohol or drugs.^129^ Emotional injury is often defined as “injury to the psychological capacity or emotional stability of the child as evidenced by an observable or substantial change in behavior, emotional response, or cognition” and injury as evidenced by “anxiety, depression, withdrawal, or aggressive behavior.”^129^

### Parental Substance Abuse

Many States include parental substance abuse as an element of their definitions of child abuse and neglect.^129^ Exposures considered to be maltreatment include prenatal exposure of a child to harm because of the mother’s use of an illegal drug or other substance; manufacture of a controlled substance in the presence of a child or on the premises occupied by a child; allowing a child to be present where the chemicals or equipment for the manufacture of controlled substances are used or stored; selling, distributing, or giving drugs or alcohol to a child; and use of a controlled substance by a caregiver that impairs the caregiver’s ability to adequately care for the child.

### Abandonment

Seventeen States include abandonment in their definitions of abuse and neglect as a type of neglect.^129^ Nineteen define it as separate from neglect.^129^ Abandonment of the child occurs when the parent’s identity or whereabouts are unknown, the child has been left by the parent in circumstances in which the child suffers serious harm, or the parent has failed to maintain contact with the child or to provide reasonable support for a specified period of time.

### Domestic Violence

Some States include exposure to domestic violence (DV) as a form of abuse or neglect in their legislation.^130^ Domestic violence and child maltreatment, particularly physical and emotional abuse, are known to have high rates of co-occurrence.^131^ Additionally, CAPTA promotes the use of differential response for child exposure to domestic violence (e.g., offering timely services without a formal determination or substantiation of child abuse or neglect) to avoid separating the child from the nonperpetrating parent (usually the mother). The 2010 reauthorization of CAPTA calls attention to the need for a more comprehensive and collaborative approach across CPS and domestic violence services that addresses the safety of both child and adult victims.

## Appendix A2 Current Recommendations From Various Professional Organizations on Prevention of Child Maltreatment

Organization, Year | Recommendation
American Academy of Family Physicians 2013^69^ | Screening/Intervention Notes that there is insufficient evidence that any specific screening strategy or behavioral intervention produces better health outcomes than clinician awareness and evaluation of potential signs of abuse. Nonetheless provides a list of steps primary care physicians can take to prevent child abuse, which includes screening for risk factors or problems, with a link to the American Academy of Pediatrics’ recommendations.
American Academy of Pediatrics 2010,^71^ 2015^72^ | Screening/Intervention No statement on screening or intervention Universal prevention 2014 (published in October 2010, reaffirmed in January 2014) Strongly recommends physician involvement in preventing child maltreatment.^71^ Notes that universal prevention of child maltreatment must begin with an approach that assesses the caregivers’ strengths and deficits and connects the family with community resources that will protect the dependent children before abuse or neglect occurs. 2015 (published in April 2015)^72^ Focuses on management of suspected physical abuse. Notes that “Child abuse prevention is important but difficult and requires efforts that are broad and sustained. The pediatrician, as a trusted advisor to parents, caregivers, and families about health, development, and discipline, can play an important role in abuse prevention by assessing caregivers’ strengths and deficits, providing education to enhance parenting skills, connecting families with supportive community resources that address parent and family needs, and promoting evidence-based parenting practices that are nurturing and positive.” This statement cites the 2010 clinical statement.
Canadian Task Force on Preventive Health Care 2000^68^ | Screening Unacceptable rate of predictive value (e.g., positive predictive value of 6.6% and a sensitivity of 55.6% for physical abuse in one study). D recommendation for screening: “because of the high false-positive rates of screening tests for child maltreatment and the potential for mislabeling people as potential child abusers, the possible harms associated with these screening maneuvers outweigh the benefits.” Interventions Good evidence to include referral in the periodic health examination for home visitation by nurses (A). Insufficient evidence to include referral in the periodic health examination for prevention of child maltreatment (C) for comprehensive health care; parent education and support; or home-based services, including case management, education, and psychotherapy. No additional evidence to alter recommendation (C) in 1993 update for programs for children aimed at preventing sexual abuse and abduction.
Community Preventive Services Task Force^70^ | Screening None Interventions Noted strong evidence of effectiveness for early childhood home visitation to prevent violence against the child (maltreatment): recommended. Also noted that “programs delivered by professional visitors (i.e., nurses or mental health workers) seem more effective than programs delivered by paraprofessionals, although programs delivered by paraprofessionals for 2 years also appear to be effective in reducing child maltreatment.”

## Appendix A3 Contextual Question 1: What Is the Validity and Reliability of Risk-Assessment Tools to Identify Children and Adolescents at Risk of Child Maltreatment?

Among the 21 good or fair quality trials and the 13 poor quality trials evaluating the effectiveness of interventions to prevent child maltreatment, six used screening instruments to identify children and adolescents at risk of maltreatment for inclusion in prevention trials. The six studies used one of five screening instruments: Kempe Family Stress Checklist (KFSI), the Maternal History Interview (MHI-2), the Parent Screening Questionnaire (PSQ) within the SEEK Model, the Brief Infant-Toddler Social and Emotional Assessment (BITSEA), and the Parent Risk Questionnaire (PRQ). Appendix A3 Table 1 presents information on reliability and validity of these instruments. We found reports of screening test accuracy^132,^ ^133^ for two of five instruments. The results from one screening test accuracy study indicate high sensitivity and specificity (80% and 89.4% respectively) for KFSI but the method of validation has serious flaws because it appears to exclude participants with intermediate risk.^132^ A second study reported relatively lower rates of sensitivity and specificity (65% and 81.3% respectively) for MHI-2 but a very low positive predictive value (5.5%) and high false positive and false negative rates.^133^

Three additional included studies used screening instruments adapted from the KFSI and examined specific areas of parent and family functioning including age of parents, social support, planning of pregnancy, parental substance use, family financial situation, maternal use of needed services, maternal intelligence or health, difficulty of child-caring, maternal exposure to abuse, and other history of family violence as well as criminal or mentally ill behavior. We did not find studies evaluating the reliability or validity of these adapted instruments.^108,^ ^109,^ ^134–136^

Among the 1,850 records excluded from this review, six studies used one of four additional screening instruments to identify children at risk of maltreatment. These include the BabyFirst Screen, , the Brisbane Evaluation of Needs Questionnaire, and the Child Abuse Potential Inventory (CAPI). Appendix A3 Table 2 presents information on reliability and validity of these instruments. The BabyFirst Screen was the only instrument for which we found statistics on validity, specifically out-of-home placements. Similar to the MHI-2 instrument, the positive predictive value is low, and the false positive and negative rates are relatively high. Authors of studies evaluating the Child Abuse Potential Inventory (CAPI) instrument did not report measures such as sensitivity and specificity.^137,^ ^138^ We did not find validations of other instruments in a population with a wide spectrum of risk. The California Family Risk Assessment was evaluated for predictive validity of new reports in a sample of already identified cases.^139^ The Clinical Prediction Tool evaluated the risk of referral to child protection referrals among children with scalds or burns.^140^ One study of an instrument, the Parenting Profile Assessment, did not measure validity against an external measure. The authors reported sensitivity and specificity against a combination of parental self-report of abuse and agency reports.^141^ In general, the instruments described above have poor accuracy. Instruments to predict physical child abuse in emergency room settings may not have relevance to the primary care context and have a high false-positive rate.^142,^ ^143^

Appendix A3 Table 1 Reliability and Validity of Risk Screening Instruments Used in Included Studies

Instrument | Study using the Instrument | Description | Reliability | Validity^*^
Kempe Family Stress Checklist (KFSI)^132,^ ^144^ | Caldera et al, 2007,^92^ Duggan et al, 2007,^91^ DuMont et al, 2008,^93^ DuMont et al, 2010,^94^ Duggan et al, 1999^145^ Duggan et al, 2004^146^ | - 10-item rating scale; - Items include psychiatric and criminal history, childhood history of care, emotional functioning, attitudes towards and perception of children, discipline of children, and level of stress in parent’s life; - Original checklist developed to evaluate parents with known abuse or neglect | - High reliability reported in HFA sites in Oregon for classifying parents on individual characteristics in terms of levels of risk (r=0.93) but does not provide answer to whether families would receive the same score by independent evaluations.^144^ | - Validated in a sample, in 197 women 2 to 2.5 years after baseline measure.^132^; - Validated against identified abuse, neglect, or failure to thrive (from chart review, specifics not defined); - Validation of 38 with positive scores (possibly scores>=40, not clearly specified) and 157 without positive scores (threshold not specified; possibly includes 100 women with scores 0-10 and 25-35); - 80% sensitivity and 89.4% specificity, sample appears to exclude intermediate risk category; - Reported 52.5% positive predictive value, 96.8% negative predictive value.^132^
Maternal History Interview (MHI-2)^112,^ ^133^ | Brayden et al, 1993^112^ | - Series of open-ended questions that are designed to predict abuse, neglect, or nonorganic failure to thrive; - Participant answers are scored by best fit into predetermined categories; - Subscale scores are developed for knowledge of parenting skills and philosophy about discipline, personality (extroversion, aggressiveness, dependency, and self-image), positive and negative feelings about the pregnancy, the mother’s perception of her nurture as a child, a truncated version of the Life Stress Inventory for both mother and father, and a “lie” scale (to detect attempts to respond only with socially appropriate answers). | - 90% or greater interobserver agreement among four trained interviewers.^112^ | - Validation study on 1400 expectant mothers screened^133^; - Target children and siblings followed through 36 months for reports of abuse (excluding “unsubstantiated reports, grudge or crank reports, and those without evidence of trauma.” Siblings were included only if their first abuse report occurred after the interview; - Based on reported data,^†^ calculated sensitivity: 65%; calculated specificity: 81.3%, positive predictive value: 5.5%, calculated negative predictive value: 99.3%; calculated false positive rate: 34.8%, calculated false negative rate: 18.7%
Parent Screening Questionnaire (PSQ)^147,^ ^148^ | Dubowitz et al, 2009,^148^ Dubowitz et al, 2012^147^ | - 20-item self-report questionnaire; - Screens for risk factors for maltreatment: parental depression, substance abuse, major stress, intimate partner violence, food insecurity, and harsh punishment. | - Not reported | - Not reported
Brief Infant-Toddler Social and Emotional Assessment (BITSEA)^117,^ ^149^ | Lowell et al, 2011^117^ | - 42-item screener for parents and child-care providers; - Measures both problems (problem scale, including items associating with externalizing and internalizing behaviors and dysregulation) and delays in the acquisition of competencies (competence scale, including competence, social relatedness, maladaptiveness, and atypicality) in 1- to 3-year-olds, also consists of items designed to measure symptoms of autism spectrum disorders. Intended to identify children “at risk” for or currently experiencing social-emotional/behavioral problems. | - 10-to-45-day test-retest reliability (intraclass correlation coefficient) 0.87 for the problem scale; 0.85 for the competence scale, n=119).^117^ | - Not reported
Parent Risk Questionnaire (PRQ)^117^ | Lowell et al, 2011^117^ | - Developed for intervention (Lowell et al, 2011^117^):; - 25-item parent-report screener Assessing risk in 12 areas including depression, domestic violence, substance use, homelessness, incarceration, isolation, single and teen parenthood, education, and employment. | - Not reported | - Not reported

* Specifically, we evaluated tests of validity against an external measure of abuse or neglect (not self-report), and included measures such as sensitivity, specificity, negative or positive predictive values, false negatives or positive, and area under the curve, when reported.

† By including subjective comments from the screening, 273 women would have been identified as high risk, with 15 being reported subsequently for abuse; 1127 women would have been identified as not being at high risk, with 8 being reported subsequently for abuse^133^

Appendix A3 Table 2 Reliability and Validity of Additional Risk Screening Instruments

Instrument | Description | Reliability | Validity^*^
BabyFirst Screen^150^ | - 23 weighted items relating to biological, psychological, and social risk factors for maltreatment.; - One item about congenital anomaly or acquired disability, four items about developmental risk factors such as low birth weight and complications of pregnancy and delivery.; - 8 items on family interaction risk factors such as age of mother, single parent households with or without social support, parent education status.; - 10 items of other risk factors including relationship distress, multiple births, prenatal class attendance, maternal smoking during pregnancy, harsh discipline, existing involvement with child protective service, anxiety disorder, parent’s criminal history or exposure to child abuse/neglect | - Not reported | - BabyFirst Screen administered at birth to parents of infants born in Manitoba, Canada between 2000 to 2002, followed for reports of out-of-home placement through 2004; - 5,563 (14.9%) screened ‘‘at risk,’’ 24,923 (66.7%) screened ‘‘not at risk.” 6,859 (18.3%) not screened^150^; - 3% placed in out-of-home care at least once during the study period.; - Reported sensitivity: 77.6%; specificity: 83.3%; positive predictive value: 10.9%, negative predictive value: 99.3%; false positive rate:16.7%; false negative rate: 22.4%
Brisbane Evaluation of Needs Questionnaire^151^ | - Study-developed questionnaire designed to identify adverse family characteristics; - The first tier included physical forms of domestic violence, childhood abuse of either parent, sole parenthood and ambivalence to the pregnancy (sought termination, no antenatal care); - Second tier included less definitive risk factors: maternal age less than 18 years, unstable housing, financial stress, less than 10 years of maternal education, low family income, social isolation, history of mental health disorder (either parent), alcohol or drug abuse, and domestic violence other than physical violence | - Not reported | - Not reported
Child Abuse Potential Inventory (CAPI)^138,^ ^152^ | - 160-item self-report measure consisting of a primary clinical scale containing a 77-item Physical Abuse Scale with eight subscales: distress, rigidity, unhappiness, ego, loneliness, problem with child and self, problem with family, and problem with others. | - Split-half and Kuder-Richardson-20 reliability coefficients range from 0.92 to 0.98^138^ | - Not reported

* Specifically, we evaluated tests of validity against an external measure of abuse or neglect (not self-report), and included measures such as sensitivity, specificity, negative or positive predictive values, false negatives or positive, and area under the curve, when reported.