# Acknowledgements

This systematic evidence review was prepared for the Agency for Healthcare Research and Quality (contract #290-97-0018, task order no. 2) to be used by the U.S. Preventive Services Task Force. Task Force members Steven Woolf, MD, MPH and Janet Allen, PhD, RN, served as liaisons. Oregon Health & Science University, Evidence-based Practice Center staff who contributed to this project included Peggy Nygren MA, research associate, Susan Wingenfeld, administrative assistant, and Patty Davies, MA, librarian.