# Discussion

## Summary of Evidence Quality

Table 10 summarizes the evidence obtained for this systematic review by indicating the type of study design and quality of evidence for each key question, using criteria developed by the USPSTF.^27^ Quality ratings include scores for both internal validity (the strength of individual studies) and external validity (the extent to which studies are generalizable to a primary care population).

Table 10. Summary of Evidence Quality

Key Questions | Evidence Code* | Quality of Evidence†
| | Internal Validity | External Validity
Arrow 1: Does screening using risk factor assessment and/or bone density testing reduce fractures? | None
Arrow 2: Does risk factor assessment accurately identify women who may benefit from bone density testing? | II-2 | Poor-good: small studies, risk assessment instruments often not validated | Poor-fair: no instruments used widely for screening purposes although some were developed from
Arrow 3: Do bone density measurements accurately identify women who may benefit from treatment? | II-2 | Fair-good: studies indicate the short-term predictability for fracture. | Fair: not known how well results of studies translate to practice.
Arrow 4: What are the harms of screening? | II-2, III | Poor-fair: small studies, descriptive. | Poor: small studies, selected subjects.
Arrow 5: Does treatment reduce the risk of fractures in women identified by screening? | I | Poor-good: no good-quality trials for estrogen. | Poor-fair: subjects of trials may be different than primary care patients.
| | Good trials indicate fractures prevention for raloxifene and bisphosphonates.
Arrow 6: What are the harms of treatment? | I, II-2 | Poor-good: long-term effects of newer agents not known. | Poor-fair: difficult to know how risks affect individual patients.

* Evidence codes based on study design categories27:

I = randomized, controlled trials

II-1 = controlled trials wihout randomization

II-2 = cohort or case-control analytic studies,

II-3 = multiple time series, dramatic uncontrolled experiments

III = opinions of respected authorities, descriptive studies

† Quality of evidence based on criteria developed by the USPSTF27

## Outcomes Table

To estimate the effect of screening for osteoporosis on reducing hip and vertebral fractures in 10,000 postmenopausal women, we created an outcomes table based on assumptions from the reviewed studies (Table 11). These estimates include age-specific prevalence rates expressed in 5-year age intervals^161^ and treatment effects based on trials (37% risk reduction for hip fracture, 50% for vertebral fracture).^150,^ ^28,^ ^137,^ ^162^ We estimated an adherence rate of 70% based on reports of adherence and side effects from treatment trials and allowing for less optimal adherence in the general population.

Table 11. Screening for Osteoporosis in 10,000 Postmenopausal Women

Hip and Vertebral Fracture Outcomes by 5-year Age Intervals | Age (years)
| 50–54 | 55–59 | 60–64 | 65–69 | 70–74 | 75–79
Base Case Assumptions†
Prevalence of osteoporosis | 0.0305 | 0.0445 | 0.065 | 0.120 | 0.2025 | 0.285
Relative risk for hip fracture with treatment | 0.63 | 0.63 | 0.63 | 0.63 | 0.63 | 0.63
Relative risk for vertebral fracture with treatment | 0.52 | 0.52 | 0.52 | 0.52 | 0.52 | 0.52
Adherence to treatment | 0.7 | 0.7 | 0.7 | 0.7 | 0.7 | 0.7
Results, n
Identified as high-risk (osteoporotic) | 305 | 445 | 650 | 1200 | 2025 | 2850
Hip fractures prevented | 1 | 2 | 5 | 14 | 39 | 70
NNS to prevent 1 hip fracture | 7446 | 4338 | 1856 | 731 | 254 | 143
NNT to prevent 1 hip fracture | 227 | 193 | 121 | 88 | 51 | 41
Vertebral fractures prevented | 5 | 7 | 22 | 40 | 95 | 134
NNS to prevent 1 vertebral fracture | 1952 | 1338 | 458 | 248 | 105 | 75
NNT to prevent 1 vertebral fracture | 60 | 60 | 30 | 30 | 21 | 21

* NNS = number needed to screen for benefit; NNT = number needed to treat. reduction for hip fractures143, and 50% risk reduction for vertebral fractures28; treatment compliance of 70% based on results of treatment trials and allowing less optimal compliance.

Using the assumptions in the table, if 10,000 65-to-69-year old women with an osteoporosis prevalence rate of 0.120 underwent bone densitometry (DXA of the femoral neck), 1,200 would be identified as high-risk (T-score <-2.5). If these women were offered treatment that resulted in a 37% reduction of hip fracture risk and 50% reduction of vertebral fracture risk, and 70% of them adhered to therapy, then 14 hip fractures and 40 vertebral fractures would be prevented over 5 years. The number of women in this age group needed to screen to prevent 1 hip fracture in 5 years is 731, and the number of women with low bone density needed to treat is 88. The number needed to screen to prevent 1 vertebral fracture is 248, and the number needed to treat is 30. These numbers become more favorable in the older age groups because the prevalence of osteoporosis increases steadily with age. For women age 75 to 79, the number needed to screen is 143, and the number needed to treat is 41 for hip fractures.

The literature review indicated that the prevalence of osteoporosis, the predictability of densitometry, and the effectiveness of treatment are less, or may be less, for younger than for older postmenopausal women. To determine if considering clinical risk factors when screening younger postmenopausal women is useful, we also included risk estimates for clinical risk factors in a sensitivity analysis. Because studies of risk assessment instruments that we reviewed included predominantly older women, we determined risk estimates by reviewing 7 observational studies of risk factors and fractures specifically conducted in populations with at least 50% of subjects under age 65.^163–169^

The 3 most consistent predictors of fracture in these studies were increasing age, low weight or body mass index, and nonuse of hormone replacement therapy (defined by current, ever, or certain durations of use). These are also the 3 variables used in the Osteoporosis Risk Assessment Instrument (ORAI) to identify women with low bone density,^39^ and the variables most strongly associated with low bone density in a study enrolling mostly younger postmenopausal women in the U.S.^170^ Based on these studies, we estimated that having one of these risk factors increased the probability of having osteoporosis by up to 100% and the risk of fracture by 70% (relative risk 1.7).

For the younger age groups, the presence of clinical risk factors influences the outcomes. For example, only 5 hip fractures are prevented over 5 years when screening all women age 60 to 64 years, but this increases to 9 if a risk factor increasing the risk of fracture by 70% is present. For women 60 to 64 years old with a risk factor, the number needed to screen (1092) and number needed to treat (72) to prevent hip fractures approach those of the 65-to-69-age group (Figure 2).

Figure 2. Number Needed to Screen to Prevent 1 Hip Fracture in 5 Years

## Conclusions

Although many studies have been published about osteoporosis in postmenopausal women, there have been no trials of screening and, therefore, no direct evidence that screening improves outcomes. Instruments developed to assess clinical risk factors for low bone density or fractures generally have moderate-to-high sensitivity and low specificity, many have not been validated, and none have been widely tested in a practice setting. Among different bone density tests measured at various sites, bone density measured at the femoral neck by dual-energy x-ray absorptiometry is the best predictor of hip fracture and is comparable to forearm measurements for predicting fractures at other sites. Women with low bone density have a 40 to 50% reduction in fracture risk when treated with raloxifene (vertebral fractures) or bisphosphonates (both vertebral and nonvertebral fractures). Trials of estrogen are inconclusive because of methodologic limitations.

Support for population screening would be based on evidence that the prevalences of osteoporosis and fractures increase with age, that the short-term risk of fracture can be estimated by bone measurement tests and risk factors, and that the fracture risk among women with low bone density can be significantly reduced with treatment. When applying these data to outcomes tables of screening strategies, estimates of the numbers of women needed to screen and treat to prevent fractures can be determined. Age-based screening is supported by prevalence data; i.e., the number needed to screen to prevent fractures decreases sharply as age and prevalence increase. Use of risk factors to screen younger women may identify additional high-risk women and provide number needed to screen estimates comparable to screening older women without risk factors. These findings relate to screening asymptomatic women only, and do not apply to women who would be considered for testing based on pre-existing or incident fractures or presence of secondary causes of osteoporosis.

There are several limitations to this approach, however, and results from a well-designed trial of screening strategies will supercede our estimations based on indirect evidence. Our estimates in the outcomes table are limited by assumptions that are arguable or highly variable by patient and setting. Our treatment effect and compliance assumptions are especially optimistic and reflect results of clinical trials, not clinical practice. We chose a 5-year time horizon based on the short-term predictability of bone measurement tests as well on results of short-term treatment trials. Long-term outcomes may provide a more accurate estimate of benefits. Also, we cannot exclude the possibility that harms outweigh benefits, particularly since the long-term effects of bisphosphonates are not yet known.

## Limitations of the Literature

Evidence upon which we based our conclusions is also limited. Overall, evidence is generally stronger for women older than 65 years than younger because more research has been done in older age groups. Bone loss in the peri- and early postmenopausal years is important to long-term bone health, but few published studies address screening and treatment for younger postmenopausal women. Also, younger women are more likely to experience fractures of the radius, vertebrae, and other sites than of the hip. Most studies currently focus on hip fracture outcomes.

Similarly, studies of non-white women are limited. Prevalence data indicate that white and Asian women have the highest rates of osteoporosis,^171^ and white women are generally 2 to 3 times more likely than non-white women to suffer a hip fracture.^172^ Rates in African American women are roughly half of other groups.^13,^ ^173^ Although limited in number, studies of risk factors for fracture indicate similarities across racial groups.^164,^ ^174,^ ^175^ However, no bone measurement studies or treatment trials include large numbers of non-white women. It may be difficult to provide race-specific screening recommendations in the absence of more evidence.

The role of clinical risk factors is still unclear. Although many risk factors are associated with osteoporosis and fractures, how to use them to select women to test or treat is uncertain. The risk factors identified by our literature review and used in the outcomes table are only best estimates. It may be that other risk factors will prove to be equally predictive when used for screening purposes.

## Future Research

Further validation of existing risk assessment instruments or development of new ones would be useful. Few studies have evaluated the effect of altering modifiable risk factors such as smoking cessation, strength and balance training, and visual correction. These interventions may prove to be as effective as drug therapy in preventing fractures, and may also be important effect modifiers that would confound the observed effectiveness of the treatments.

The use of peripheral bone measurement tests in screening, either alone or as part of a sequential approach, has not been well studied. Most treatment trials use hip DXA as entry criteria and results may not apply to women diagnosed by other tests. Further research is needed to define the appropriate use of these technologies.

How frequently to screen has also not been specifically studied, but data are needed to determine optimal screening intervals. Estimations can be made based on the age-specific prevalence of osteoporosis and precision of bone measurement devices. Less frequent testing for younger postmenopausal women when prevalence is lower (e.g., 5-year intervals), and more frequent testing for older women (e.g., 2-year intervals) might be reasonable. Screening intervals less than 2 years seem unwarranted because the precision error of densitometry would likely exceed the estimated bone loss in such a brief time interval.^176^ Once a woman is screened and determined to have osteoporosis, future bone measurement testing for screening purposes would not be necessary.

Many gaps remain in the evidence for osteoporosis screening. Although the effectiveness of population screening has yet to be demonstrated, current literature provides support for screening based on evidence that osteoporosis and fractures increase with age, that short-term risk of fracture can be estimated by bone measurement tests and risk factor assessment, and that treatment may reduce fracture risk among women with low bone density. Osteoporotic fractures present an enormous health burden on an expanding elderly population, underscoring the importance of further research to more accurately determine the benefits and harms of screening.