# Results

## Arrow 1: Does screening using risk factor assessment and/or bone density testing reduce fractures?

No studies have evaluated the effect of screening in reducing fractures.

## Arrow 2: Does risk factor assessment accurately identify women who may benefit from bone density testing?

Hundreds of studies have reported associations between clinical risk factors and low bone density and fractures in postmenopausal women. Several clinical risk factors are consistently associated with increased risks of low bone density and fractures (advancing age, white race, low weight or weight loss, nonuse of estrogen replacement, history of previous fracture, family history of fracture, history of falls, and low scores on one or more measures of physical activity or function), while others are important in some, but not all, studies (smoking, alcohol use, caffeine use, low calcium and vitamin D intake, and use of certain drugs).^29^ Fewer studies, however, evaluate how to use these risk factors to identify individual women at risk for low bone density or fracture. Ideally, risk factor assessment would aid clinicians in selecting who should and should not undergo bone density testing, reduce modifiable risk factors, and consider treatment.

### Risk Assessment Based on the Likelihood of Low Bone Density

One approach to risk assessment is to identify women at high risk for osteoporosis for bone density testing. This approach assumes that those with low bone density could benefit from identification and treatment.

We identified 10 cross-sectional studies that describe methods of determining risk for individual women based on selected clinical risk factors (Table 5, bone density outcomes).^30–39^ The most common methodologic limitations of these studies were lack of generalizability because of small numbers of subjects or nonrepresentative subjects, and lack of validation.

Table 5. Studies of Risk Factor Assessment

Author | Design | N | Validated | Risk Factors Included | Outcome | Performance | Quality Rating*
Bone Density Outcomes
Slemenda, 1990^36^ | Cross-sectional | 124 | No | Age, height, weight, calcium intake, caffeine intake, alcohol and tobacco use, urinary markers of bone turnover. | Correct classification of high or low BMD (lowest third of subjects) | Midshaft radius: 68% low, 77% high. Lumbar spine: 61% low, 45% high. Femoral neck: 66% low, 53% high. | Poor
Falch, 1992^30^ | Cross-sectional | 73 | Yes | Low body weight, reduced renal phosphate reabsorption, smoking. | Bone loss | Sensitivity 36%, specificity 89%, PPV 74%. | Poor
Ribot, 1992^35^ | Cross-sectional | 1565 | No | Weight, menopause, duration of menopause. | Vertebral BMD < -2 SD | Sensitivity 73%, specificity 66%. | Fair
Elliot, 1993^32^ | Cross-sectional | 320 | Yes | Spine BMD: age, weight, smoking status, age at menarche. Femoral neck BMD: age, weight, family history, activity, smoking status. | Low lumbar spine and femoral neck BMD (lowest third of age matched normal | Lumbar spine: sensitivity 86%, specificity 32%. Femoral neck: sensitivity 89%, specificity 25%. | Fair
Michaelsson, 1996^33^ | Cross-sectional | 175 | No | Weight > 70kg. | Femoral neck BMD < -2.5 SD | Sensitivity 94%, specificity 36%, PPV 21%, NPV 97%. | Fair
| Cross-sectional | 61 | No | 1. Arm span-height difference of at least 3 cm. 2. Arm span-height difference,age above or below 70, and whether arm span was below or above 160 cm. | BMD <= -2.5 SD and vertebral fracture | Arm span only: sensitivity 58%, specificity 56%. Arm span, age, arm span length: sensitivity 81%, specificity 64%. | Poor
Ballard, 1998^34^ | Cross-sectional | 1158 | No | Age, age at menopause, height, weight, gravidity, parity, current use of steroids, current HRT. | Osteoporosis of femoral neck and/or spine | ROC area 0.73. | Fair
Lydick, 1998^37^ | Cross-sectional | 1279 | Yes | Age, weight, race, estrogen use, rheumatoid arthritis, history of fractures. | Femoral neck BMD <= -2 SD | Sensitivity 89%, specificity 50%; ROC area 0.81. | Good
Goemaere, 1999^38^ | Cross-sectional | 300 | No | 18-item questionnaire of risk factors for osteoporosis (race, height loss, age, weight, smoking, coffee, alcohol, dairy product use, activity, family history, existence of comorbidities, history of wrist fracture, menopause before 45 years, corticosteroid use). | Lumbar spine, femoral neck, and hip BMD | Lumbar spine: ROC area 0.66; Femoral neck: ROC area 0.69; Hip: ROC area 0.76. | Fair
Cadarette, 2000^39^ | Cross-sectional | 926 | Yes | Age, weight, current use of HRT. | Hip or lumbar spine BMD <= -2.5 | Sensitivity 95%, specificity 41%. | Good
Fracture Outcomes
Kleerekoper, 1989^50^ | Case-control | 663 | No | Model 1; total months of lactation, family history of osteoporosis, years post menopause, weight. Model 2: breast fed, surgical menopause, age at menarche, age, smoking status. | Vertebral fractures | Model 1: ROC area (SE) 0.55 (0.07); sensitivity 56%; specificity 54%. Model 2: ROC 0.51 (0.042); sensitivity 63% specificity 39%. | Fair
van Hemert, 1990^44^ | Cohort | 1014 | No | Age, metacarpal cortical area, relative cortical area, BMI, height, diameter of forearm, diameter of knee, age at menarche, age at menopause, smoking, number of children, period of lactation. | Osteoporotic fractures | Sensitivity 48%, specificity 82%. | Fair
Cooper, 1991^51^ | Case-control | 1012 | No | Age, height, vertebral fracture after age 45, age of last menstrual period, number of children, ever use oral corticosteroid. | Vertebral fractures | Sensitivity 51%, specificity 69%. | Fair
Wolinsky, 1994^49^ | Cohort | 368 | No | White race, female gender, living in southern U.S., age, having been hospitalized in the previous year, previous fall, body mass. | Hip fractures | ROC 0.71; sensitivity 64.7%, specificity 65.7%. | Fair
Johnell, 1995^48^ | Case-control | 5618 | No | Late menarche, poor mental score, low BMI, low physical activity, low exposure to sunlight, and low consumption of calcium and tea. | Hip fractures | Sensitivity 55%, specificity 65%. | Fair
Ranstam, 1996^45^ | Case-control | 7474 | No | Mental-functional risk score: knowledge of the day of week, knowledge of age, ability to wash, ability to dress. . | Hip fractures | A less than perfect score had a sensitivity 46%, specificity 79%. | Fair
Tromp, 1998^47^ | Cohort | 1469 | No | Female gender, living alone, past fractures, inactivity, height, use of analgesics | Probability of fractures | No predictors = 0%; 4 predictors 0.129 | Fair
Burger, 1999^46^ | Cohort | 5208 | No | Model with BMD: age, gender, height, use of a walking aid, current smoking, BMD of femoral neck. Model without BMD: age, gender, height, use of a walking aid, current smoking, weight. | Hip fractures | Model with BMD: ROC area 0.88; sensitivity 70%, specificity 84%. Model without BMD: ROC area 0.83; sensitivity 70%, specificity 83%. | Fair

* Harris^27^

Note: BMD indicates bone mass density; NPV, negative predictive value; PPV, postive predictive value; SD, standard deviation.

ROC indicates receiver operating characteristic (values >= 0.80 are usually required to consider a test to be effective).

One risk assessment instrument from a study with a good-quality rating assigned points to selected risk factors for low femoral neck bone density (age, weight, race, estrogen use, presence of rheumatoid arthritis, history of fractures) to create a summary measure referred to as the Simple Calculated Osteoporosis Risk Estimation (SCORE).^37^ These risk factors were obtained from over 1,200 women from the community and were subsequently tested in a validation group of 259 women. SCORE had an area under the ROC curve of 0.81 in the development group, and a sensitivity of 91% and specificity of 40% in the validation group.

SCORE performed poorly, however, in a cohort from the Rancho Bernardo Study.^40^ In this study, women had a mean age approximately 10 years above that of women in the original SCORE cohorts. A total of 1,013 postmenopausal white women age 44 to 98 years underwent assessment with SCORE protocol and DXA of the femoral neck. Using the recommended SCORE cutpoint of 6, all but 5.5% of the women would have been recommended for bone density testing.

The Osteoporosis Risk Assessment Instrument (ORAI) uses 3 items--age, weight, and current use of hormone replacement therapy--to identify women with low bone density.^39^ It was developed in a community-based sample of 1,376 women over 45 years of age who did not report a previous diagnosis of osteoporosis. The prevalence of osteoporosis in the development cohort (n=926), defined in the study as a T-score of -2.5 or lower at the hip or lumbar spine, was 11%. In the validation set (n=450), the three items identified 94.4% of the women who had osteoporosis. The specificity was 41.4%.

A recent study compared the performance of 5 clinical decision rules for bone density testing among 2,365 postmenopausal women aged 45 years or older enrolled in a community-based study of osteoporosis in Canada.^41^ These included guidelines from the National Osteoporosis Foundation (NOF),^42^ SCORE,^37^ ORAI,^39^ Age, Body Size, No Estrogen (ABONE),^43^ and body weight criterion (weight <70 kg).^33^ In this study, SCORE and ORAI had the highest area under the ROC curves (SCORE: sensitivity 99.6%, specificity 17.9%, ROC 0.80; ORAI: sensitivity 97.5%, specificity 27.8%, ROC 0.79).

### Risk Assessment Based on Risk of Fracture

The assumption underlying this approach is that women who have a higher overall risk of fracture have a higher benefit from identification and treatment--i.e. the number needed to treat is lower, and the cost-effectiveness of treatment is higher, for higher-risk patients.

We identified 8 studies of clinical prediction models of fracture risk (Table 5, fracture outcomes).^44–51^ None of these studies received a good rating for internal validity. Four studies evaluated hip fracture outcomes, 2 vertebral fractures, and 2 all types of fractures. These studies determined how well risk factors were associated with fractures known to have occurred already (4 case-control studies), or how well they would predict fractures in the future (4 prospective cohort studies).

The best-performing model for fracture outcomes reported an area under the ROC curve of 0.83.^46^ This model was based on a prospective study of 5,208 subjects whose risk factors were determined at baseline. Hip fracture outcomes were determined 3.8 years later, and risk points were assigned from beta coefficients of regression models. Variables in the model included age, gender, height, use of a walking aid, current smoking, and weight. Adding femoral neck bone density to the model and remodeling all of the parameters improved its performance only slightly. This model has not been tested prospectively in a separate population.

## Arrow 3: Do bone density measurements accurately identify women who may benefit from treatment?

Several technologies are available to measure bone (Table 6).^52–55^ Single photon absorptiometry (SPA), first described in 1963, was based on the principle of measuring photons absorbed by mineral in the tissues.^56^ More recent densitometry techniques, such as dual-energy x-ray absorptiometry (DXA), are based on the same principle, but have the advantages of access to axial sites, better precision, lower radiation exposure, shorter examination time, reduced influence of soft tissue thickness, and a more convenient or reliable source of photons. Results of these densitometry tests are expressed as grams of mineral in a projected area (g/cm^2^). Quantitative computed tomography (QCT), an alternative method of measuring axial bone density, is expressed as the grams of mineral in a volume of bone (g/cm^3^). QCT also provides a computed tomography image that radiologists can use to assess bone architecture and structural integrity.

Table 6. Characteristics of Bone Density and Quantitative Ultrasound Tests

Test | Sites | Examination time, operator skill needed | Radiation exposure | Capital Costs-Technology Purchase | Precision | Cost | Charges | Comments
| | minutes, skill level | | $U.S. | % | | $US
Single photon absorptiometry (SPA) | Wrist, heel | 5–15, low | low | | | | $50–150 | Uses isotopes
Dual-energy photon absorptiometry (DPA) | Spine, proximal femur, whole body | 20–40 | low | $20,000 | 3–10 | inexpensive | $150–300 | Uses isotopes
Single x-ray absorptiometry (SXA) | Peripheral sites | | 0.08–4.6 uSv | $20,000 | 0.5–2 | | $50–150
Dual-energy X-ray absorptiometry (DEXA or DXA) | Lumbar spine, proximal femur | 5–10, high | 0.08–4.6 uSv (pencil beam) or 60 uSv (fan beam) | $100,000–200,000 | 1–5 | Fairly expensive | $136* | Influenced by osteoarthritis
| Total body | | | | 0.5 | Expensive
Peripheral dual-energy X-ray absorptiometry (pDXA) | peripheral (wrist, heel) | | | | 2–5 | Inexpensive
Quantitative computed tomography (QCT) | Spine | 10–30, high | 25–360 uSv | $5,000–15,000† | 2–5 | | $150–300 | Higher radiation exposure; Measures the true volumetric density
Quantitative ultrasonography (QUS) | Heel, fingers, tibia, patella | 5–10, low | none | $10,000–100,000 | 0.4–4 | | $35* | Low cost, portable, no radiation
Radiographic absorptiometry (RA) & Quantitative mircodenistometry (QMD) | Hand | 5–10, high | 0.08–4.6 uSv | ^†^ | 1–2 | | $90–160 | Low cost, portable

* Average Medicare reimbursement

† uses conventional CT or radiographic equipment

Note: uSv indicates microSieverts.

Densitometry devices that measure peripheral bone density are considerably less expensive to buy and use than axial DXA. Radiographic absorptiometry and quantitative microdensitometry use computer software to estimate bone density from conventional radiographs of the hand. Other devices for measuring bone density in the arm or heel include single-energy x-ray absorptiometry (SXA), peripheral dual-energy x-ray absorptiometry (pDXA), and peripheral quantitative computed tomography (pQCT).

Quantitative ultrasound (QUS) devices report the way that bone attenuates sound waves and/or the speed with which sound travels through the bone.^57^ Commercial devices measure the “broadband ultrasonic attenuation” (BUA, expressed as dB/MHz), the speed of sound (SOS), and the “stiffness,” a measure derived from the BUA and SOS. Quantitative ultrasound does not measure bone mineral content and is categorized separately from the other technologies. While these measures are not highly correlated with measures of bone density made by DXA, some in vitro studies^58–61^ but not all^62^ suggest that QUS might reflect other aspects of bone structure that could be associated with fragility.

### Accuracy and Reliability of Tests

The accuracy of densitometry tests in everyday practice has not been studied outside research protocols and major referral centers. Patient factors such as obesity, handedness, and edema (for ultrasound),^63–68^ and osteoarthritis (for DXA of the spine)^69^ affect estimates of bone density.

Correlations among different bone density devices are low (0.35 to 0.60).^70–90^ When used in the same patients, DXA machines from different makers differ by 6 to 15%^91–96^ in the proportion of patients diagnosed to have osteoporosis.

Published studies consistently show that the probability of being diagnosed with osteoporosis depends on the choice of test and site.^97–101^ One analytical study, for example, found that, in the NHANES III sample, 6% of women over 60 years old would be diagnosed to have osteoporosis if DXA of the total hip were used as the only test, versus 14% for DXA of the lumbar spine, 3% for QUS, and 50% for QCT.^98^

The likelihood of being diagnosed with osteoporosis also depends on the number of sites tested. Testing in the forearm, hip, spine, or heel will generally identify different groups of patients. A physician cannot say, based only on a forearm test, that the patient “does not have osteoporosis.” Conversely, although the results of a test at any site are associated to some degree with fractures at other sites, the physician may not be able to assess whether the patient who has a low T-score on a hand or forearm test has significant bone loss at other sites.

### Prediction of the Short-term Risk of Fractures

The literature describing the performance of bone measurement tests to predict fractures is extensive. We focused our review on a meta-analysis that provided a summary of older studies, and on prospective cohort studies not included in the meta-analysis.

The meta-analysis assessed 23 publications from 11 separate prospective cohort studies published before 1996.^102^ Studies were pooled to estimate the age-adjusted relative risk of various types of fractures for a one standard deviation decrease in bone density. Nearly all available data included in these studies were from women in their late 60s or older and all tests used densitometry techniques. Results of the meta-analysis indicated that DXA measured at the femoral neck predicted hip fracture better than measurements made at other sites, and was comparable to forearm measurements for predicting fractures at other sites.^103–105^ For bone density measurements made at the femoral neck, the pooled relative risk per one standard deviation decrease in bone density was 2.6 (2.0–3.5).

To update these results, we identified 15 cohort studies either not included in the meta-analysis or published since 1996 of peri- or postmenopausal women who had DXA, QUS, radiographic absorptiometry (including quantitative microdensitometry), or other bone measurement tests that reported fracture outcomes.^103,^ ^105–118^ The cohorts include the Study for Osteoporotic Fractures (SOF), Epidemiologie de L'Osteoporose (EPIDOS), Hawaii Osteoporosis Study (HOS), Diagostisch Onderzoek Mammacarcinoom (DOM), two projects from Aberdeen, Scotland, and one each from Rotterdam, Netherlands, Kuopio, Finland, and Modena, Italy. Details of these studies are reported elsewhere.^29^

For this review, we included studies that reported DXA of the hip for the prediction of hip fractures (Table 7).^103,^ ^105–110,^ ^112,^ ^114,^ ^116,^ ^117^ Rather than reporting details of individual studies, we reported results from the cohorts according to the age groups addressed. We confined all analyses of prospective studies to the time horizon actually observed, rather than extrapolating to 5-year or lifetime risk. We described the probability of a fracture in subjects classified as “high risk” or “low risk” according to their hip DXA result. Classification of “high” and “low” risk varied across studies, and was based on the cutoff value for the test. In one analysis of the SOF cohort, for example, the overall risk of hip fracture during approximately 2 years of followup was about 1% (9 per 1,000). If the hip DXA indicated osteoporosis, the probability of a hip fracture was 2.3%; if not, the probability was 0.46% (about 5 per 1,000). For the average patient in this cohort, then, low bone density increased the chance of fracture within 2 years from 9 to 23 per 1,000, while an osteopenic or normal result decreased the probability of fracture from 9 to 5 per 1,000. The limitations of measuring these differences in probabilities are that they depend on the length of followup and the pretest probability of fracture.

Table 7. Prospective Studies of DXA of the Hip Reporting Hip Fractures

Cohort | Population | Age range | Follow up (years) | N | Probability of hip fracture | Mean bone density | Cutoff values | Relative risk per 1 SD (CI) | Probability of hip fracture*
| | | | | | | | | “low risk” | “high risk”
Study of Osteoporotic Fractures (SOF)103, 105, 106, 114 | Community-dwelling white women from 4 areas in the U.S. recruited from lists. | >=65 | 1.8–2.9 | 5236 | 0.009 | 0.63 | lowest quartile | 2.6 (1.9–3.8) | 0.005 | 0.023
| | 65–79 | 2.9 | | | 0.66 | | 2.9 (2.2–3.9)
| | >=80 | 2.9 | | | 0.59 | | 2.1 (1.4–3.2)
| | 65–69 | 1.8 | 2371 | 0.003 | | age-specific quartiles | | 0.0028 | 0.005
| | 70–74 | 1.8 | 3013 | 0.0076 | | | | 0.005 | 0.016
| | 75–79 | 1.8 | 1728 | 0.007 | | | | 0.003 | 0.019
| | 80–84 | 1.8 | 731 | 0.018 | | | | 0.007 | 0.049
| | >=85 | 1.8 | 291 | 0.024 | | | | 0.014 | 0.028
Epidemiologie de L'Osteoporose (EPIDOS)108–110,116 | Women from 5 cities in France recruited from voting lists and health insurance companies. | >=75 | 2 | 5656 | 0.02 | 0.69–0.72 | <0.703 g/cm2 | 1.9 (1.6–2.4) | 0.033 | 0.008
| | <80 | 2 | 3982 | 0.013 | 0.73 | T-score <-2.5 | | 0.002 | 0.025
| | >=80 | 2 | 3616 | 0.028 | 0.67–0.71 | T-score <-2.5 | | 0.006 | 0.04
Rotterdam107 | People aged 55 and over living in Rotterdam, Netherlands. | >=55 | 3.8 | 3078 | 0.13 | | risk function† | 2.5 (1.8–3.6) | 0.007 | 0.069

* Probability of hip fracture if bone density was classified as high or low risk.

† Regression equation using age and bone density.

Note: CI indicates confidence interval; DXA, dual energy x-ray absorptiometry; SD, standard deviation.

DXA of the hip predicted hip fracture best in the SOF and Rotterdam studies (relative risk per one standard deviation decrease 2.6 [CI 1.9–3.8] and 2.5 [CI 1.8–3.6]). Prediction was not as good among women over 75 years of age. Two recent studies included younger, perimenopausal women between the ages of 45 and 56, but these subjects had too few hip fractures to estimate the relative risk. The adjusted relative risk for all nonvertebral fractures was 1.39 (CI 1.2–1.6) in one study^112^ and 1.4 (1.3–2.4) in the other,^117^ which is comparable to the relative risks for all nonvertebral fractures in older women. The 2-year probability of fracture in the group with high bone density was 2.4%, versus 1.7% in the group with low bone density. The low difference (7 per 1,000) reflects the fact that bone density testing provides less information about the short-term risk of fracture in younger, lower-risk individuals.

## Arrow 4: What are the harms of screening?

There are several potential harms of screening for women, however, very few studies have been published. Receiving a test result indicating osteoporosis could produce anxiety and perceived vulnerability^119^ that may be unwarranted. Women with osteoporosis voiced significantly more fears than women who had normal bone density on a quality of life questionnaire.^21^

Some clinicians believe that the results of bone measurement tests motivate patients to exercise, adhere to medication regimens, and change other behaviors to reduce their risk of fracture. Conversely, women informed that they do not have osteoporosis may interpret this to mean that they do not need to engage in preventive measures such as exercise, calcium intake, and smoking cessation. Some women may be falsely reassured that abnormal results from a hip DXA scan from last year appear “improved” by a normal calcaneal ultrasound report this year. The potential time, effort, expense, and radiation exposure of repeated scans over a lifetime have not yet been determined.

A limited number of studies have evaluated the impact bone density test results have on women including adherence to therapy. Of 1,335 women from the SOF cohort who completed a questionnaire about estrogen therapy and were taking estrogen, 34% reported their primary reason was prevention or treatment of osteoporosis.^120^ In a randomized trial of 141 women within 3 years of menopause who were referred from 3 private practices, those who underwent bone density testing were more likely to fill a prescription for HRT than women who received an educational message about osteoporosis (63% vs. 20%, p<0.05).^121^ Another study found that test results appear to influence physicians' decisions to prescribe HRT.^122^

A randomized trial of screening for osteoporosis measured quality-of-life and use of hormone replacement therapy 2 years later.^123^ A total of 1,600 women aged 45 to 54 years were randomly selected from a population-based registry in Aberdeen, Scotland. In the group assigned to screening, 576 (72%) responded to an invitation to have bone density testing. Two years later, use of hormone replacement therapy was higher in the screened group (30% vs. 24%), and was highest (43%) among screened women who had bone density in the lowest quartile. There were no differences between screened and unscreened women in any aspect of quality of life, menopausal symptoms, anxiety, or frequency of falls.

A survey of 261 women who received densitometry studied their perception of risk of fracture and degree of worry, and whether they made changes based on their test results.^124^ Of the 53% who reported that their test was below normal, virtually all of them (94%) reported initiating preventive measures. Fifty-six percent of those who reported their test was normal also initiated prevention measures. Women who reported below normal test results were more likely to start HRT than those with normal or above results. Of the entire group, 24% who reported below normal results said they began limiting activities to avoid falling; for women 65 years and older, this proportion rose to 31%. About one-third of the sample (86 women) had a second bone measurement test. About 26 women reported losing bone at an accelerated rate; of these, 22 initiated additional prevention.

Potential harms may also arise from inaccuracies and misinterpretations of bone measurement technology. The variation between techniques, along with the lack of methods to integrate bone density results with clinical predictors, makes it difficult for clinicians to provide accurate information to patients about their test results. One randomized trial examined the effect of densitometry on the practice patterns of 57 primary care physicians who ordered DXA tests for their patients, and also their understanding of the reports they received.^125^ Physicians found densitometry reports confusing and were not confident that their interpretations of T-scores were accurate. This was especially true among those who received a short technical report compared to a longer written report.

## Arrow 5: Does treatment reduce the risk of fractures in women identified by screening?

Although several forms of treatment have been studied, we focused on recent trials of three types of agents: estrogen, SERMs, and bisphosphonates.

### Estrogen Replacement Therapy

A recent meta-analysis of 22 trials of estrogen reported an overall 27% reduction in nonvertebral fractures (RR 0.73, 0.56–0.94).^126^ Several trials included in the meta-analysis, however, do not meet inclusion criteria for our review because they used unpublished data, did not verify fractures radiographically, included traumatic fractures, or included women who were hospitalized or had secondary causes of osteoporosis. Five randomized controlled trials of estrogen with vertebral or nonvertebral fracture outcomes met our inclusion criteria (Table 8).^127–131^

Table 8. Randomized Controlled Trials of Estrogen and SERMs with Fracture Outcomes

| | | Duration | Age | | Relative risk (95% CI) for fractures | | Quality
Author | Drug/dose | N | (years) | (years) | Population | Vertebral | Nonvertebral | Rating*
Lufkin, 1992^127^ | Cyclic estradiol transdermal patch (0.1 mg) with oral medroxyprogesterone (10 mg) or placebo. | 78 | 1 | 45–75 | 1 or more vertebral fractures; Mayo Clinic, Minnesota | 0.39 (0.16–0.95) | NA | Fair
Wimalawansa, 1998^128^ | Cyclic premarin (0.625 mg/day) with norgestrel (150 microgm/12 days each month) or placebo; all subjects received calcium and vitamin D. | 36 | 4 | Mean 65 | Established osteoporosis; attending metabolic bone disease outpatient clinics | HRT: 33.3/1,000 patient-yrs; calcium/vit D: 89.3/1,000 patient-yrs;No significant difference between groups | NA | Poor
| | | | Early postmenopause
Koulainen, 1998^129^ | 1. Sequential estradiol (2 mg/day) with cyproiterone acetate (1 mg/day); 2. Vit D (300IU/day); 3. HRT & vit D; 4. Placebo. | 464 | 4.3 | | No osteoporosis; a subgroup of the Kuopio Osteoporosis Study (n=13,100) based in Finland | NA | HRT alone: 0.29 (0.10–0.90); HRT & Vit D: 0.44 (0.17–1.15) | Fair
Mosekilde, 2000^130^ | Sequential estradiol (1–2) mg/day with norethisterone acetate (1 mg/day for 10 days each month; continuous estradiol (2 mg/day) if hysterectomy or non use. | 1006 | 5 | 45–52 | Postmenopausal Danish women recruited by mailed questionnaire. | 2.0 (0.62–06.49) | All:0.82 (0.53–1.29); forearm: 0.40 (0.16–1.01); other: 0.96 (0.57–1.64) | Poor
Cauley, 2001^131^ | Continuous combined conjugated equine estrogen (0.625 mg) with medroxyprogesterone (2.5 mg) or placebo. | 2763 | 4.1 | <80 (mean 67) | Heart and Estrogen/progestin Replacement Study (HERS); with coronary disease, intact uterus; fractures a secondary outcome. | 0.69 (0.3–1.4) | Any: 0.94 (0.8–1.2); hip: 1.09 (0.5–2.3); wrist: 1.01 (0.3–1.4); other: 0.91 (0.7–1.2) | Fair
Lufkin, 1998^135^ | Raloxifene (60 or 120 mg/day) or placebo; all received calcium and vitamin D. | 143 | 1 | 45–75 (mean 65) | At least 1 vertebral fracture and low BMD; Mayo Clinic, Minnesota and Arizona. | 1.15 (0.75–1.75) | 0.51 (0.12–2.16) | Good
Ettinger, 1999^134^ | Raloxifene (60 or 120 mg/day) or placebo; all received calcium and vitamin D. | 7705 | 3 | 31–80 (mean 67) | Multiple Outcomes of Raloxifene Evaluation (MORE); 25 countries; met WHO criteria for osteoporosis. | 0.59 (0.05–0.70) | 0.91 (0.79–1.06) | Good
Fisher, 1998^136^ | Tamoxifen (20 mg/day) or placebo. | 13,388 | 5 | 35 and over | National Surgical Adjuvant Breast and Bowel Project Breast Cancer Prevention Trial (P-1); high risk for breast cancer in US andCanada; fractures a secondary outcome. | 0.74 (0.41–1.32) | Hip: 0.55 (0.25–1.15); Colles' 0.61 (0.29–1.23) | Fair

* Harris, 2001^27^

Note: CI indicates confidence interval; SERMs, selective estrogen receptor modulators.

BMD indicates bone mass density;

A trial of 78 postmenopausal women age 47 to 75 years with one or more pre-existing vertebral fractures evaluated incident vertebral fractures.^127^ The treatment group was provided with a cyclic regimen of transdermal estrogen and progesterone for one year and was compared to an untreated placebo group. The estrogen group experienced 8 new vertebral fractures in 7 women, while the placebo group had 20 fractures in 12 women. Despite a lower vertebral fracture rate in the estrogen group (RR 0.39; CI 0.16–0.95), the number of women experiencing new vertebral fractures was not significantly different between groups. A smaller trial of 4 years duration comparing 18 women using a cyclic oral estrogen regimen to 18 women in a comparison group found no significant difference in vertebral fractures.^128^

Three trials reported nonvertebral fracture outcomes. A primary prevention trial enrolled a subgroup of a large prospective osteoporosis study based in Finland.^129^ In this study, 464 early postmenopausal women without osteoporosis were randomly assigned to one of four groups: cyclic oral estradiol with progestin, vitamin D alone, estradiol with progestin and vitamin D, or placebo. New, symptomatic, radiographically confirmed nonvertebral fractures were recorded during a mean 4.3 years of follow-up. The risk for fracture was significantly lower for the estrogen/progestin alone group (RR 0.29; CI 0.10–0.90), but not for the estrogen/progestin and vitamin D group, or the vitamin D alone group, compared to placebo when adjusted for baseline bone density and prior fractures. Another primary prevention trial randomized 1,006 early postmenopausal women (age 45 to 58 years) in Denmark to oral estradiol/norethisterone or placebo. After 5 years, the relative risk for all types of fractures was 0.82 (0.53–1.29), and for forearm fractures 0.40 (0.16–1.01).^130^

The Heart and Estrogen/progestin Replacement Study (HERS) is a secondary prevention trial of the effects of estrogen on cardiovascular outcomes.^132^ This study enrolled 2,763 postmenopausal women with pre-existing coronary disease under 80 years old (mean 66.7 years). A subgroup of women underwent bone densitometry, and 15% of them had osteoporosis. Fractures at various sites were secondary outcomes. The treatment group was given a continuous combined regimen of conjugated estrogen with medroxyprogesterone per day and compared with an equal-sized placebo group. After 4 years, this study found no difference between groups for all fractures combined, or hip, wrist, spine, or other types of fractures specifically.^131^

These trials did not meet USPSTF criteria to be ranked as good-quality studies because they did not assemble or maintain comparable groups,^130,^ ^131^ were not blinded,^129,^ ^130^ were small, ^127–129^ or used inappropriate analyses.^127,^ ^128^ The largest trial, HERS, did not monitor for asymptomatic incident vertebral fractures, potentially missing as many as 2/3 of vertebral fractures that would be diagnosed solely by radiographic morphometric criteria.^133^ These limitations in study design and generalizability led to inconclusive evidence about the effectiveness of estrogen in fracture prevention.

### Selective Estrogen Receptor Modulators

Two good-quality randomized controlled trials of raloxifene with fracture outcomes have been published (Table 8). The largest study, the Multiple Outcomes of Raloxifene Evaluation (MORE) study, included 7,705 postmenopausal women aged 31 to 80 years.^134^ These women met WHO criteria for osteoporosis based on low bone density or presence of vertebral fractures. Incident vertebral fractures were determined using radiographic criteria at the 24- and 36- month visits and at other times if new symptoms of vertebral fractures developed. Nonvertebral fractures were determined by interviewing subjects at 6-month visits.

After 3 years of treatment, women in the raloxifene group had a significantly reduced risk for vertebral fractures compared with women in the placebo group (RR 0.59; CI 0.50–0.70). The risk for nonvertebral fractures was not significantly reduced. A smaller trial of one-year duration also evaluated the effects of raloxifene but found no differences in fracture outcomes compared to placebo.^135^

Women enrolled in the National Surgical Adjuvant Breast and Bowel Project Breast Cancer Prevention Trial (P-1) of tamoxifen were also monitored for fractures, although this was a secondary outcome.^136^ In this study, 13,388 women were randomized to tamoxifen or placebo and followed for 5 years. Incident fractures of the hip, wrist, and spine were confirmed by x-rays. Relative risks for total fractures, hip, wrist, and spine were not significantly reduced.

### Bisphosphonates

A recent unpublished meta-analysis^28^ of 11 randomized trials^137–147^ including 12,855 women found that alendronate significantly reduced vertebral fractures (RR 0.52, 95% CI 0.43–0.65), forearm fractures (RR 0.48, 95% CI 0.29–0.78), and all nonvertebral fractures (RR 0.50, 95% CI 0.38–0.69). There was a non-significant trend toward reduction in hip fractures.

We evaluated data from these trials to determine if women who have a similar overall risk of fracture, but different bone densities, have a similar benefit from treatment. The published studies are summarized in Table 9. This question is clinically important because the lack of accepted criteria for initiating treatment remains a problem. The meta-analysis review found no relation between the average bone density and the effect size of alendronate, but the researchers did not have individual patient data. None of the studies stratified patients by overall risk, or published subgroup analyses of the effect size in relation to overall fracture risk.

Table 9. Randomized Controlled Trials of Alendronate with Fracture Outcomes

| Duration | Age
Author | (years) | (years) | Population | Population | Exclusion Criteria* | Lost to Followup | Quality Rating†
Adami, 1995^138^ | 2 | 48–76 | 9 Italian Centers, T-score< -2 (0.67g/cm2); 5% vertebral fractures | 9 Italian Centers, T-score< -2 (0.67g/cm2); 5% vertebral fracture | Narrow | 32/211 (15.2 %) | Fair to Good
Black, 1996^137^ | 3 | 55–81 | 11 U.S. cities, BMD<0.68 g/cm2; no previous vertebral fractures | 11 U.S. cities, BMD<0.68 g/cm2; no previous vertebral fracture | Broad (medical illness, dyspepsia, etc) | 81/2027 (4%) | Good
Bone, 1997^139^ | 2 | >60 | 15 U.S. sites, BMD <0.84 g/cm2; average 20 yrs since menopause; 30.7% vertebral fractures | 15 US sites, BMD < .84 g/cm2, average 20 years since menopause; 30.7% vertebral fractures | Broad (medical illness, NSAIDs, GI drugs) | 19/359 (5.3%) | Fair to Good
Chesnut, 1995^140^ | 2 | 42–75 (avg. 63) | 7 centers, spine BMD<0.88, average hip BMD 0.7; at least 5 years since menopause | 7 centers, LS BMD<.88, average hip BMD .7; at least 5 years since menopause | Broad | 26/157 (16.6%) | Fair
Cummings, 1998^146^ | 4 | 55–81 | 11 U.S. cities, BMD<0.68 g/cm2 (aver. 0.59); no previous vertebral fractures | 11 U.S. cities, BMD<0.68 g/cm2 (aver. 0.59), no previous vertebral fracture | Broad (medical illness, dyspepsia) | 179/4432 (4%) | Good
Greenspan, 1998^144^ | 2.5 | Over 65 | 1 Boston center, no BMD entry criteria | Over 65 | Narrow (“good health”) | 33/120 (27.5%) | Fair

† Harris, 2001^27^

* In general, “narrow” criteria excluded estrogen users and patients with illnesses affecting bone metabolism

GI= Gastrointestinal

BMI= Bone mass density

NSAID= Nonsteroidal anti-inflammatory drug

The Fracture Intervention Trial (FIT) of alendronate was conducted with 2 different groups of participants and provides some information about levels of risk. One group (FIT-I) included a higher-risk group of 2,027 women who had T-scores of -1.6 or lower and pre-existing vertebral fractures.^137^ The 3-year risk of hip fracture in the placebo group was 2.2% (1.1% in the alendronate group, relative hazard 0.49 [0.23–0.99]), and the 3-year risk of any clinical fracture was 18.2% (13.6% in the alendronate group, RH 0.72 [0.58–0.90]). Within FIT-I, the highest-risk women—those who were oldest, had the most vertebral fractures at baseline, or had the lowest bone density—had the largest absolute benefit from treatment.^148^ The numbers needed to treat with alendronate for 5 years to prevent one new vertebral fracture were 8 for women aged 75 years or older compared with 9 for women younger than 75 years, and 4 for women with 2 or more existing vertebral fractures compared with 16 for women with one existing vertebral fracture.

A second study from FIT (FIT-II) included a lower-risk sample of 4,432 women who also had T-scores of -1.6 or lower, but did not have pre-existing vertebral fractures.^149^ The 4-year incidences of hip fracture (1.1%) and any clinical fractures (14.1%) in the placebo group were fewer than those of the women in the placebo group of the FIT-I study. In FIT-II, only the subgroup of treated patients (n=1,627) who had a T-score under -2.5 had a significant risk reduction for all clinical fractures, from 19.6% to 13.1% (RR 0.64; 0.50–0.82). There was no risk reduction for fractures for patients who had T-scores between -1.6 and -2.5.

The results from FIT suggest that women with more risk factors for fracture, such as those who are older, have very low bone density, or have pre-existing vertebral fractures, have the greatest absolute benefit with treatment. However, FIT did not examine other nonskeletal risk factors, such as psychomotor impairment, poor gait, and other factors that increase the risk of falling.

One recent, fair-quality randomized trial examined the effect of these factors on the benefit of treatment with another bisphosphonate, risedronate.^150^ Risedronate had no effect on hip fracture rates among women 80 years of age or older who had one or more risk factors for falls. These women did not necessarily have osteoporosis. As the authors note, many of these women had only one risk factor, so the result does not exclude the possibility that women who have multiple risk factors for falls would benefit from treatment. In the same report, in women aged 70 to 79 with severe osteoporosis (T score < -3 or worse), risedronate reduced hip fractures by 40% (0.6; CI 0.4–0.9; NNT 77). Many of these women had risk factors for falls, but the report did not say whether risedronate was more or less effective for them than for women who had the same degree of osteoporosis but did not have risk factors.

### Generalizability of Randomized Trials

For the results of trials to be applicable to a screening program, the trials must include patients who would be identified by screening the general population. We examined recruitment and eligibility characteristics of the 11 randomized trials of alendronate to assess whether selection biases or other biases might affect their generalizability. Overall, the trials included relatively healthy women who were not using estrogen. Except for the 2 trials of early postmenopausal women who were not osteoporotic, most of the subjects were older than 65 years of age.

FIT-II is the largest study and provided the most detailed description of recruitment and results. In FIT-II, recruitment of the sample of 4,432 women began with a query that was mailed to over a million women selected from the general population in 11 cities. Women who had medical problems, including dyspepsia, or who used estrogen were excluded. Fifty-four thousand (about 5.4%) responded by telephone, of whom 26,137 (52%) had a screening visit. A higher than expected proportion of these (65%) had sufficiently low bone density to enroll in the study. Of these, 57% were classified as “ineligible, did not wish to continue, or screened after recruitment to this arm”; it is not clear from this description how many patients did not meet the eligibility criteria. In addition, an unspecified number of patients (up to 28,000) were found to be ineligible at the initial stage of recruitment. The demographic characteristics of eligible and screened, but excluded, subjects were not reported. None of the other randomized trials disclosed any details of how the sample was recruited or how many respondents were found to be ineligible before randomization.

In other clinical areas, the results of industry-sponsored trials were significantly more favorable to newer therapies than trials funded by nonprofit organizations.^151,^ ^152^ Because all 11 trials of alendronate were funded wholly or in part by the maker, we were unable to assess the influence of sponsorship on effect size. If effectiveness of treatments is smaller than estimated in these trials, the efficiency of screening to identify candidates for treatment will be reduced and the number needed to screen will increase.

## Arrow 6: What are the harms of treatment?

Potential risks of estrogen use include thromboembolic events,^153^ cholecystititis,^154^ endometrial cancer in those with a uterus taking unopposed estrogen,^155^ and possibly ovarian cancer,^156^ breast cancer (particularly in long-term users),^157^ and thromboembolic stroke.^158^ Some women may experience effects such as breast tenderness, vaginal bleeding, and mood changes, among others. Both raloxifene and tamoxifen are associated with thromboembolic events, leg cramps, and hot flashes.^159^

Overall, gastrointestinal side effects occur in about 25% of patients taking alendronate, but these rates were usually not higher, or only a little higher, than those for placebo. Higher rates have been observed among Medicare enrollees taking alendronate.^160^ In randomized trials, rates of ulcers are higher for patients taking alendronate; in the FIT II trial, 2.2% of alendronate patients developed ulcer disease, versus 1.2% in the placebo group (p<0.05). The long-term adverse effects of alendronate are unknown.