# Methods

## Literature Search Strategy

Relevant studies were identified from multiple searches of MEDLINE (1966 to May 2001), HealthSTAR (1975 to May 2001), and Cochrane databases, reference lists of systematic reviews, and experts. The search strategy is described in Appendix 1. We reviewed a set of Cochrane meta-analyses of treatment trials presented at the National Institutes of Health Consensus Development Conference on Osteoporosis in March 2000.^28^ In addition, we sent letters to manufacturers of bone measurement devices requesting additional information about the performance of their instruments, but we received no new data. This report was reviewed by 6 content reviewers.

## Inclusion/Exclusion Criteria

Two reviewers read each abstract to determine its eligibility. We included English-language abstracts that had original data about postmenopausal women and osteoporosis and that addressed screening, or the effectiveness of risk factor assessment, bone measurement testing, or treatment. Postmenopausal women were those who had experienced surgical or natural menopause, regardless of age. Women with pre-existing atraumatic fractures were not considered in the screening population because they already meet the WHO definition of osteoporosis. We did not include studies of primary prevention of osteoporosis such as the role of nutrition, calcium consumption, and physical activity. We did not review known secondary causes of osteoporosis such as corticosteroid use and certain chronic diseases because these are beyond the scope of population screening. We also did not systematically review data describing the link between fractures and morbidity and mortality because this relationship has been previously established.

For studies of prediction, we selected articles if they reported the relationship between risk factor assessment methods or bone measurement tests and bone density, bone loss, or fractures. To address treatment issues, we reviewed studies of hormone replacement therapy, selective estrogen receptor modulators (SERMs), and bisphosphonates. We focused on randomized controlled trials of current therapies reporting radiographically verified, nontraumatic fracture outcomes, because fractures are a stronger measure of effectiveness than bone density. Investigators read the full-text version of the retrieved papers and re-applied the initial eligibility criteria. We excluded articles if they did not provide sufficient information to determine the methods for selecting subjects and for analyzing data.

## Size of Literature Reviewed

The initial literature search included 6,194 titles and abstracts about risk factors. Of these, 230 were reviewed, and 18 studies about risk factor assessment were included. For bone measurement tests, 2,125 titles and abstracts were initially found, and 85 studies were reviewed. Studies of treatment were initially identified from a Cochrane meta-analysis^28^ supplemented by MEDLINE searches for alendronate, risedronate, estrogen, and raloxifene. Periodic updates for all topics continued through May 2001.

## Literature Synthesis

To assess the internal validity of individual studies, we applied a set of criteria developed by the current U.S. Preventive Services Task Force (Appendix 2).^27^

We created an outcomes table to summarize the number of hip and vertebral fractures prevented based on age-specific prevalence rates, and treatment effects obtained from results of the reviewed studies. We conducted a sensitivity analysis to determine the influence of risk factors on the number needed to screen.