# Introduction

Half of all postmenopausal women will have an osteoporosis-related fracture during their lives, including one-quarter who will develop a vertebral deformity,^1^ and 15% who will suffer a hip fracture.^2^ As early as 1975, it was acknowledged that bone density measurements were related to future fracture risk. In the 1990s, the magnitude of this risk in relation to age and bone density was carefully measured in several well-designed longitudinal studies. Recently, data indicating that newer therapies can prevent fractures in asymptomatic postmenopausal women with osteoporosis have become available as well.

Despite the high prevalence of osteoporosis and the impact of fractures on mortality, independence, and quality of life, whether it is appropriate to screen asymptomatic postmenopausal women is unclear. Recent systematic reviews and guidelines disagree about which women should be screened and when (Table 1).^3–11^ This disagreement reflects, in part, gaps in the evidence. For example, most guidelines recommend using risk factors to select patients for bone density testing, but because of inadequate data there is no consensus on what risk factors to use.

Table 1. Recent Systematic Reviews of Osteoporosis

Publication | Year | Organization Producing Report | Conclusions
| | | Risk factors | Choice of test | Monitoring | Use of markers | Cost-effectiveness
Bone Density Measurement - A Systematic Review3 | 1997 | Swedish Council on Technology Assessment in Health Care | Must consider risk factors other than bone density alone to make decisions about testing or treatment. | BMD in hip or spine cannot be reliably estimated from measurements in arm or heel. | Measurements at intervals <2 years are unnecessary. | No documentation that repeated measurements of markers influence treatment in a way that improves long-term clinical outcomes.
Effectiveness of Bone Density Measurement and Associated Treaments for Prevention of Fractures4 | 1996 | International Network of Agencies for Health Technology Assessment | | The precision and accuracy of all BMD tests in community settings are unknown. Accuracy of ultrasound still not proven. | BMD would require minimum followup of 1 to 1.5 years to detect bone loss of 2 to 3%.
Bone Mineral Density Testing: Does the Evidence Support its Selective Use in Well Women?5 | 1997 | British Columbia Office of Health Technology Assessment | Currently there are no validated risk assessment tools to select patients for BMD testing. In the general population, clinical assessment was no worse than BMD measurement in assessment of fracture risk. | Result of BMD test by any current technology is an unsuitable measure upon which to base clinical decisions. | | | Available economic evaluations are not adequate evidence that BMD testing is more cost-effective than universal hormone therapy or no intervention.
Osteoporosis: Review of the Evidence for Prevention, Diagnosis, and Treatment and Cost-effectiveness Analysis6 | 1998 | National Osteoporosis Foundation | Appropriateness of measuring BMD depends on fracture risk, determined by age and other risk factors, and treatment being considered. | Given the better predictive value of hip measurements for hip fractures, hip DXA should be the primary measurement. | The longer the interval between measurements, the more precise the estimate of changes in bone mass; effect of monitoring on treatment is unknown. | Biochemical markers are promising but their role in patient management is not yet known.
Quantitative Ultrasound for Bone Density Measurement7 | 1998 | Alberta Heritage Foundation for Medical Research | | Quantitative calcaneal ultrasound is a promising diagnostic technology, but its role in osteoporosis diagnosis is unclear. Good evidence that ultrasound can identify increased risk of fracture in populations but not individuals.
Selective Testing with Bone Density Measurement8 | 1999 | Alberta Heritage Foundation for Medical Research | There is potential for selective use of BMD in association with appraisal of other risk factors. Assessment protocols for such an approach have promise as a useful tool for selecting whom to test. Advice on treatment options should consider evidence of efficacy and effectiveness in terms of absolute reduction in risk of fracture, long term compliance, and adverse effects. | Substantial uncertainty with the performance of BMD in correctly classifying an individual as osteoporotic. Ultrasound is less precise than DXA. | Minimum acceptable interval between measurements may be as long as 2 years.
Osteoporosis: Clinical Guidelines for Prevention and Treatment9 | 1999 | Royal College of Physicians | Recommends selective testing in women with risk factors (based not on evidence but on expert opinion). | DXA at the hip is preferred because of higher predictive value for fracture risk. | Optimal use of BMD measurements in monitoring response to treatment is uncertain, recommend future research. | Until biochemical markers become more widely established and supported by evidence, their use in clinical practice will remain limited. | The cost-effectiveness of BMD measurements improves as the expense of the therapy goes up.
Ultrasonography of the Heel for Diagnostic Osteoporosis and Selecting Patients for Pharmacologic Treatment10 | 1999 | Blue Cross and Blue Shield Association | | Use of ultrasound to direct treatment may result in a substantially smaller health outcome benefit compared to DXA. 43 to 76% of patients benefiting from treatment would be identified by ultrasound (sensitivity); 75 to 90% of patients not benefiting by treatment would be identified by ultrasound (specificity).
Consensus Statement on Prevention and Treatment of Osteoporosis11 | 1999 | Israel Center for Technology Assessment in Health Care/Israel Ministry of Health/Israel Medical Association | Physician's responsibility to estimate risk of osteoporosis and fractures and to consider performing additional tests; based on some risk factors, report recommends BMD every 2 years | Recommends DXA done at facilities with quality control and following regulations on operations and interpretation of results; additional technologies to be considered if efficiency proven compared to DXA. | Calls for publicly funded BMD in women over 65 every 5 years; in postmenopausal women over 50 every 2 years if certain risk factors present; in those with disease entailing increased risk of osteoporosis, no limit on age or frequency of test.

Note: BMD indicates bone mineral density; DXA, dual-energy X-ray absorptiometry

As part of the U.S. Preventive Services Task Force update of its recommendations,^12^ we examined evidence on the benefits and harms of screening asymptomatic postmenopausal women for osteoporosis. Specifically, we addressed the role of risk factors in identifying high-risk women, techniques of bone measurements to identify risk of fractures, effectiveness of treatment in reducing risk for fractures, and harms of screening and treatment.

## Burden of Suffering/Epidemiology

Osteoporosis affects a large proportion of American women over the age of 50. The third National Health and Nutrition Examination Survey (NHANES III) estimated that 12 million (41%) white women over age 50 met WHO criterion for osteopenia and 5 million (15%) for osteoporosis (Table 2). The prevalence of osteoporosis in Mexican-American women is similar to white women. While rates in black women are approximately half that of the other groups, they are still substantial (8%). Including all races, an estimated 14 million women over age 50 have osteopenia and over 5 million have osteoporosis.^13^

Table 2. Prevalence of Low Femoral Neck Bone Density in U.S. Women Over Age 50 (DXA)

Race | Osteopenia (-2.5<T-score<-1.0) | | Osteoporosis (T-score < -2.5)
| Prevalence (%)* | Millions** | Prevalence (%)* | Millions**
All | 40 | 14 | 15 | 5
NHW | 41 | 12 | 15 | 5
NHB | 28 | 0.9 | 8 | 0.3
MA | 38 | 0.3 | 16 | 0.1

* Age adjusted to 1980 U.S. Census

** Undercount adjusted estimates from March 1990 & 1993 Current Population Surveys

Note: Data taken from NHANES III Looker (1998).^13^

DXA indicates dual-energy X-ray Absorptiometry; MA, Mexican American; NHB, non-Hispanic black; NHW, non-Hispanic white.

The prevalence of osteoporosis increases with age for all sites measured. By the WHO definition (low bone density at the hip, spine, or forearm), up to 70% of women over age 80 have osteoporosis (Table 3). Percentages almost double across all sites during the eighth decade and again during the ninth.^14^

Table 3. Osteoporosis Prevalence (%) in White Women in the U.S. Over Age 50 by Decade (DPA and SPA)*

Age | Spine | Hip | Wrist | At spine, hip, or wrist
50–59 | 7.6 | 3.9 | 3.7 | 14.8
60–69 | 11.8 | 8.0 | 11.8 | 21.6
70–79 | 25.0 | 24.5 | 23.1 | 38.5
≥80 | 32.0 | 47.5 | 50.0 | 70.0
All | 16.5 | 16.2 | 17.4 | 30.3

* Data taken from Melton (1995).^14^

Note: DPA indicates dual photon absorptiometry; SPA, single photon absorptiometry.

Using data from the 5% U.S. Medicare sample, the actuarial (life table) risk of a 65-year-old white woman sustaining a fracture by age 90 is 16% for the hip, 9% for distal forearm, and 5% for proximal humerus.^2^ Age is an important factor in the relationship between bone density and the absolute risk of fracture. An increase in age of 13 years increases the risk of hip fracture by the same amount as a one standard deviation decrease in bone density. As illustrated in Table 4, the 5-year risk of hip fracture for a 90-year-old woman with a T-score of -1.0 is 2 %, equivalent to that of a 70-year-old woman with a T-score of -2.0.^6^ Older women have a much higher fracture rate than younger women with the same bone density because of increasing risk from other factors such as bone quality and tendency to fall.^15^ Hip fractures are associated with high rates of mortality and loss of independence.^16,^ ^17^

Table 4. 5-Year Hip Fracture Rates for Women Without Previous Hip Fracture by Age*

| T-score
Age | -5 | -4 | -3 | -2 | -1 | 0 | 1 | 2
50 yrs | | | 0.024 | 0.0095 | 0.0038 | 0.0015 | 0.0006 | 0.00023
60 yrs | | 0.069 | 0.029 | 0.011 | 0.0047 | 0.0018 | 0.0007 | 0.00025
70 yrs | | 0.127 | 0.055 | 0.023 | 0.0096 | 0.0039 | 0.001
80 yrs | 0.35 | 0.2 | 0.09 | 0.042 | 0.018 | 0.007 | 0.0028
90 yrs | 0.29 | 0.19 | 0.097 | 0.046 | 0.02 | 0.006
* Data derived from decision model presented in the National Osteoporosis Foundation Report (1998)^6^
50 yrs | | | 0.024 | 0.0095 | 0.0038 | 0.0015 | 0.0006 | 0.00023
60 yrs | | 0.069 | 0.029 | 0.011 | 0.0047 | 0.0018 | 0.0007 | 0.00025
70 yrs | | 0.127 | 0.055 | 0.023 | 0.0096 | 0.0039 | 0.001
80 yrs | 0.35 | 0.2 | 0.09 | 0.042 | 0.018 | 0.007 | 0.0028
90 yrs | 0.29 | 0.19 | 0.097 | 0.046 | 0.02 | 0.006
* Data derived from David Eddy Model from the National Osteoporosis Foundation Report 1998

Sixteen percent of postmenopausal women have osteoporosis of the lumbar spine.^14^ Five percent of 50-year-old white women and 25% of 80-year-old women have had at least one vertebral fracture.^1^ Although many vertebral fractures are only incidentally detected on x-rays, some cause severe pain leading to 150,000 hospital admissions per year in those over age 65, 161,000 physician office visits, and more than 5 million days of restricted activity in those age 45 or older.^18^ The functional impact of vertebral fracture on quality of life can be substantial.^19^

The burden of osteoporosis extends beyond the consequences of fracture. The process of diagnosis and treatment can also affect quality of life. An osteoporosis-targeted quality of life questionnaire was developed to assess the impact of the disease among women in the community, specifically focusing on physical difficulty with activities of daily living, necessary adaptations, and fears.^20^ Using this questionnaire, women with osteoporosis indicated significantly more difficulties with routine daily activities compared to women with osteopenia or normal bone density.^21^ Also, women who had osteoporosis had significantly more fears than women who had normal bone density. It is not clear how comorbidities influence these differences in quality of life.

## Health Care Interventions

Low bone density has been used to predict risk for fractures as well as to diagnose osteoporosis. Osteoporosis has been defined as “a systemic skeletal disease characterized by low bone mass and microarchitectural deterioration of bone tissue, leading to enhanced bone fragility and a consequent increase in fracture risk.”^22,^ ^23^ This definition emphasizes that, in addition to bone mass, the structure of bone is also an important factor in the mechanism of fractures. In practice, however, the diagnosis is most often made in a patient who has had an osteoporotic fracture or who has been found to have low bone density.

In 1994, a World Health Organization (WHO) working group^24^ noted that there was a wide range in estimates of the prevalence of osteoporosis (2.5% to 95%), depending on what value of bone density was classified as abnormal. Therefore, while it endorsed the earlier definition of osteoporosis, the working group proposed that, in epidemiologic studies, osteoporosis should be diagnosed when bone mineral density (BMD) is 2.5 standard deviations below the mean for healthy young adult women at the spine, hip, or wrist, or when a history of an atraumatic fracture is present.^25^

The number of standard deviation units above or below the young healthy mean is called the T-score. For example, if a 60-year-old woman has a T-score of minus one, her bone density is one standard deviation below the average bone density of healthy women in their twenties. A Z-score is the number of standard deviation units above or below the mean for one's own age group. The woman in the example has a Z-score of zero, meaning that a T-score of minus one is average for a 60-year-old woman.

Ideally, the value of bone density used to define the disease osteoporosis would be selected in order to identify a group of patients known to have a high risk of complications (fractures) and likely to benefit from identification and treatment. The WHO working group chose a T-score of minus 2.5 or less as the criterion. By screening 3 sites, twice as many women would be diagnosed with osteoporosis than by screening at the hip alone. The working group also proposed that low bone mass or osteopenia be diagnosed when bone density was 1.0 to 2.5 standard deviations below the young healthy mean. These diagnostic criteria have been incorporated into bone density reports and in the inclusion criteria for recent randomized controlled trials of therapies for osteoporosis. Although they were not intended for use as a clinical treatment threshold, they are being used as such.

Recently, several participants in the WHO working group recommended that the diagnosis of osteoporosis should be based only on the T-score obtained at the hip measured by dual-energy x-ray absorptiometry (DXA).^26^ They proposed that measurements at other sites and with other technologies may be useful for assessing risk for fracture, but should not be used for diagnosis of osteoporosis.

## Prior Recommendations

The Second Task Force stated that there was insufficient evidence to recommend for or against routine screening for osteoporosis with bone densitometry in postmenopausal women.^12^ The Task Force recommended that all postmenopausal women should be counseled about hormone prophylaxis and be advised on the importance of modifying certain risk factors such as smoking, exercise, and calcium intake. They felt that screening may be appropriate for high-risk women considering treatment decisions.

## Analytic Framework and Key Questions

The analytic framework (Figure 1) depicts a screening strategy that includes an assessment of clinical risk factors, then measurement of bone density on a high-risk group.^27^ We addressed these key questions for the target population of asymptomatic postmenopausal women:

Figure 1. Osteoporosis Screening Analytic Framework

Arrow 1: Does screening using risk factor assessment and/or bone density testing reduce fractures?

Arrow 2: Does risk factor assessment accurately identify women who may benefit from bone density testing?

Arrow 3: Do bone density measurements accurately identify women who may benefit from treatment?

Arrow 4: What are the harms of screening?

Arrow 5: Does treatment reduce the risk of fractures in women identified by screening?

Arrow 6: What are the harms of treatment?

It is important to note that our review has a limited perspective: that of selecting asymptomatic postmenopausal women from the general population for testing and treatment. Many experts would argue that public health efforts and provider attention should be focused on adolescents and should promote measures to increase peak bone mass. Peak bone mass, which is achieved in a woman's twenties, is an important determinant of bone strength throughout life. This review does not address primary prevention of osteoporosis or the impact screening can have relative to the potential impact of primary prevention of osteoporosis.