# Appendix 1. Search Strategies for Individual Topics

## Risk Factors

1. exp osteoporosis
  osteoporosis, postmenopausal
2. bone density
3. 1 or 2
4. exp risk
  logistic models risk assessment
  risk factors
5. 3 and 4
6. exp transplantation
  cell transplantation transplantation, autologous
  organ transplantation transplantation, heterologous
  replantation transplantation, heterotopic
  tissue transplantation transplantation, homologous
7. exp kidney failure
  kidney failure, acute diabetes insipidus, nephrogenic
  kidney failure, chronic
8. su.fs. (Surgery as a subheading anywhere in the article)
9. athletic injuries
10. exp sports
  baseball basketball bicycling
  boxing golf football
  gymnastics hockey mountaineering
  racquetball running martial arts
  skating skiing track and field
  soccer swimming weight lifting
  walking wrestling
11. exp fractures/dt,su,th (limited to surgery and other therapies)
  femoral fractures fractures, closed
  fractures, comminuted fractures, malunited
  fractures, open fractures, spontaneous
  fractures, stress fractures, ununited
  humeral fractures radius fractures
  rib fractures shoulder fractures
  skull fractures spinal fractures
  tibial fractures ulna fractures
12. orthopedic$.mp. (As a textword anywhere)
13. 6 or 7 or 8 or 9 or 10 or 11 or 12
14. 5 [underlined: not] 13 (statements 6 through 12 were excluded from the study)
15. limit 13 to female
16. limit 14 to human
17. limit 15 to english language
18. looked at english abstracts of foreign articles
19. exp fractures or exp osteoporosis or bone density
20. exp risk (terms as in 4)
21. 19 and 20
22. exp cohort studies
  longitudional studies
  follow-up studies
  prospective studies
23. meta-analysis
24. exp case control studies
  retrospective studies
25. predictive value of tests
26. evidence-based medicine
27. 22 or 23 or 24 or 25 or 26
28. 21 and 27
29. limit 28 to human
30. limit 29 to english language

## Bone Density and Quantitative Ultrasound Testing

1. exp osteoporosis
  osteoporosis, postmenopausal
2. bone density
3. 1 or 2
4. densitometry, x-ray
5. exp ultrasonography
  echocardiography ultrasonography, doppler
  echoencephalography ultrasonography, interventional
  endosonography ultrasonography, mammary
6. calcaneous/us (us = ultrasonics)
7. (dxa or sxa or bua or qct or qus or mxa or mrx or ra or dip or sos or ubps or spa or dpa).tw.
8. exp osteoporosis/us (us = ultrasonics)
9. 4 or 5 or 6 or 7 or 8
10. 3 and 9
11. limit 10 to human
12. limit 11 to english language
13. looked at english abstracts of foreign articles

## Hormone Replacement Therapy

1. exp hormone replacement therapy
  estrogen replacement therapy
2. hormone replacement.tw. (text word taken from title and abstract of article)
3. estrogen replacement.tw.
4. exp estrogens/ad,tu (ad = administration & dosage; tu = therapeutic use)
  equilenin estrogens, catechol
  equilin estrogens, conjugated
  estradiol estrogens, non-steroidal
  estriol estrone
5. exp estrogens, synthetic/ad,tu
  estrogens, non-steroidal epimestrol
  chlorotrianisene ethinyl estradiol
  coumestrol mestranol
  dienestrol quinestrol
  diethylstilbestrol hexestrol
  zearalenone zeranol
6. 1 or 2 or 3 or 4 or 5
7. exp osteoporosis
  osteoporosis, postmenopausal
8. exp fractures
  femoral fractures fractures, closed
  fractures, comminuted fractures, malunited
  fractures, open fractures, spontaneous
  fractures, stress fractures, ununited
  humeral fractures radius fractures
  rib fractures shoulder fractures
  skull fractures spinal fractures
  tibial fractures ulna fractures
9. fracture$.tw.
10. bone density
11. 7 or 8 or 9 or 10
12. 6 and 11
13. limit 12 to human
14. limit 13 to english language
15. looked at english abstracts of foreign articles

## Randomized Controlled Trials of Estrogen and SERMs

### Estrogen

1. exp hormone replacement therapy
  estrogen replacement therapy
2. hormone replacement.tw. (text word taken from title and abstract of article)
3. estrogen replacement.tw.
4. exp estrogens/ad,tu (ad = administration & dosage; tu = therapeutic use)
  equilenin estrogens, catechol
  equilin estrogens, conjugated
  estradiol estrogens, non-steroidal
  estriol estrone
5. exp estrogens, synthetic/ad,tu
  estrogens, non-steroidal epimestrol
  chlorotrianisene ethinyl estradiol
  coumestrol mestranol
  dienestrol quinestrol
  diethylstilbestrol hexestrol
  zearalenone zeranol
6. 1 or 2 or 3 or 4 or 5
7. limit 6 to randomized controlled trials (check for document type)
8. randomized controlled trials
9. randomized.tw.
10. 8 or 9
11. 6 and 10
12. 7 or 11
13. limit 12 to human
14. limit 13 to english language
15. looked at english abstracts of foreign articles

### Tamoxifen and raloxifene

1. (tamoxifen or raloxifene).mp.
2. Bone density/ or “bone density”.mp
3. exp osteoporosis/ or “osteoporosis”.mp
4. exp fractures/ or fracture$.mp.
5. exp hormone replacement therapy
6. estrogen replacement.mp.
7. 2 or 3 or 4 or 5 or 6
8. 1 and 7
9. limit 8 to (human and english language)
10. exp breast neoplasms/
11. 9 not 10
12. from 11 keep 1–145