# References

1 Moyer VA. Primary care interventions to prevent child maltreatment: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2013 Aug 20;159(4):289–95. doi: 10.7326/0003-4819-159-4-201308200-00667. PMID: 23752681.23752681
2 Centers for Disease Control and Prevention. Intimate Partner Violence: Definitions. Atlanta, GA: Centers for Disease Control and Prevention; 2015. http://www.cdc.gov/violenceprevention/intimatepartnerviolence/definitions.html. Accessed April 5, 2016.
3 Breiding MJ, Basile KC, Smith SG, . Intimate Partner Violence Surveillance: Uniform Definitions and Recommended Data Elements, Version 2.0. Atlanta, GA: National Center for Injury Prevention and Control, Centers for Disease Control and Prevention; 2015.
4 Hall JE, Karch DL, Crosby AE. Elder Abuse Surveillance: Uniform Definitions and Recommended Core Data Elements For Use In Elder Abuse Surveillance, Version 1.0. Atlanta, GA: National Center for Injury Prevention and Control, Centers for Disease Control and Prevention; 2016. http://www.cdc.gov/violenceprevention/pdf/ea_book_revised_2016.pdf.
5 Florida Department of Children and Families. Adult Services Program Office, Comparison of Definitions: Florida Statutes 415 and 825. Tallahassee, FL: Florida Department of Children and Families; 2007. www.dcf.state.fl.us/initiatives/apspanel/docs/comparisonOfDefinitions.doc. Accessed April 17, 2012.
6 Teaster PB, Dugar TA, Mendiono MS, . The 2004 Survey of State Adult Protective Services: Abuse of Vulnerable Adults 18 Years of Age and Older The National Committee for the Prevention of Elder Abuse and The National Adult Protective Services Association. Washington, DC: 2007. http://www.ncea.aoa.gov/Resources/Publication/docs/APS_2004NCEASurvey.pdf
7 Sumner SA, Mercy JA, Dahlberg LL, . Violence in the United States: status, challenges, and opportunities. JAMA. 2015 Aug 4;314(5):478–88. doi: 10.1001/jama.2015.8371. PMID: 26241599.26241599
8 Hien D, Ruglass L. Interpersonal partner violence and women in the United States: an overview of prevalence rates, psychiatric correlates and consequences and barriers to help seeking. Int J Law Psychiatry. 2009 Jan-Feb;32(1):48–55. doi: 10.1016/j.ijlp.2008.11.003. PMID: 19101036.19101036
9 Smith SG, Zhang X, Basile KC, . The National Intimate Partner and Sexual Violence Survey (NISVS): 2015 Data Brief. Atlanta, GA: National Center for Injury Prevention and Control, Centers for Disease Control and Prevention; 2018.
10 Breiding MJ, Smith SG, Basile KC, . Prevalence and characteristics of sexual violence, stalking, and intimate partner violence victimization-national intimate partner and sexual violence survey, United States, 2011. MMWR Surveill Summ. 2014 Sep 5;63(8):1–18. doi: [pii]. PMID: 25188037.25188037
11 Breiding MJ, J. C, Black MC. Intimate Partner Violence in the United States—2010. Atlanta, GA: National Center for Injury Prevention and Control, Centers for Disease Control and Prevention; 2014.
12 Kann L, McManus T, Harris WA, . Youth Risk Behavior Surveillance - United States, 2015. MMWR Surveill Summ. 2016 Jun 10;65(6):1–174. doi: 10.15585/mmwr.ss6506a1. PMID: 27280474.27280474
13 U.S. Government Accountability Office. Elder Justice: Stronger Federal Leadership Could Enhance National Response to Elder Abuse. Washington, DC: U.S. Government Accountability Office; 2011. http://www.gao.gov/new.items/d11208.pdf
14 Laumann EO, Leitsch SA, Waite LJ. Elder mistreatment in the United States: prevalence estimates from a nationally representative study. J Gerontol B Psychol Sci Soc Sci. 2008 Jul;63(4):S248–S54. PMID: 18689774.18689774
15 Acierno R, Hernandez MA, Amstadter AB, . Prevalence and correlates of emotional, physical, sexual, and financial abuse and potential neglect in the United States: the National Elder Mistreatment Study. Am J Public Health. 2010 Feb;100(2):292–7. doi: 10.2105/ajph.2009.163089. PMID: 20019303.20019303
16 Teaster PB, Dugar TA, Otto JM, . The 2004 survey of state protective services: abuse of adults 60 years of age and older. Washington, DC: National Center on Elder Abuse; 2006.
17 Casteel C, Martin SL, Smith JB, . National study of physical and sexual assault among women with disabilities. Inj Prev. 2008 Apr;14(2):87–90. doi: 10.1136/ip.2007.016451. PMID: 18388227.18388227
18 Haydon AA, McRee AL, Tucker Halpern C. Unwanted sex among young adults in the United States: the role of physical disability and cognitive performance. J Interpers Violence. 2011 Nov;26(17):3476–93. doi: 10.1177/0886260511403756. PMID: 21602209.21602209
19 Centers for Disease Control and Prevention. Intimate Partner Violence: Consequences. Atlanta, GA: Centers for Disease Control and Prevention; 2015. http://www.cdc.gov/violenceprevention/intimatepartnerviolence/consequences.html. Accessed April 5, 2016.
20 Centers for Disease Control and Prevention. Costs of intimate partner violence against women in the United States. Atlanta, GA: CDC, National Center for Injury Prevention and Control; 2003.
21 Cannell MB, Weitlauf JC, Garcia L, . Cross-sectional and longitudinal risk of physical impairment in a cohort of postmenopausal women who experience physical and verbal abuse. BMC Womens Health. 2015;15:98. doi: 10.1186/s12905-015-0258-2. PMID: 26554450.26554450
22 Baker MW, LaCroix AZ, Wu C, . Mortality risk associated with physical and verbal abuse in women aged 50 to 79. J Am Geriatr Soc. 2009 Oct;57(10):1799–809. doi: 10.1111/j.1532-5415.2009.02429.x. PMID: 19682130.19682130
23 Li Y, Marshall CM, Rees HC, . Intimate partner violence and HIV infection among women: a systematic review and meta-analysis. J Int AIDS Soc. 2014;17:18845. doi: 10.7448/ias.17.1.18845. PMID: 24560342.24560342
24 Coker AL. Does physical intimate partner violence affect sexual health? A systematic review. Trauma Violence Abuse. 2007 Apr;8(2):149–77. doi: 10.1177/1524838007301162. PMID: 17545572.17545572
25 Shah PS, Shah J. Maternal exposure to domestic violence and pregnancy and birth outcomes: a systematic review and meta-analyses. J Womens Health (Larchmt). 2010 Nov;19(11):2017–31. doi: 10.1089/jwh.2010.2051. PMID: 20919921.20919921
26 Desmarais SL, Pritchard A, Lowder EM, . Intimate partner abuse before and during pregnancy as risk factors for postpartum mental health problems. BMC Pregnancy Childbirth. 2014;14:132. doi: 10.1186/1471-2393-14-132. PMID: 24708777.24708777
27 Pavey AR, Gorman GH, Kuehn D, . Intimate partner violence increases adverse outcomes at birth and in early infancy. J Pediatr. 2014 Nov;165(5):1034–9. doi: 10.1016/j.jpeds.2014.06.060. PMID: 25128162.25128162
28 Cerulli C, Bossarte RM, Dichter ME. Exploring intimate partner violence status among male veterans and associated health outcomes. American Journal of Mens Health. 2014 Jan;8(1):66–73. doi: 10.1177/1557988313492558. PMID: WOS:000327992900008.
29 Fletcher J. The effects of intimate partner violence on health in young adulthood in the United States. Soc Sci Med. 2010 Jan;70(1):130–5. doi: 10.1016/j.socscimed.2009.09.030. PMID: 19819603.19819603
30 Burnett JP, Jackson SLP, Sinha AKM, . Five-year all-cause mortality rates across five categories of substantiated elder abuse occurring in the community. J Elder Abuse Negl. 2016 Jan 21:1–17. doi: 10.1080/08946566.2016.1142920. PMID: 26797389.26797389
31 Dong X, Simon M, Mendes de Leon C, . Elder self-neglect and abuse and mortality risk in a community-dwelling population. JAMA. 2009 Aug 5;302(5):517–26. doi: 10.1001/jama.2009.1109. PMID: 19654386.19654386
32 Lachs MS, Williams CS, O’Brien S, . Adult protective service use and nursing home placement. Gerontologist. 2002 Dec;42(6):734–9. PMID: 12451154.12451154
33 Dong X, Chen R, Chang ES, . Elder abuse and psychological well-being: a systematic review and implications for research and policy-a mini review. Gerontology. 2013;59(2):132–42. doi: 10.1159/000341652. PMID: 22922225.22922225
34 Capaldi DM, Knoble NB, Shortt JW, . A systematic review of risk factors for intimate partner violence. Partner Abuse. 2012 Apr;3(2):231–80. doi: 10.1891/1946-6560.3.2.231. PMID: 22754606.22754606
35 Taillieu TL, Brownridge DA. Violence against pregnant women: prevalence, patterns, risk factors, theories, and directions for future research. Aggression and Violent Behavior. 2010;15(1):14–35. doi: 10.1016/j.avb.2009.07.013.
36 Hamby S, Finkelhor D, Turner H. Teen dating violence: co-occurrence with other victimizations in the National Survey of Children’s Exposure to Violence (NatSCEV). Psychol Violence. 2012 Apr;2(2):111–24. doi: 10.1037/a0027191. PMID: WOS:000314745200002.
37 Millett LS, Kohl PL, Jonson-Reid M, . Child maltreatment victimization and subsequent perpetration of young adult intimate partner violence: an exploration of mediating factors. Child Maltreat. 2013 May;18(2):71–84. doi: 10.1177/1077559513484821. PMID: 23633678.23633678
38 Renner LM, Whitney SD. Risk factors for unidirectional and bidirectional intimate partner violence among young adults. Child Abuse Negl. 2012;36:40.22269774
39 Costa BM, Kaestle CE, Walker A, . Longitudinal predictors of deomstic violence perpetration and victimization: a systematic revew. Aggression and Violent Behavior. 2015;24:261–72.
40 Burnes D, Pillemer K, Caccamise PL, . Prevalence of and risk factors for elder abuse and neglect in the community: a population-based study. J Am Geriatr Soc. 2015 Sep;63(9):1906–12. doi: 10.1111/jgs.13601. PMID: 26312573.26312573
41 Lachs MS, Pillemer KA. Elder abuse. N Engl J Med. 2015 Nov 12;373(20):1947–56. doi: 10.1056/NEJMra1404688. PMID: 26559573.26559573
42 Brownell P, Berman J, Salamone A. Mental health and criminal justice issues among perpetrators of elder abuse. J Elder Abuse Negl. 2000;11(4):81–94. doi: 10.1300/J084v11n04_06. PMID: 21877986.21877986
43 Moon A, Williams O. Perceptions of elder abuse and help-seeking patterns among African-American, Caucasian American, and Korean-American elderly women. Gerontologist. 1993 Jun;33(3):386–95. PMID: 8325527.8325527
44 Feder G, Ramsay J, Dunne D, . How far does screening women for domestic (partner) violence in different health-care settings meet criteria for a screening programme? Systematic reviews of nine UK National Screening Committee criteria. Health Technol Assess. 2009 Mar;13(16):iii–iv, xi–xiii, 1–113, 37–347. doi: 10.3310/hta13160. PMID: 19272272.19272272
45 Nelson HD, Bougatsos C, Blazina I. Screening Women for Intimate Partner Violence and Elderly and Vulnerable Adults for Abuse: Systematic Review to Update the 2004 U.S. Preventive Services Task Force Recommendation. Rockville MD; 2012.
46 Scogin F, Beall C, Bynum J, . Training for abusive caregivers: an unconventional approach to an intervention dilemma. J Elder Abuse Negl. 1998;1(4):73–86.
47 Alvarez C, Fedock G, Grace KT, . Provider screening and counseling for intimate partner violence: a systematic review of practices and influencing factors. Trauma Violence Abuse. 2016 Mar 31 doi: 10.1177/1524838016637080. PMID: 27036407.27036407
48 Houry D, Sachs CJ, Feldhaus KM, . Violence-inflicted injuries: reporting laws in the fifty states. Ann Emerg Med. 2002 Jan;39(1):56–60. PMID: 11782731.11782731
49 National Center on Elder Abuse. State Directory of Helplines, Hotlines, and Elder Abuse Prevention Resources. Washington, DC: Administration on Aging; 2011. http://www.ncea.aoa.gov/NCEAroot/Main_Site/Find_Help/State_Resources.aspx. Accessed April 18, 2012.
50 Violence Against Women and Department of Justice Reauthorization Act. 109-162, 119, 119 Stat 2960-3135.; 2005.
51 Nelson H, Nygren P, McInerney Y. U.S. Preventive Services Task Force Evidence Syntheses, formerly Systematic Evidence Reviews. Screening for Family and Intimate Partner Violence. Rockville (MD): Agency for Healthcare Research and Quality (US); 2004.
52 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews Agency for Healthcare Research and Quality AHRQ Publication No. 10(11)-EHC063-EF. BKG. Rockville, MD: Agency for Healthcare Research and Quality; 2011.
53 Harris RP, Helfand M, Woolf SH, . Current methods of the US Preventive Services Task Force: a review of the process. Am J Prev Med. 2001 Apr;20:(3 Suppl):21–35. PMID: 11306229.11306229
54 West SL, Gartlehner G, Mansfield AJ, . Comparative Effectiveness Review Methods: Clinical Heterogeneity Methods Research Paper. AHRQ Publication No. 10-EHC070-EF. Rockville, MD: Agency for Healthcare Research and Quality; September 2010. PMID: 2143333721433337. http://effectivehealthcare.ahrq.gov/
55 Owens DK, Lohr KN, Atkins D, . AHRQ series paper 5: grading the strength of a body of evidence when comparing medical interventions-agency for healthcare research and quality and the effective health-care program. J Clin Epidemiol. 2010 May;63(5):513–23. doi: 10.1016/j.jclinepi.2009.03.009. PMID: 19595577.19595577
56 Berkman ND, Lohr KN, Ansari MT, . Grading the strength of a body of evidence when assessing health care interventions: an EPC update. J Clin Epidemiol. 2015 Nov;68(11):1312–24. doi: 10.1016/j.jclinepi.2014.11.023. PMID: 25721570.25721570
57 Klevens J, Kee R, Trick W, . Effect of screening for partner violence on women’s quality of life: a randomized controlled trial. JAMA. 2012 Aug 15;308(7):681–9. doi: 10.1001/jama.2012.6434. PMID: 22893165.22893165
58 Koziol-McLain J, Garrett N, Fanslow J, . A randomized controlled trial of a brief emergency department intimate partner violence screening intervention. Ann Emerg Med. 2010 Oct;56(4):413–23 e1. doi: 10.1016/j.annemergmed.2010.05.001. PMID: 20538369.20538369
59 MacMillan HL, Wathen CN, Jamieson E, . Screening for intimate partner violence in health care settings: a randomized trial. JAMA. 2009 Aug 5;302(5):493–501. doi: 10.1001/jama.2009.1089. PMID: 19654384.19654384
60 Klevens J, Sadowski LS, Kee R, . Effect of screening for partner violence on use of health services at 3-year follow-up of a randomized clinical trial. JAMA. 2015 Aug 4;314(5):515–6. doi: 10.1001/jama.2015.6755. PMID: 26241603.26241603
61 Tjaden P, Thoennes N. Full Report of the Prevalence, Incidence, and Consequences of Violence Against Women: Findings From the National Violence Against Women Survey U.S. Department of Justice. NCJ 183781. Washington, DC: November 2000. https://www.ncjrs.gov/pdffiles1/nij/183781.pdf
62 Mills TJ, Avegno JL, Haydel MJ. Male victims of partner violence: prevalence and accuracy of screening tools. J Emerg Med. 2006 Nov;31(4):447–52. doi: 10.1016/j.jemermed.2005.12.029. PMID: 17046494.17046494
63 Ernst AA, Weiss SJ, Cham E, . Detecting ongoing intimate partner violence in the emergency department using a simple 4-question screen: the OVAT. Violence Vict. 2004 Jun;19(3):375–84. PMID: 15631287.15631287
64 Feldhaus KM, Koziol-McLain J, Amsbury HL, . Accuracy of 3 brief screening questions for detecting partner violence in the emergency department. JAMA. 1997 May 7;277(17):1357–61. PMID: 9134940.9134940
65 Paranjape A, Liebschutz J. STaT: a three-question screen for intimate partner violence. J Womens Health (Larchmt). 2003 Apr;12(3):233–9. doi: 10.1089/154099903321667573. PMID: 12804354.12804354
66 Chen PH, Rovi S, Vega M, . Screening for domestic violence in a predominantly Hispanic clinical setting. Fam Pract. 2005 Dec;22(6):617–23. doi: 10.1093/fampra/cmi075. PMID: 16055473.16055473
67 Dubowitz H, Prescott L, Feigelman S, . Screening for intimate partner violence in a pediatric primary care clinic. Pediatrics. 2008 Jan;121(1):e85–91. doi: 10.1542/peds.2007-0904. PMID: 18166548.18166548
68 Sohal H, Eldridge S, Feder G. The sensitivity and specificity of four questions (HARK) to identify intimate partner violence: a diagnostic accuracy study in general practice. BMC Fam Pract. 2007;8:49. doi: 10.1186/1471-2296-8-49. PMID: 17727730.17727730
69 Zink T, Levin L, Putnam F, . Accuracy of five domestic violence screening questions with nongraphic language. Clin Pediatr (Phila). 2007 Mar;46(2):127–34. doi: 10.1177/0009922806290029. PMID: 17325085.17325085
70 Paranjape A, Rask K, Liebschutz J. Utility of STaT for the identification of recent intimate partner violence. J Natl Med Assoc. 2006 Oct;98(10):1663–9. PMID: 17052059.17052059
71 Iverson KM, King MW, Resick PA, . Clinical utility of an intimate partner violence screening tool for female VHA patients. J Gen Intern Med. 2013 Oct;28(10):1288–93. doi: 10.1007/s11606-013-2534-x [doi]. PMID: 23824907.23824907
72 Iverson KM, King MW, Gerber MR, . Accuracy of an intimate partner violence screening tool for female VHA patients: a replication and extension. J Trauma Stress. 2015 Feb;28(1):79–82. doi: 10.1002/jts.21985 [doi]. PMID: 25624170.25624170
73 Koziol-McLain J, Coates CJ, Lowenstein SR. Predictive validity of a screen for partner violence against women. Am J Prev Med. 2001 Aug;21(2):93–100. doi: [pii]. PMID: 11457628.11457628
74 Weiss SJ, Ernst AA, Cham E, . Development of a screen for ongoing intimate partner violence. Violence Vict. 2003 Apr;18(2):131–41. PMID: 12816400.12816400
75 MacMillan HL, Wathen CN, Jamieson E, . Approaches to screening for intimate partner violence in health care settings: a randomized trial. JAMA. 2006 Aug 2;296(5):530–6. doi: 10.1001/jama.296.5.530. PMID: 16882959.16882959
76 Wathen CN, Jamieson E, MacMillan HL. Who is identified by screening for intimate partner violence? Womens Health Issues. 2008 Nov-Dec;18(6):423–32. doi: 10.1016/j.whi.2008.08.003. PMID: 19041594.19041594
77 Fulfer JL, Tyler JJ, Choi NJ, . Using indirect questions to detect intimate partner violence: the SAFE-T questionnaire. J Interpers Violence. 2007 Feb;22(2):238–49. doi: 10.1177/0886260506295814. PMID: 17202578.17202578
78 Lock J. The Development of the Consequences of Screening Tool and the Psychometric Assessment of Three Woman Abuse Measures [thesis]. Hamilton, ON: McMaster University; 2008.
79 O’Doherty L, Hegarty K, Ramsay J, . Screening women for intimate partner violence in healthcare settings. Cochrane Database Syst Rev. 2015;7:CD007007. doi: 10.1002/14651858.CD007007.pub3. PMID: 26200817.26200817
80 Bair-Merritt MH, Jennings JM, Chen R, . Reducing maternal intimate partner violence after the birth of a child: a randomized controlled trial of the Hawaii Healthy Start Home Visitation Program. Arch Pediatr Adolesc Med. 2010 Jan;164(1):16–23. doi: 10.1001/archpediatrics.2009.237. PMID: 20048237.20048237
81 Sharps PW, Bullock LF, Campbell JC, . Domestic violence enhanced perinatal home visits: the DOVE randomized clinical trial. J Womens Health (Larchmt). 2016 Nov;25(11):1129–38. doi: 10.1089/jwh.2015.5547. PMID: 27206047.27206047
82 El-Mohandes AA, Kiely M, Joseph JG, . An intervention to improve postpartum outcomes in African-American mothers: a randomized controlled trial. Obstet Gynecol. 2008 Sep;112(3):611–20. doi: 10.1097/AOG.0b013e3181834b10. PMID: 18757660.18757660
83 Tiwari A, Leung WC, Leung TW, . A randomised controlled trial of empowerment training for Chinese abused pregnant women in Hong Kong. BJOG. 2005 Sep;112(9):1249–56. doi: 10.1111/j.1471-0528.2005.00709.x. PMID: 16101604.16101604
84 Zlotnick C, Capezza NM, Parker D. An interpersonally based intervention for low-income pregnant women with intimate partner violence: a pilot study. Arch Womens Ment Health. 2011 Feb;14(1):55–65. doi: 10.1007/s00737-010-0195-x. PMID: 21153559.21153559
85 Kiely M, El-Mohandes AA, El-Khorazaty MN, . An integrated intervention to reduce intimate partner violence in pregnancy: a randomized controlled trial. Obstet Gynecol. 2010 Feb;115(2 Pt 1):273–83. doi: 10.1097/AOG.0b013e3181cbd482. PMID: 20093899.20093899
86 Hegarty K, O’Doherty L, Taft A, . Screening and counselling in the primary care setting for women who have experienced intimate partner violence (WEAVE): a cluster randomised controlled trial. Lancet. 2013 Jul 20;382(9888):249–58. doi: 10.1016/S0140-6736(13)60052-5. PMID: 23598181.23598181
87 Rhodes KV, Rodgers M, Sommers M, . Brief motivational intervention for intimate partner violence and heavy drinking in the emergency department: a randomized clinical trial. JAMA. 2015 Aug 4;314(5):466–77. doi: 10.1001/jama.2015.8369. PMID: 26241598.26241598
88 Miller E, Tancredi DJ, Decker MR, . A family planning clinic-based intervention to address reproductive coercion: a cluster randomized controlled trial. Contraception. 2016.
89 Miller E, Decker MR, McCauley HL, . A family planning clinic partner violence intervention to reduce risk associated with reproductive coercion. Contraception. 2011 Mar;83(3):274–80. doi: 10.1016/j.contraception.2010.07.013. PMID: 21310291.21310291
90 Tiwari A, Fong DY, Yuen KH, . Effect of an advocacy intervention on mental health in Chinese women survivors of intimate partner violence: a randomized controlled trial. JAMA. 2010 Aug 4;304(5):536–43. doi: 10.1001/jama.2010.1052. PMID: 20682933.20682933
91 Saftlas AF, Harland KK, Wallis AB, . Motivational interviewing and intimate partner violence: a randomized trial. Ann Epidemiol. 2014 Feb;24(2):144–50. doi: 10.1016/j.annepidem.2013.10.006. PMID: 24252714.24252714
92 El-Mohandes AA, Kiely M, Gantz MG, . Very preterm birth is reduced in women receiving an integrated behavioral intervention: a randomized controlled trial. Matern Child Health J. 2011 Jan;15(1):19–28. doi: 10.1007/s10995-009-0557-z. PMID: 20082130.20082130
93 Dong X. Advancing the field of elder abuse: future directions and policy implications. J Am Geriatr Soc. 2012 Nov;60(11):2151–6. doi: 10.1111/j.1532-5415.2012.04211.x [doi]. PMID: 23110488.23110488
94 Tiwari A, Fong DY, Wong JY, . Safety-promoting behaviors of community-dwelling abused Chinese women after an advocacy intervention: a randomized controlled trial. Int J Nurs Stud. 2012 Jun;49(6):645–55. doi: 10.1016/j.ijnurstu.2011.12.005. PMID: 22227168.22227168
95 Cunningham RM, Whiteside LK, Chermack ST, . Dating violence: outcomes following a brief motivational interviewing intervention among at-risk adolescents in an urban emergency department. Acad Emerg Med. 2013 Jun;20(6):562–9. doi: 10.1111/acem.12151. PMID: 23758302.23758302
96 Kempe H. Child abuse and neglect: the family and the community. Cambridge, MA: Ballinger Publishing Company; 1976.
97 Poole N, Greaves L, Jategaonkar N, . Substance use by women using domestic violence shelters. Subst Use Misuse. 2008 Jul;43(8-9):1129–50. doi: 10.1080/10826080801914360. PMID: 18649235.18649235
98 Fulmer T, Strauss S, Russell SL, . Screening for elder mistreatment in dental and medical clinics. Gerodontology. 2012 Jun;29(2):96–105. doi: 10.1111/j.1741-2358.2010.00405.x [doi]. PMID: 22225431.22225431
99 Folstein MF, Folstein SE, McHugh PR. Minimental state: a practical method for grading the cognitive state of patients for clinicians. J Psychiatr Res. 1975;12:189–98.1202204
100 Taft AJ, Small R, Hegarty KL, . Mothers’ AdvocateS In the Community (MOSAIC)-non-professional mentor support to reduce intimate partner violence and depression in mothers: a cluster randomised trial in primary care. BMC Public Health. 2011;11:178. doi: 10.1186/1471-2458-11-178. PMID: 21429226.21429226
101 Nelson HD, Bougatsos C, Blazina I. Screening women for intimate partner violence: a systematic review to update the U.S. Preventive Services Task Force recommendation. Ann Intern Med. 2012 Jun 5;156(11):796–808, W-279, W-80, W-81, W-82. doi: 10.7326/0003-4819-156-11-201206050-00447. PMID: 22565034.22565034
102 Dicola D, Spaar E. Intimate partner violence. Am Fam Physician. 2016 Oct 15;94(8):646–51. PMID: 27929227.27929227
103 Schulman EA, Hohler AD. The American Academy of Neurology position statement on abuse and violence. Neurology; 2012. p. 433–5.22282648
104 Thackeray JD, Hibbard R, Dowd. Clinical Report: Intimate Partner Violence: The Role of the Pediatrician. Pediatrics. 2010;126(4):833–41.20945525
105 Thackeray JD, Hibbard R, Dowd MD. Clinical Report-Intimate Partner Violence: The Role of the Pediatrician. Pediatrics. 2010 May;125(5):1094–100. doi: 10.1542/peds.2010-0451. PMID: WOS:000277232800032.20421260
106 American College of Obstetricians and Gynecologists. Intimate partner violence. Committee Opinion No. 518. Obstet Gynecol; 2012. p. 412–7.22270317
107 Chamberlain L, Levenson R. A Guide for Obstetric, Gynecologic and Reproductive Health Care Settings. Second ed. San Francisco, CA: Futures Without Violence, formerly the Family Violence Prevention Fund; 2012.
108 AWHONN Position Statement. Intimate partner violence. J Obstet Gynecol Neonatal Nurs. 2015 May-Jun;44(3):405–8. doi: 10.1111/1552-6909.12567. PMID: 25809582.25809582
109 Committee on Preventive Services for Women aIoM. Clinical Preventive Services for Women: Closing the Gaps. Washington, DC: National Academies Press; 2011.
110 Canadian Task Force for Preventive Health Care. Appraised Guidelines, Domestic Abuse. 2016. http://canadiantaskforce.ca/appraised-guidelines/2013-domestic-abuse/2016.
111 World Health Organization. Responding to intimate partner violence and sexual violence against women: WHO clinical and policy guidelines. Geneva: World Health Organization; 2013. http://apps.who.int/iris/bitstream/10665/85240/1/9789241548595_eng.pdf. Accessed March 4, 2016.
112 American Academy of Family Physicians. Intimate Partner Violence and Abuse of Vulnerable Adults Leawood, KS: American Academy of Family Physicians; 2014. https://www.aafp.org/patient-care/clinical-recommendations/all/domestic-violence.html. Accessed February 20, 2018.
113 American Congress of Obstetricians and Gynecologists. Elder Abuse and Women’s Health. Committee Opinion. 2013 July;568.
114 Boltz M, Capezuti E, Fulmer TT, eds. Evidence-Based Geriatric Nursing Protocols for Best Practice. Fifth ed. New York: Springer Publishing Company. ProQuest ebrary; 2016.
115 Galantowicz S, Crisp S, Karp N, . Safe at Home? Developing Effective Criminal Background Checks and Other Screening Policies for Home Care Workers AARP Public Policy Institute. Washington, DC: 2010. http://assets.aarp.org/rgcenter/ppi/ltc/2009-12.pdf
116 Cham GW, Seow E. The pattern of elderly abuse presenting to an emergency department. Singapore Med J. 2000 Dec;41(12):571–4. PMID: 11296780.11296780
117 Evans CS, Hunold KM, Rosen T, . Diagnosis of elder abuse in U.S. emergency departments. J Am Geriatr Soc. 2017 Jan;65(1):91–7. doi: 10.1111/jgs.14480. PMID: 27753066.27753066
118 Rosen T, Bloemen EM, LoFaso VM, . Emergency department presentations for injuries in older adults independently known to be victims of elder abuse. J Emerg Med. 2016 Mar;50(3):518–26. doi: 10.1016/j.jemermed.2015.10.037. PMID: WOS:000373301600050.26810019
119 Rosen T, Hargarten S, Flomenbaum NE, . Identifying elder abuse in the emergency department: toward a multidisciplinary team-based approach. Ann Emerg Med. 2016 Sep;68(3):378–82. doi: 10.1016/j.annemergmed.2016.01.037. PMID: 27005448.27005448
120 Brown JB, Lent B, Schmidt G, . Application of the Woman Abuse Screening Tool (WAST) and WAST-short in the family practice setting. J Fam Pract. 2000 Oct;49(10):896–903. PMID: 11052161.11052161
121 Canterino JC, VanHorn LG, Harrigan JT, . Domestic abuse in pregnancy: A comparison of a self-completed domestic abuse questionnaire with a directed interview. Am J Obstet Gynecol. 1999 Nov;181(5 Pt 1):1049–51. PMID: 10561616.10561616
122 Coker AL, Pope BO, Smith PH, . Assessment of clinical partner violence screening tools. J Am Med Womens Assoc. 2001 Winter;56(1):19–23. PMID: 11202067.11202067
123 Ernst AA, Weiss SJ, Cham E, . Comparison of three instruments for assessing ongoing intimate partner violence. Med Sci Monit. 2002 Mar;8(3):CR197–201. PMID: 11887036.11887036
124 Furbee PM, Sikora R, Williams JM, . Comparison of domestic violence screening methods: a pilot study. Ann Emerg Med. 1998 Apr;31(4):495–501. PMID: 9546020.9546020
125 Glass N, Dearwater S, Campbell J. Intimate partner violence screening and intervention: data from eleven Pennsylvania and California community hospital emergency departments. J Emerg Nurs. 2001 Apr;27(2):141–9. doi: 10.1067/men.2001.114387. PMID: 11275861.11275861
126 McFarlane J, Christoffel K, Bateman L, . Assessing for abuse: self-report versus nurse interview. Public Health Nurs. 1991 Dec;8(4):245–50. PMID: 1766908.1766908
127 McFarlane J, Parker B, Soeken K, . Assessing for abuse during pregnancy. Severity and frequency of injuries and associated entry into prenatal care. JAMA. 1992 Jun 17;267(23):3176–8. PMID: 1593739.1593739
128 McFarlane J, Soeken K, Wiist W. An evaluation of interventions to decrease intimate partner violence to pregnant women. Public Health Nurs. 2000 Nov-Dec;17(6):443–51. PMID: 11115142.11115142
129 Moody LE, Voss A, Lengacher CA. Assessing abuse among the elderly living in public housing. J Nurs Meas. 2000 Summer;8(1):61–70. PMID: 11026166.11026166
130 Morrison LJ, Allan R, Grunfeld A. Improving the emergency department detection rate of domestic violence using direct questioning. J Emerg Med. 2000 Aug;19(2):117–24. PMID: 10903457.10903457
131 Neale AV, Hwalek MA, Scott RO, . Validation of the Hwalek-Sengstock Elder Abuse Screening Test. J Appl Gerontol. 1991;10(4):406–18.
132 Norton LB, Peipert JF, Zierler S, . Battering in pregnancy: an assessment of two screening methods. Obstet Gynecol. 1995 Mar;85(3):321–5. doi: 10.1016/0029-7844(94)00429-h. PMID: 7862365.7862365
133 Pan HS, Ehrensaft MK, Heyman RE, . Evaluating domestic partner abuse in a family practice clinic. Fam Med. 1997 Jul-Aug;29(7):492–5. PMID: 9232411.9232411
134 Parker B, McFarlane J, Soeken K, . Testing an intervention to prevent further abuse to pregnant women. Res Nurs Health. 1999 Feb;22(1):59–66. PMID: 9928964.9928964
135 Reis M, Nahmiash D. Validation of the Caregiver Abuse Screen (CASE) Can J Aging. 1995;14(2):45–60.
136 Sherin KM, Sinacore JM, Li XQ, . HITS: a short domestic violence screening tool for use in a family practice setting. Fam Med. 1998 Jul-Aug;30(7):508–12. PMID: 9669164.9669164
137 Smith M, Martin F. Domestic violence: recognition, intervention, and prevention. Medsurg Nurs. 1995 Feb;4(1):21–5. PMID: 7874217.7874217
138 Chang JC, Decker M, Moracco KE, . What happens when health care providers ask about intimate partner violence? A description of consequences from the perspectives of female survivors. J Am Med Womens Assoc. 2003 Spring;58(2):76–81. PMID: 12744419.12744419
139 Curry MA, Durham L, Bullock L, . Nurse case management for pregnant women experiencing or at risk for abuse. J Obstet Gynecol Neonatal Nurs. 2006 Mar-Apr;35(2):181–92. doi: 10.1111/j.1552-6909.2006.00027.x. PMID: 16620243.16620243
140 Houry D, Feldhaus K, Peery B, . A positive domestic violence screen predicts future domestic violence. J Interpers Violence. 2004 Sep;19(9):955–66. doi: 10.1177/0886260504267999. PMID: 15296611.15296611
141 Houry D, Kaslow NJ, Kemball RS, . Does screening in the emergency department hurt or help victims of intimate partner violence? Ann Emerg Med. 2008 Apr;51(4):433–42, 42 e1-7. doi: 10.1016/j.annemergmed.2007.11.019. PMID: 18313800.18313800
142 Hurley KF, Brown-Maher T, Campbell SG, . Emergency department patients’ opinions of screening for intimate partner violence among women. Emerg Med J. 2005 Feb;22(2):97–8. doi: 10.1136/emj.2002.002626. PMID: 15662056.15662056
143 Koziol-McLain J, Giddings L, Rameka M, . Intimate partner violence screening and brief intervention: experiences of women in two New Zealand Health Care Settings. J Midwifery Womens Health. 2008 Nov-Dec;53(6):504–10. doi: 10.1016/j.jmwh.2008.06.002. PMID: 18984506.18984506
144 Liebschutz J, Battaglia T, Finley E, . Disclosing intimate partner violence to health care clinicians - what a difference the setting makes: a qualitative study. BMC Public Health. 2008;8:229. doi: 10.1186/1471-2458-8-229. PMID: 18601725.18601725
145 Peralta RL, Fleming MF. Screening for intimate partner violence in a primary care setting: the validity of “feeling safe at home” and prevalence results. J Am Board Fam Pract. 2003 Nov-Dec;16(6):525–32. PMID: 14963079.14963079
146 Reichenheim ME, Moraes CL. Comparison between the abuse assessment screen and the revised conflict tactics scales for measuring physical violence during pregnancy. J Epidemiol Community Health. 2004 Jun;58(6):523–7. PMID: 15143123.15143123
147 Renker PR, Tonkin P. Women’s views of prenatal violence screening: acceptability and confidentiality issues. Obstet Gynecol. 2006 Feb;107(2 Pt 1):348–54. doi: 10.1097/01.AOG.0000195356.90589.c5. PMID: 16449123.16449123
148 Sethi D, Watts S, Zwi A, . Experience of domestic violence by women attending an inner city accident and emergency department. Emerg Med J. 2004 Mar;21(2):180–4. PMID: 14988343.14988343
149 Spangaro JM, Zwi AB, Poulos RG. “Persist. Persist.”: A Qualitative Study of Women’s Decisions to Disclose and Their Perceptions of the Impact of Routine Screening for Intimate Partner Violence. 2010.
150 Spangaro JM, Zwi AB, Poulos RG, . Six months after routine screening for intimate partner violence: attitude change, useful and adverse effects. Women Health. 2010 Mar;50(2):125–43. doi: 10.1080/03630241003705060. PMID: 20437301.20437301
151 Thombs BD, Bernstein DP, Ziegelstein RC, . A brief two-item screener for detecting a history of physical or sexual abuse in childhood. Gen Hosp Psychiatry. 2007 Jan-Feb;29(1):8–13. doi: 10.1016/j.genhosppsych.2006.10.013. PMID: 17189738.17189738
152 Weinsheimer RL, Schermer CR, Malcoe LH, . Severe intimate partner violence and alcohol use among female trauma patients. J Trauma. 2005 Jan;58(1):22–9. PMID: 15674145.15674145
153 Zeitler MS, Paine AD, Breitbart V, . Attitudes about intimate partner violence screening among an ethnically diverse sample of young women. J Adolesc Health. 2006 Jul;39(1):119 e1-8. doi: 10.1016/j.jadohealth.2005.09.004. PMID: 16781970.16781970
154 Buri HM, Daly JM, Jogerst GJ. Elder abuse telephone screen reliability and validity. J Elder Abuse Negl. 2009 Jan-Mar;21(1):58–73. doi: 10.1080/08946560802571912. PMID: 19197621.19197621
155 Kita S, Haruna M, Hikita N, . Development of the Japanese version of the Woman Abuse Screening Tool-Short. Nurs Health Sci. 2017 Mar;19(1):35–43. doi: 10.1111/nhs.12298. PMID: 27426035.27426035
156 McNutt LA, Carlson BE, Rose IM, . Partner violence intervention in the busy primary care environment. Am J Prev Med. 2002 Feb;22(2):84–91. doi: [pii]. PMID: 11818176.11818176
157 Shakil A, Donald S, Sinacore JM, . Validation of the HITS domestic violence screening tool with males. Fam Med. 2005 Mar;37(3):193–8. PMID: 15739135.15739135
158 McFarlane JM, Groff JY, O’Brien JA, . Secondary prevention of intimate partner violence: a randomized controlled trial. Nurs Res. 2006 Jan-Feb;55(1):52–61. PMID: 16439929.16439929
159 Zhang H, Neelarambam K, Schwenke TJ, . Mediators of a culturally-sensitive intervention for suicidal African American women. J Clin Psychol Med Settings. 2013 Dec;20(4):401–14. doi: 10.1007/s10880-013-9373-0. PMID: 23864403.23864403
160 Basile KC, Hertz MF, Back SE. Intimate Partner Violence and Sexual Violence Victimization Assessment Instruments for Use in Healthcare Settings: Version 1. Atlanta, GA: Centers for Disease Control and Prevention, National Center for Injury Prevention and Control; 2007. https://www.cdc.gov/violenceprevention/pdf/ipv/ipvandsvscreening.pdf. Accessed May 10, 2017.