# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project and appreciate their considerable support, commitment, and contributions: Amanda Borsky, DrPH, MPP, AHRQ Medical Officer; Tracy Wolff, MD, MPH, AHRQ Associate Scientific Director; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; expert reviewers Adelita Gonzales Cantu, PhD, RN, The University of Texas Health Science Center at San Antonio; Joanne Klevens, MD, PhD, Centers for Disease Control and Prevention; and Timothy Platts-Mills, MD, MSc, University of North Carolina at Chapel Hill; federal partner reviewers Jeffrey H. Herbst, PhD, and Joanne Klevens, MD, PhD, both affiliated with the Centers for Disease Control and Prevention; and RTI International–University of North Carolina EPC staff Carol Woodell and Rachel Palmieri Weber, Project Managers; Lynn Whitener, Librarian; Sharon Barrell, Editor; and Loraine Monroe, Publications Specialist.