# Chapter 4 Discussion

## Summary of Evidence

Table 6 and Table 7 provide a summary of findings in this evidence review. These tables are organized by KQ and provides a summary of the main findings along with a description of consistency, precision, quality, limitations, strength of evidence, and applicability.

Table 6 Summary of Evidence for Screening for Intimate Partner Violence

Key Question and Topic | No. of Studies & Study Design | No. of Participants | Summary of Main Findings (Including Consistency and Precision) | Quality | Limitations (Including Reporting Bias) | Strength of Evidence | Applicability
1: Benefits of screening | 3 RCTs | 3,759 | IPV (k=3): No significant difference between screening and control groups over 3-18 months; consistent, imprecise QOL (k=2): No significant difference between screening and control groups on SF-12 scores over 6–18 months; one RCT also found no significant difference between groups on WHOQOL-Bref subdomains; consistent, imprecise Depression/PTSD/health care utilization (k=1): No significant difference between groups for depression, PTSD, or health care utilization outcomes (each reported by only one trial each); unknown consistency, imprecise | Good to fair | Studies enrolled participants from different settings (U.S. primary care settings, one New Zealand ED, and mixed Canadian health care settings) and used diverse screening processes | Moderate for no benefit (IPV); and QOL); Low for no benefit (health care utilization; depression;PTSD) | Unselected adult women presenting for primary care and ED visits; one large U.S. trial was set in primary care clinics only
2: Identifying current, past, or increased risk for abuse and neglect | 15 Cross-sectional | 4,460 | Past-year IPV (women; k=5): Across five screeners (HARK, HITS, E-HITS, PVS, and WAST),, sensitivity ranged from 65 to 87%, and specificity ranged between 80 to 95%; mostly consistent, imprecise Past-year IPV (men, k=1): Sensitivity of two screeners (PVS, HITS) ranged from 30 to 71% and specificity ranged from 83 to 88%; unknown consistency, imprecise Current/ongoing IPV (k=4): Across 5 screeners (OAS, AAS, OVAT, STaT, 3-item unnamed) accuracy varied widely; inconsistent, imprecise | Fair | Most screeners were assessed in only one study; studies used different reference standards and sometimes used different cutpoints for positivity in the same reference standard; handling of missing data (incomplete questionnaires) was often not reported; reporting bias not detected | Low (accuracy of past-year IPV in women) Insufficient (past-year IPV in men) | Adult women seeking care in various clinical settings with unknown IPV symptom status
3: Harms of screening | 2 RCTs | 1,051 | Two RCTs concluded no adverse effects of screening were identified; consistent, unknown precision | Fair | One RCT did not report whether harms were prespecified; the other collected harms using a structured questionnaire, however, outcome timing (at initial screening visit) may not be sufficient to assess harms; reporting bias not detected | Low for no harms | Adult women seeking care in various clinical settings
4: Benefits of treatment | 11 RCTs | 6,740 | IPV (k=10): Two found a statistically significant benefit in favor of the intervention (one HV intervention and one counseling intervention addressing multiple risk factors) and one other HV intervention found an association with reduced IPV but differences were not statistically significant. Seven RCTs evaluated a counseling intervention for women with screen-detected IPV; five found similar rates of IPV in both groups with no statistically significant differences, and two reported on subtypes of violence only and found mixed results; inconsistent, imprecise QOL (k=3): 2 RCTs found no difference between groups on SF-12 scores, and 1 found mixed results across SF-36 subdomains; mostly consistent, imprecise Depression (k=5): Inconsistent results across different measures (3 RCTs found significant benefit and 2 did not); inconsistent, imprecise Anxiety (k=1): No significant benefit (similar HADS scores in both groups); unknown consistency, imprecise PTSD (k=1): No significant benefit (similar PTSD symptom scores in both groups); unknown consistency, imprecise Bith outcomes (k=1): Significantly lower rates of very preterm birth (based on analyses not accounting for missing data), no difference between groups for low birth weight, very low birth weight, or preterm births; unknown consistency, imprecise | Fair | Studies assessed heterogeneous interventions and measured IPV at different time points using different outcome measures; benefit for IPV and birth outcomes in one behavioral counseling intervention may be related to counseling for other risk factors (smoking, depression) and not specific to counseling for IPV;; reporting bias not detected | Low (IPV, QOL) Insufficient (anxiety, depression, PTSD, birth outcomes) | Women who screen positive for IPV during a routine primary care visit; studies that found significant benefit for reducing overall IPV enrolled pregnant women
5: Harms of treatment | 5 RCTs | 1,409 | No study found significant harms associated with the interventions; consistent, imprecise | Fair | Studies did not comment on whether harms were prespecified or how they were ascertained; reporting bias not detected | Low for no harms | Women who screen positive for IPV during a routine primary care visit

Abbreviations: CES-D=Center for Epidemiologic Studies Depression; CTS-2=Conflict Tactics Scale-2; E-HITS=Electronic HITS; ED=emergency department; HARK=Humiliation, Afraid, Rape, Kick; HITS=Hurt/Insult/Threaten/Scream Tool; IPV=intimate partner violence; k=number of studies; PTSD=posttraumatic stress disorder; QOL=quality of life; RCT=randomized, controlled trial; SPAN=Startle, Physiological Arousal, Anger, and Numbness instrument; WAST=Woman Abuse Screening Tool; WHOQOL-Bref=World Health Organization Quality of Life-Bref instrument.

Table 7 Summary of Evidence for Screening for Elder Abuse and Abuse of Vulnerable Adults

Key Question and Topic | No. of Studies & Study Design | No. of Participants | Summary of Main Findings (Including Consistency and Precision) | Quality | Limitations (Including Reporting Bias) | Strength of Evidence | Applicability
1: Benefits of screening | 0 | NA | NA | NA | NA | Insufficient | NA
2: Identifying current, past, or increased risk for abuse and neglect | 1 Cross-sectional study | 139 | Compared with the CTS, the H-S/EAST had a sensitivity of 46% (95% CI, 32 to 59) for detecting physical or verbal aggression and a specificity of 73% (95% CI, 62 to 82); unknown consistency, imprecise | Fair | Scale is relatively long (15 items) and may not be feasible for screening older adults presenting for routine care; reporting bias not detected | Insufficient | Generally healthy older adults presenting for routine dental care; population had a high prevalence of abuse on CTS (41% had violence/verbal aggression)
3: Harms of screening | 0 | NA | NA | NA | NA | Insufficient | NA
4: Benefits of treatment | 0 | NA | NA | NA | NA | Insufficient | NA
5: Harms of treatment | 0 | NA | NA | NA | NA | Insufficient | NA

Abbreviations: CI=confidence interval; CTS=Conflict Tactics Scale; H-S/EAST=Hwalek-Sengstock Elder Abuse Screening Test; NA=not applicable.

### Evidence for the Benefits and Harms of Screening for IPV

Overall, consistent evidence from three RCTs (3,759 participants) found no benefit of screening adult women for IPV. Despite differences in setting, screening process, and comparisons, none found a statistically significant reduction in IPV among the screened group compared with a nonscreened control group over 3 to 18 months of followup (moderate strength of evidence). Two RCTs also measured quality of life and found no significant difference between groups (moderate strength of evidence).^57,^ ^60^ We found no RCTs of screening enrolling men or adolescents, and none focused on pregnant women or that reported outcomes separately by pregnancy status.

The RCT enrolling women from Canadian health care settings^59^ was included in the prior (2013) review for the USPSTF (and the other two RCTs are new and were not included in the prior report). This trial has several limitations, including high overall attrition (42%) with higher abuse scores among those with missing data.^59^ Another concern noted in the prior review for the USPSTF was the potential that the approach used in the control group may have biased results toward the null. Specifically, women randomized to the control group were provided with information cards listing local resources for women experiencing IPV and underwent extensive questioning about IPV over 18 months of followup; these types of activities have the potential to influence participants’ behavior and affect outcomes of the trial.^59^ Similar potential bias toward the null is unlikely in the newly identified RCTs; neither screened women at baseline (and both measured IPV at only one time point). In addition, the RCT set in U.S. primary care centers also included two nonscreened control groups (one was given a list of partner violence resources and one was not); there was no significant difference in IPV incidence, quality of life, or health care utilization between women allocated to the partner violence resource list group and the no-resource list control group.^57^

In the RCT enrolling women from Canadian health care settings, the response to women with a positive IPV screen was left to the discretion of the clinician. The newly identified RCTs assessed more standardized interventions for women who screened positive for IPV. The RCT enrolling women from U.S. primary care settings showed a brief video to all women who screened positive (focused on advocacy, support, and encouragement to seek help) in addition to providing a list of resources. The RCT set in a New Zealand emergency department provided information about referral options and an additional clinical assessment (to assess safety) to all women who screened positive. If appropriate (e.g., there was a safety concern), additional on-site support was provided by the emergency department provider or hospital social worker. The newly identified RCT set in a New Zealand emergency department has unclear applicability to U.S. primary care centers (19% of the population was presenting for an acute injury, not specific to IPV); this trial also measured outcomes over a relatively short duration (3 months), which may not be sufficient time to detect a benefit.

Potential harms of screening asymptomatic populations for abuse include labeling, stigma, and risk of increased violence. The RCT enrolling women from various Canadian health care settings actively monitored harms and found no differences for women who were either exposed or not exposed to IPV;^59^ however, outcomes were only measured over a short duration (14 days) following screening. Other potential harms of screening include false-positive test results that lead to more in-depth inquiry or referrals from health professionals that would not lead to benefit and may cause labeling. For this topic, the gold standard for determining abuse is a longer-form structured questionnaire (e.g., CTS-2) and/or interview. For screening programs in primary care settings, positive tests are not generally confirmed with a test such as the CTS-2 but would (ideally) be followed by a conversation with a health care provider about safety, counseling, preferences for referrals, or other resources.

### Accuracy of Screening Questionnaires or Tools for Identifying Asymptomatic Populations Experiencing IPV

Screening tools are available for clinical practice that may reasonably identify women experiencing past year IPV (low strength of evidence). The 15 included studies assessed the accuracy of tools designed to detect IPV over different time frames (current/ongoing, past-year, or lifetime occurrence). Five studies evaluated accuracy of screeners for detecting any past-year IPV (HARK, HITS, E-HITS, PVS, and WAST) in adult women (Figure 6), sensitivity ranged from 65 to 87 percent, and specificity ranged between 80 and 95 percent. When limiting to studies enrolling participants from nonemergency department settings (i.e., primary care or community samples only), sensitivity was slightly higher (range: 75% to 87%), and specificity was unchanged. Most tools were assessed by only 1 study; the HITS was evaluated in 2 studies (both enrolling women veterans) one of which also evaluated the E-HITS. Estimates for accuracy of HITS and E-HITS were generally consistent but imprecise, with sensitivity ranging from 75 to 78 percent and specificity ranging from 80 to 83 percent.

The estimates of screening test accuracy for detecting past-year IPV are derived from populations with a prevalence of IPV (based on a gold standard) of 14 to 27 percent. The two studies enrolled women from primary care or mixed settings (primary care, OBGYN, and emergency departments) and reported an IPV prevalence of 23 and 14 percent, respectively. This is similar to the prevalence rate reported by the KQ 1 RCT enrolling women from U.S. primary care settings (15%). In a population of 100,000 women with 15 percent prevalence of IPV, use of the HARK screener (80% sensitivity and 95% specificity) would result in 81,000 true-positive tests and 5,000 false-positive tests (positive predictive value, 83%). Use of the WAST tool, with slightly higher sensitivity (87%) but lower specificity (89%) than the HARK, in a population with the same IPV prevalence (15%) would result in 87,484 true-positive tests and 11,000 false-positive tests (positive predictive value, 56%). The meaning of false-positive tests is not clear. As noted previously, the reference standard used to assess screening tool accuracy is a longer-form structured questionnaire. False-positive results may indicate a misunderstanding of the screening question. Alternatively, women with a false-positive test may have experienced IPV but choose to answer the reference standard negatively because disclosure of violence may be uncomfortable. Only one included study (N=856) assessed the ability of a 3-item tool to predict future (3- to 5-month abuse) abuse in a population cohort; the tool had poor accuracy (20% sensitivity and 96% specificity) for predicting future partner abuse.

### Benefits and Harms of IPV Interventions

Overall, evidence from 11 studies (6,740 participants) evaluating interventions for women with screen-detected IPV intervention or who were considered at risk for IPV was imprecise and often inconsistent. We graded the strength of evidence as low or insufficient for evidence on benefits of interventions. Although all RCTs enrolled only women, they assessed heterogeneous interventions and reported on a wide range of outcomes. For the most commonly reported outcome (IPV incidence), trials used different measures (e.g., CTS-2 scores, incidence of reproductive coercion) and often reported outcomes differently for the same measure (e.g., mean CTS-2 scores, incidence rate of violent episodes measured by the CTS-2). Most RCTs found lower rates of IPV over time in both groups, but few found a statistically significant difference between groups. Few studies enrolling similar populations and evaluating similar types of interventions reported on other outcomes (e.g., quality of life, reproductive outcomes). No studies measured mortality.

Two home-visiting interventions^80,^ ^81^ found lower rates of IPV among women assigned to the intervention group compared with controls; however, the difference between groups was small and results were imprecise (only one found a statistically significant difference).^81^ Three RCTs enrolling pregnant women with screen-detected IPV evaluated a counseling intervention; two found benefit^82,^ ^83^ and one did not;^84^ in one study, the benefit was significant for some subtypes of violence (psychological and minor physical abuse) but not others (severe physical and sexual abuse).^83^ One RCT assessing counseling for multiple risk factors reported on birth outcomes among the subgroup of women experiencing IPV at baseline (N= 306 out of 1,044 enrolled); there was no significant difference between groups in rates of low birth weight neonates (<2,500 g), very low birth weight neonates (<1,500 g), or preterm birth (<37 weeks); however, significantly fewer women in the intervention group had very preterm neonates (≤33 weeks).^82^ The RCT assessing behavioral counseling that found benefit for IPV and some birth outcomes among pregnant women has limitations. The intervention targeted multiple risk factors (smoking, environmental tobacco smoke exposure, depression, and IPV);^82^ improvement in birth outcomes among the women who had experienced IPV at baseline may not be attributable to IPV counseling. For example, among the subgroup of women reporting IPV at baseline, 62 percent reported being depressed, and those randomized to the intervention also received counseling for depression (in addition to IPV);^85^ the improvement in outcomes may be attributable to counseling for depression as opposed to IPV counseling. We graded the strength of evidence for birth outcomes as insufficient, downgrading because of imprecision, unknown consistency, few events from one subgroup analysis of an RCT, and uncertainty about whether results could be attributed to IPV counseling.

Across the six RCTs enrolling nonpregnant women, five measured IPV incidence. Four of these found no significant difference between groups in rates of overall IPV exposure^86,^ ^87^ or combined physical and sexual violence;^88,^ ^89^ rates of IPV were either similar across groups or slightly lower among women in the control group. One trial reported on subtypes of violence only and found benefit for psychological aggression but not for physical assault or sexual coercion.^90^ Two RCTs measured changes in quality of life following an intervention for IPV; scores were similar and differences were not statistically significant.^86,^ ^90^ Three RCTs reported on depression outcomes; two found benefit in favor of the intervention group (although one found a difference below the threshold for a clinically meaningful change),^86,^ ^90^ and one found similar scores between groups.^91^

Few RCTs reported on adverse effects of interventions. No trial found a statistically significant increase in IPV rates in the intervention group. Most studies reported that no adverse effects of the intervention were detected but did not specify whether harms outcomes were prespecified or how they were collected.

### Evidence for the Benefits and Harms of Screening for Elder Abuse and Abuse of Vulnerable Adults

We found no screening trials of elder abuse or abuse of vulnerable adults.

### Accuracy of Screening Questionnaires or Tools for Identifying Asymptomatic Populations With Elder Abuse or Abuse of Vulnerable Adults

We included one fair-quality study (N=139) assessing the accuracy of screening for abuse in older adults (age 65 or older) presenting for routine dental care.^98^ Eligible participants included those who received caregiver assistance and scored 18 or more on the Mini Mental Status Examination. The enrolled population had a relatively high prevalence of elder maltreatment based on CTS violence/verbal aggression scales (41%). Compared with the CTS, the H-S/EAST tool had a sensitivity of 46 percent (95% CI, 32 to 59) and specificity of 73.2 percent (95% CI, 62 to 82) for detecting elder abuse. No studies were found on the effectiveness of screening questionnaires or tools in identifying abuse and neglect of vulnerable adults.

### Benefits and Harms of Interventions for Elder Abuse or Abuse of Vulnerable Adults

We found no trials of interventions for older adults or vulnerable adults with screen-detected abuse.

## Limitations

This review did not evaluate the evidence on programs to prevent IPV victimization or studies that assess routine screening and interventions for perpetrators of abuse. The scope of this review focuses on asymptomatic populations without signs or symptoms of abuse. We did not assess the literature on whether certain physical or psychological symptoms should trigger an assessment of abuse (i.e., “case finding”) for any type of abuse. Our conclusions for KQ 4 (interventions for IPV) may differ slightly from the prior 2013 report. In addition to including several newly identified studies relevant to both KQ1 and KQ4, we also we excluded one trial (the MOSAIC trial) included in the prior report because it enrolled women who were referred based on symptoms of abuse or self-disclosure of IPV status (and were not screen detected).^100^ Women randomized to 12 months of weekly home visits from trained nonprofessional peer supporters had lower mean abuse scores than women in the control group at 1 year.

RCTs of IPV screening (KQ 1) were limited by heterogeneity in enrollment settings and differences in screening processes; however, trials measured similar outcomes and found consistent results. For KQ 3 (harms of screening), we limited the review to study designs that had a concurrent control group. This limit excluded uncontrolled studies that report results from single cohorts or focus groups of women who were offered IPV screening. The prior review for the USPSTF concluded that study populations and methods in noncontrolled studies varied widely. Results from these studies did not show significant harm related to screening; some studies found that a minority of respondents indicated discomfort with screening (particularly among those with prior IPV), infringement of privacy, worries about increasing abuse by disclosing IPV, and feelings of sadness or depression.^101^

Some studies of IPV screening tool accuracy (KQ 2) were limited by unclear applicability (many enrolled participants from emergency department settings) and imprecise results. Populations enrolled from emergency department settings may be more likely to include participants with acute injuries or other symptoms that may be related to abuse (Appendix A). Few tools were assessed by more than one study. We included only studies that compared an existing tool with a gold standard (and not studies comparing two different screening tools); this resulted in the exclusion of approximately nine studies from the 2004 and 2013 reviews for the USPSTF that did not include an appropriate reference standard (Appendix D).

RCTs of IPV interventions (KQ 4) were limited by overall attrition (20% or higher in 7 of 11 RCTs), potential measurement bias (e.g., recall bias or variation in comfort with self-reported measures of violence frequency/severity), and heterogeneity in outcome reporting (particularly for IPV outcomes). Usual care and use of a co-intervention (e.g., provision of an IPV resource sheet) in control groups varied across screening and intervention studies and was sometimes not described. Whether offering an information card or list of resources to women constitutes an active intervention is not clear; although it could lead to an inability to measure differences between intervention and control groups if women do change their behavior and seek services, one large screening RCT found no difference in outcomes between women who were provided a list of partner violence resources and those who were not. Finally, three studies were conducted in other countries (one in Australia and two in Hong Kong); the applicability of these studies to women in the United States may be limited by differences in cultural, social, and other factors. Studies of screening older and vulnerable adults for abuse and neglect were lacking. We identified only one study (of test accuracy) specific to elder abuse and no studies relevant to vulnerable adults.

## Future Research Needs

Future studies could assess whether screening specific groups of women (e.g., pregnant women) results in improve health outcomes. The included RCTs of screening enrolled women of childbearing age, but none enrolled women from prenatal settings only or reported outcomes among women who were screened during prenatal care. Few studies with a control group assessed potential harms of screening; harms, such as labeling or increased abuse, may not be apparent until weeks or months following an initial screening visit. Future studies that assess screening should report on potential harms over a sufficient period of time following screening to assess potential psychosocial harms. Although one RCT assessing a behavioral counseling intervention during prenatal care found benefit for reducing both IPV and some adverse neonatal outcomes, it is not clear whether results are consistent across other populations or whether the benefit was attributable to the IPV counseling component alone versus counseling for IPV and other co-occurring risk factors (e.g., smoking or depression) at the same time. Future studies could assess whether similar behavioral counseling interventions for pregnant women with screen-detected IPV improve health outcomes. Finally, future research is needed to assess the accuracy of screening tools in men, as well as the benefit and harms of interventions for men with IPV.

Studies are needed to improve research for screening older and vulnerable adults for abuse and neglect. No RCTs of screening or interventions have been done. Studies of screening instruments are lacking. Screening and interventions for this population are likely to be different than IPV given that some older and vulnerable adults may not have sufficient physical, mental, or financial abilities to engage in screening or interventions. For these situations, instruments could be targeted toward caregivers. Additional challenges to this research may include the legal requirements related to disclosure, underlying medical conditions of patients (e.g., cognitive impairments for older persons), and dependence on the perpetrator for caregiving and access to medical care, among other issues.

## Conclusions

Although available screening tools may reasonably identify women experiencing past 12-month or current IPV, RCTs of IPV screening in adult women do not show reduction in IPV or improvement in quality of life over 3 to 18 months of followup. Interventions for women with screen-detected IPV show inconsistent results; limited evidence from some RCTs suggested that home visiting interventions and behavioral counseling interventions that address multiple risk factors may lead to reduced IPV among perinatal populations. No eligible studies assessed screening or treatment for elder abuse and abuse of vulnerable adults.