# Chapter 3 Results

## Literature Search

We identified 3,263 unique titles and abstracts and assessed 373 full-text articles for eligibility (Figure 3). We excluded 348 articles for various reasons detailed in Appendix C and included 30 published studies (34 articles) of good or fair quality. Of the included studies, three (four articles) addressed KQ 1, and two of these also reported on harms (KQ 3). Fifteen studies were included that examined IPV test accuracy (KQ 2). Eleven studies (14 articles) were identified that focused on the benefits of IPV interventions (KQ 4), and five of these also reported on harms. We identified one KQ 2 study of elder abuse test accuracy. We identified no eligible KQ 1 (direct evidence of screening), KQ 3 (harms of screening), KQ 4 (benefits of intervention), or KQ 5 (harms of intervention) studies that addressed elder abuse or abuse of vulnerable adults. Details of quality assessments of included studies and studies excluded because of poor quality are provided in Appendix E.

Figure 3 Summary of Evidence Search and Selection Diagram

Abbreviations: KQ=key question; IPV=intimate partner violence; NIH=National Institutes of Health; WHO ICTRP: World Health Organization International Clinical Trials Registry Platform.

Figure 3 is a flow chart that summarizes the search and selection of articles. 4,190 records were identified through database searching, including 3,422 records from PubMed, 130 records from the Cochrane Library, and 638 records from Embase. 177 additional records were identified through other sources, including 34 records from ClinicalTrials.gov, 11 records from HSRProj, 22 records from WHO ICTRP, 54 records from NIH Reporter, and 56 by hand-searching. After removal of duplicates, 3,263 titles and abstracts were screened for potential inclusion. Of these, 373 were deemed appropriate for full-text review to determine eligibility. After full-text review, 348 were excluded: 88 for ineligible publication type/not original research, 33 for ineligible population, 16 for ineligible screening, 10 for ineligible treatment, 45 for ineligible comparator, 55 for ineligible outcome, 63 for ineligible study design, 21 for ineligible setting, 6 for ineligible geographical setting, 1 was excluded by the previous review, 1 was irretrievable, and 9 for poor quality. 34 articles representing 30 studies were included in the systematic review. For the IPV KQs, 4 articles representing 3 studies were included for KQ1, 15 articles representing 15 studies were included for KQ2, 2 articles representing 2 studies were included for KQ3, 14 articles representing 11 studies were included for KQ4, and 6 articles representing 5 studies were included for KQ5. For the elderly or vulnerable adults KQs, 0 articles were included for KQ1, 1 article was included for KQ2, 0 articles were included for KQ3, 0 articles were included for KQ4, and 0 articles were included for KQ5.

## Results

### KQ1 Does Screening for Current, Past, or Increased Risk for IPV in Adults and Adolescents Reduce Exposure to IPV, Physical or Mental Morbidity, or Mortality?

#### Summary

Overall, consistent evidence from three RCTs (3,759 participants) found no benefit of screening adult women (mean ages 34 to 40 years) for IPV followed by brief counseling or referral. The three RCTs compared universal screening for IPV in a health care setting with no screening; one enrolled participants from 10 U.S. primary care clinics,^57^ one enrolled participants from a single New Zealand emergency department,^58^ and one enrolled participants from a variety of Canadian clinical settings (12 primary care sites, 11 emergency departments, and 3 OBGYN clinics).^59^ Prevalence of past-year IPV ranged from 12 to 18 percent across studies. Responses to positive screening results in the intervention group included brief education and referral options. The RCT set in U.S. primary care centers compared screening for IPV with two separate no-screen groups: one group received information on partner violence resources, and the other received no resource list;^57^ the other two trials compared in-person screening before a health care encounter with no screening. In the Canadian RCT, the control group was screened after a health care visit, and women screening positive in both groups were followed over time.

None of the three RCTs found statistically significant benefits associated with screening. The RCT set in U.S. primary care centers found similar rates of IPV among women randomized to screening (11%), receipt of a partner violence resource list (11%), and no resource list (9%) at 12 months. The two other RCTs found a small benefit associated with the intervention, however, differences between groups were not statistically significant. Two RCTs also measured QOL and found similar scores between women randomized to screening and no screening with no significant difference between groups;^57,^ ^59^ one of these (set in various Canadian healthcare settings) found an association between the intervention and improved depression and PTSD symptoms, however differences between groups were small and not statistically significant. We found no RCTs enrolling men or adolescents, and none focused on pregnant women or that reported outcomes separately by pregnancy status.

#### Characteristics of Included Trials

Three RCTs (described in 4 publications) compared universal screening for IPV in a health care setting with no screening (Table 1).^57–60^ All three trials enrolled only women; one study enrolled a minority of pregnant women (5%),^59^ and the other two did not comment on the proportion of participating women who were pregnant. Mean ages of enrolled women across studies ranged from 34 to 40 years. One trial limited enrollment to women who had a male partner within the past 12 months;^59^ the other two did not comment on whether participants had male or same-sex partners, and no studies commented on the proportion of study participants who identified as LGBTQ. One trial enrolled a majority of nonwhite participants,^57^ one enrolled a majority of white participants,^58^ and the third did not comment on race or ethnicity.^59^ Trials were conducted in the United States,^57^ New Zealand,^58^ and Canada.^59^ The recruitment setting of included trials also varied; one trial enrolled participants from 10 primary care clinics,^57^ one enrolled participants from a single emergency department,^58^ and one cluster RCT enrolled participants from a variety of clinical settings (12 primary care sites, 11 emergency departments, and 3 OBGYN clinics).^59^ Prevalence of past-year IPV ranged from 12 to 18 percent across studies.

Table 1 IPV KQ1: Characteristics of Included Randomized, Controlled Trials

Author, Year Quality | Description of Screening Intervention | Description of Comparison(s) | Recruitment Setting, Country | Source Population | N | % Non-white | Mean Age (SD), Range | % With Past-Year IPV
Klevens et al, 2012^57,^ ^60^ Good | Computerized screening (3-item Partner Violence Screen); women with a positive response to ≥1 question were shown a brief video providing support, information about a hospital-based IPV advocacy program and encouraged to seek help; they were also given a printout with resources (e.g., local partner violence advocacy programs, 24-hour hotlines, women’s shelters) | IPV resource list (no screening, all women received an IPV resource list) Control group: No screening, no-partner violence list control group | 10 primary health care clinics, U.S. | Women ≥18 years seeking clinical services who could be separated from a partner or child >3 years | 2,708 | 94.6 | 38.7 (14.9) NR | 15^*^
Koziol-McLain et al, 2010^58^ Fair | In-person screening (3-item Intimate Partner Violence screen conducted by a research assistant); if ≥1 positive response) women received a brief^†^ statement about the unacceptability of violence, were asked additional questions about safety, and received information about referral options. Women with a positive response to safety questions^‡^ had additional services while in the ED | Usual care (no formal ED IPV screening policy) | 1 ED, New Zealand | Women ≥16 presenting to the ED for care; 19% of included sample were presenting for an acute injury | 344 | 39.6^§^ | Median: 40 (IQR: 27–59) 16–94 | 18 (Lifetime prevalence: 51%)
MacMillan et al, 2009^59^ Fair | In-person screening (8-item Woman Abuse Screening Tool) before clinic visit, clinician notification of women who screened positive;^‖^ all women were given a card that listed contact information of local agencies and hotlines for women exposed to violence | No screening before health care visit (screening completed after the clinic visit); at enrollment, women received the same resource card as the screening group | 12 primary care sites; 11 EDs; and 3 OBGYN clinics, Canada | Women 18 to 64 years, had a male partner within the last 12 months and could be separated from those accompanying them | 707 | NR | 34 (NR) 18–64 | 12

* Prevalence refers to the year before enrollment and based on recall at 12 months after enrollment. Measured using 18 questions from the National Violence Against Women survey.

† Estimate based on a questionnaire descrbed by authors as a compilation of the Partner Violence Screen and Abuse Assessment Screen and asks about current (past-year) abuse. Considered positive if one of three questions was answered positively.

‡ Women who screened positive were asked questions about personal danger or children/elderly in the home who are in danger. If questions indicated a safety concern, the ED provider was notified and a referral was made to the hospital social worker or community specialist.

§ Refers to the percentage who were Mari or non-New Zealand European.

‖ The completed screening questionnaire was placed in the chart. Any discussion of the positive finding was left to the discretion of the treating clinician.

Abbreviations: ED=emergency department; KQ=key question; IPV=intimate partner violence; IQR=interquartile ratio; NR=not reported; OBGYN=obstetrics and gynecology; U.S.=United States.

All included studies assessed the benefit of universal screening for IPV (regardless of participant reason for seeking medical care) followed by a brief intervention or referral for screen positive women; no studies described the number of participants who were presenting with health complaints specific to violence. In the one RCT enrolling participants from an emergency department, 20 percent of enrolled women were presenting with an acute injury (not otherwise characterized).^58^ All RCTs used screening tools designed to identify women who had experienced any IPV within the past 12 months. Two studies used the 3-item PVS^57,^ ^58^ (one study administered the tool via a computer,^57^ and the other administered the tool in person via a research assistant),^58^ and one study used the eight-item WAST.^59^

All RCTs compared screening to no formal screening; in two studies, the control group received a list or card with partner violence resources.^57,^ ^59^ The RCT set in U.S. primary care centers compared screening for IPV with two separate no-screen groups: one group received information on partner violence resources, and the other received no resource list.^57^ Responses to positive screening tests varied across trials. In the RCT set in U.S. primary care centers, women who screened positive for IPV were immediately shown a short video providing support and information about a hospital-based partner violence advocacy program and were encouraged to seek help and also received a printout with local partner violence resources.^57^ The RCT set in a New Zealand emergency department conducted in-person screening (by a research assistant); women who screened positive were given information about referral options and an additional clinical assessment was conducted to assess safety.^58^ If women responded positively to questions about safety (concern about their own safety or that of children in their home), additional on-site support included notification of their emergency department care provider and hospital social worker.^58^ In the RCT conducted in a variety of Canadian healthcare settings, clinicians caring for women who screened positive for IPV were alerted before the encounter by placing the completed WAST screening tool in the chart; discussion of the positive findings, referrals, or treatment was left to the discretion of the treating clinician.^59^ In the same RCT, all women completed the CAS after the clinic visit; women not randomized to screening completed both the WAST and CAS at the end of their visit. Women with positive scores on both the WAST and CAS (screened and nonscreened groups) were followed for 18 months (at baseline and again at 6, 12, and 18 months).^59^

Two RCTs were rated as fair and one was rated as good (Appendix E Table 1). One RCT had high overall attrition (42%), but low differential attrition and missing data was accounted for using multiple imputation.^59^ However, women lost to followup had lower levels of education, higher scores on the WAST and CAS, and were more likely to be married compared with women retained in the trial.^59^ This same trial also had low fidelity; less than half of screen-positive women (44%) reported discussing IPV with their clinicians during their clinic visit.^59^ Rates of attrition in the other two RCTs ranged from 13 to 14 percent overall (with no significant differential attrition); the RCT set in U.S. primary care settings addressed missing data using multiple imputation the trial set in a New Zealand emergency department analyzed completers only.

#### Results of Included Trials

##### IPV

All included RCTs reported on rates of IPV following the screening intervention; however, specific measures and outcome timings varied across studies. Despite heterogeneity across studies, no study found a significant reduction in IPV among the screened group compared to a non-screened control group (Figure 4).^57–60^

Figure 4 Benefit of IPV Screening Interventions for Reducing IPV Exposure (KQ1)

Abbreviations: CAS=Composite Abuse Scale (30-items); Cl=confidence interval; IPV=intimate partner violence; N=same size; NVAW=National Violence Against Women Survey (18-items); No.=number; OR=odds ratio.

Figure 4 displays a forest plot stratified by three studies (Klevens, 2010; Koziol-McLain, 2010; and MacMillian, 2009) assessing the benefit of IPV screening interventions on reducing IPV exposure. Klevens reported that women randomized to the screened and control groups had a similar incidence of partner violence at 1 year; similarly, women randomized to the screened group and partner violence resource list-only arm had a similar rate of partner violence. Koziol-McLain reported an association between the intervention and reduced IPV exposure; however, results were not statistically significant. MacMillian reported an association between the intervention and reduced IPV recurrence but results were not statistically significant and confidence intervals were wide.

The RCT conducted exclusively in U.S. primary care settings (N=2,708) measured the occurrence of any partner violence events 1 year after screening among women randomized to three groups: screening (plus provision of a partner violence resource list), partner violence resource only, and a control (no screening or provision of a resource list). Outcomes were measured using 18 questions adapted from the National Violence Against Women Survey^61^ specific to psychological, physical, and sexual violence.^57^ A positive response to any question was considered as experiencing partner violence (i.e., counted as an event). Women randomized to the screened group and control group had a similar incidence of partner violence at 1 year (odds ratio [OR], 1.2; 95% CI, 0.7 to 2.2); similarly, women randomized to the screened group and partner violence resource list only arm had a similar rate of partner violence (OR, 1.0; 95% CI, 0.8 to 1.4).^57^ This RCT also assessed IPV recurrence among the subgroup of women reporting IPV before enrollment; rates of recurrence were similar between the screened and control groups (OR, 1.2; 95% CI, 0.7 to 2.2) and between the screened and partner violence resource list group (OR, 0.8; 95% CI, 0.5 to 1.4).^57^

The two other included RCTs measured rates of IPV using the CAS, and both reported on the number of participants in each group with a positive CAS score (≥7, range 0 to 150).^58,^ ^59^ The RCT conducted in a variety of Canadian health care settings (N=707 participants) reported on outcomes only among the subgroup of women in the screening and control arms who screened positive on the WAST and CAS at baseline. Recurrence of IPV was assessed at 6, 12, and 18 months (Figure 4); at each time point, controlling for missing data using multiple imputation, there was an association between the intervention and lower IPV recurrence but results were not statistically significant and confidence intervals were wide (OR, 0.88; 95% CI, 0.43 to 1.82 at 18 months).^59^ The trial enrolling women from one New Zealand emergency department (N=344) measured outcomes in all participants at 3 months (regardless of baseline screening results); the study found an association between the intervention and lower risk of IPV; however, results were not statistically significant (OR, 0.86; 95% CI, 0.39 to 1.92).^58^

##### Quality of Life

Two included RCTs reported on quality of life (Figure 5): the study conducted in U.S. primary care settings^57^ and the study conducted in a variety of Canadian health care settings.^59^ Both measured quality of life using the 12-Item Short For Survey (SF-12), and neither found a statistically significant difference between groups over 6 to 18 months of followup; scores were similar with less than a 2 point difference across all comparisons and outcome timings. One RCT also measured quality of life using the WHOQOL-Bref scale; scores were slightly lower in the screened group than controls (by 1 to 2 points) at 6, 12, or 18 months and differences were not statistically significant.^59^ The RCT conducted in U.S. primary care settings found no difference between 3 arms (screening group, partner violence resource group, and control group) and found similar SF-12 scores at 1 year in the subgroup of women reporting IPV at enrollment Appendix G Table 1.^57^

Figure 5 Benefit of IPV Screening Interventions for Improving Quality of Life and Depression (KQ1)

Abbreviations: CES-D=Center for Epidemiologic Studies Depression scale; CI=confidence interval; MCS=Mental Composite Score; N=sample size; PCS=Physical Composite Score; SF-12=Short Form Health Survey-12 Item;; WHOQOL-Bref=World Health Organization Quality of Life-Bref instrument.

Figure 5 displays a forest plot stratified by measure (SF-12 MCS, SF-12 PCS, WHO-QOL-Bref, and Depression [CES-D]) assessing the benefit of IPV screening interventions on quality of life and depression over 6-, 12-, and 18-month followup. Two studies (Klevens and MacMillian) reported mean differences ranging from 0.10 to 1.05 for quality of life (measured by SF-12 MCS) comparing screening to control. Two studies (Klevens and MacMillian) reported mean differences ranging from −0.50 to 1.57 for quality of life (measured by SF-12 PCS) comparing screening to control. One study (MacMillian) reported mean differences ranging from 1.32 to 2.29 for quality of life (measured by WHO-QOL-Bref) comparing screening to control. One study (MacMillian) reported mean differences ranging from 1.14 to 1.97 for depression (measured by CES-D) comparing screening to control.

##### Mental Health Outcomes

One RCT (enrolling women from a variety of Canadian health care settings) reported on PTSD and depression outcomes (Figure 5).^59^ There were no statistically significant differences between screened and control groups on the Center for Epidemiologic Studies Depression Scale at any time point; estimates favored the screening group, but results were imprecise and differences in scores between groups were small (18-month mean difference between groups: ‑1.97; 95% CI, −4.33 to 0.39).^59^ PTSD was measured using the 4-item SPAN screening tool; there was not a statistically significant difference between screened and nonscreened groups at any time point (Appendix G Table 1).

##### Health Care Utilization Outcomes

One RCT enrolling women from U.S. primary care settings reported on rates of health care utilization (not specific to use of IPV intervention services) (Appendix G Table 1).^57^ Rates of emergency department utilization and visits with a family physician, nurse, or nurse practitioner were similar for screened and nonscreened groups at 1 and 3 years.^57^

### KQ2 What Is the Accuracy of Screening Questionnaires or Tools for Identifying Adults and Adolescents With Current, Past, or Increased Risk for IPV?

#### Summary

We included 15 fair-quality studies (4,460 participants) assessing the accuracy of 12 different IPV screening tools. All studies enrolled adults, and most enrolled only women or a majority of women; one study included only men.^62^ The recruitment settings varied across the studies: five recruited from emergency departments,^62–65^ four from primary care practices,^66–69^ one from urgent care,^70^ and three recruited women by telephone or mail survey.^71–73^ Most assessed a tool designed to identify persons experiencing IPV within the past year; however, four studies reported on the accuracy of five tools for identifying current (ongoing) abuse, one assessed the accuracy of detecting lifetime abuse, and one assessed the accuracy of a tool for predicting future (3- to 5-month abuse). Five studies reported on the accuracy of five different screeners (HARK, HITS, E-HITS, PVS, and WAST) for detecting any past-year IPV in adult women; sensitivity ranged from 65 to 87 percent, and specificity ranged between 80 and 95 percent. Most were assessed by only one study; the HITS was assessed in two studies (both enrolling women veterans), one of which also evaluated a modified version of the HITS (Extended HITS [E-HITS]). Estimates for accuracy of HITS and E-HITS were generally consistent but imprecise with sensitivity ranging from 75 to 78 percent and specificity ranging from 80 to 83 percent. One study enrolling men only from an emergency department reported on the accuracy of the PVS and HITS for detecting past-year IPV; sensitivities were low for both PVS and HITS for detecting psychological abuse (30% and 35%, respectively) and for detecting physical abuse (46% for both tools).^62^ Four studies reported on the accuracy of five tools for identifying ongoing or current abuse;^63,^ ^69,^ ^70,^ ^74^ across all studies, accuracy varied widely (sensitivity 46% to 94%, specificity 38% to 95%). Only one tool, the OVAT, had a sensitivity and specificity greater than 80 percent (86% and 83%, respectively) compared with the ISA.

#### Characteristics of Included Studies

We included 15 fair-quality studies assessing the accuracy of a total of 12 screening tools for IPV (Table 2).^62–72,^ ^74–76^ Ten studies^62,^ ^63,^ ^65–70,^ ^73–76^ were in the USPSTF 2012 review,^45^ and one study^64^ was included in the 2004 review.^51^

Table 2 IPV KQ2: Characteristics of Included Studies

Author, Year Quality | Screener(s) | Timing of IPV Exposure | Population N | Recruitment Setting Country | Age in Yrs, Mean (SD), Range | % Female | % Pregnant | % Non-white
Chen et al, 2005^66^ Fair | HITS | Current | Women ≥18 years, predominantly Hispanic, currently involved with a partner n=113 | Family practice clinics U.S. | 36 (NR) Range: NR | 100 | 9 | 64
Dubowitz et al, 2007^67^ Fair | PSQ | Past year | English-speaking adult caregivers with a child <6 years seen for a well-child visit n=200 | Pediatric primary care clinic U.S. | Median: 24 Range NR | 94 (mothers) | NR | NR
Ernst et al, 2004^63^ Fair | OVAT | Current | English-speaking patients at the ED n=306 | ED U.S. | 34 (10) Range: NR | 70 | NR | 51
Feldhaus et al, 1997^64^ Fair | PVS | Past year | English-speaking women ≥18 years at ED who were noncritical ISA, n=255 CTS, n=230 | ED U.S. | 36 (16) Range: NR | 100 | NR | 55
Iverson et al, 2013^71^ Fair | HITS | Past year | Female veterans ≥18 yrs. found through VHA database and who reported an intimate relationship in past year. n=160 | Mailed survey U.S. | 48 (NR) Range: NR | 100 | NR | 20
Iverson et al, 2015^72^ Fair | HITS E-HITS | Past year | Female veterans ≥18 yrs. found through VHA database and who reported an intimate relationship within the past year n=80 | Mailed survey U.S. | 49 (NR) Range: NR | 100 | NR | 14
Koziol-McLain et al, 2001^73^ Fair | BRFSS (violence screen) | Prediction of future (3–5 months) partner abuse | English-speaking women ≥18 years n=409 | Telephone survey U.S. | 46 (16) 18 to 93 | 100 | NR | 9
MacMillan et al, 2006^75^ Fair | PVS WAST | Past year | English-speaking (and reading) women 18–64 years presenting for their own health care visit not too ill to participate n=Unclear; 2,339 completed the gold standard CAS | 2 family practices, 2 EDs, and 2 women’s health clinics Canada | 37 (12) Range: NR | 100 | NR | NR
Mills et al, 2006^62^ Fair | HITS PVS | Past year | Men ≥18 yrs. in the ED who were triaged to the medical or trauma sections n=53 | ED U.S. | 40 (11) 20–62 | 0 | NA | 78
Paranjape et al, 2003^65^ Fair | STaT | Lifetime | English-speaking women 18–64 yrs. In the non-acute section of ED n=75 | ED U.S. | 36 (10) Range: NR | 100 | NR | 66
Paranjape et al, 2006^70^ Fair | STaT | Current or most recent relationship | English-speaking women 18–65 yrs. n=240 | Urgent care U.S. | 38 (10) Range: NR | 100 | NR | ≥ 91^*^
Sohal et al, 2007^68^ Fair | HARK | Past year | Women ≥17 yrs. who had been in an intimate relationship in the last year n=232 | General practice waiting rooms U.K. | 35 (NR) 18–70 | 100 | NR | 60
Wathen et al, 2008^76^ Fair | WAST | Past year | English-speaking (and reading) women 18–64 yrs. with a male partner in the last year n=5,604 | Primary, acute, and specialty care centers Canada | Overall NR Range: NR Screen group: 39 (NR) Range: NR | 100 | Overall: NR Screen group: 8 | NR
Weiss et al, 2003^74^ Fair | OAS AAS | Current | ED patients with a current partner who were not too ill to participate (due to trauma, drug overdose, alcohol intoxication, or other condition) n=856 | ED U.S. | 36 (NR) Range: NR | 62 | NR | 49
Zink et al, 2007^69^ Fair | Unnamed^†^ | Current | English-speaking mothers in a relationship with a steady partner for ≥ 1 year and at least 1 child 3–12 yrs. n=393 | Pediatric and family medicine clinics U.S. | Median: 31 Range: 18–58 | 100 | NR | 51

* Only African American reported

† Five-item unnamed screener designed to assess relationship quality and safety using nongraphic language.

Abbreviations: AAS=Abuse Assessment Screen; BRFSS=Behavioral Risk Factor Surveillance System; CAS=Composite Abuse Scale; CTS=Conflict Tactics Scale; CTS-2=Conflict Tactics Scale-2; ED=emergency department; HARK=Humiliation, Afraid, Rape, Kick; HITS=Hurt/Insult/Threaten/Scream Tool; E-HITS=Electronic HITS; IPV=intimate partner violence; ISA=Index of Spouse Abuse; KQ=key question; N/n=sample size; NR=not reported; OAS=Ongoing Abuse Screen; OVAT=Ongoing Violence Assessment Tool; PSQ=Parent Screening Questionnaire; PVS=Partner Violence Screen; SD=standard deviation; STaT=Slapped, Things, Threaten; U.S.=United States; WAST=Woman Abuse Screening Tool.

Of the 13 studies that reported the minimum age of participants, one included participants as young as 17 years of age;^68^ the remainder included only adults (age 18 years or older). One study enrolled parents without age specified,^67^ and one included no information on age of participants.^74^ One of the studies was limited to men,^62^ and three included a minority of men (6% to 38%);^63,^ ^67,^ ^74^ the rest included only women.^64–66,^ ^68–73,^ ^75,^ ^76^ None of the studies were focused on pregnant women, and only two studies reported on the percentage of women who were pregnant (8% to 9%^66,^ ^76^). Two studies focused on women veterans.^71,^ ^72^ All but three studies^67,^ ^75,^ ^76^ reported race/ethnicity. The range of nonwhite participants was 9 percent to 78 percent; one study reported that the percentage of African Americans was 91 percent.^70^ No studies reported on the percentage of partners who were the same sex as the respondent.

The recruitment settings varied across the studies: five recruited from emergency departments,^62–65^ four from primary care practices,^66–69^ one from urgent care,^70^ and three recruited women by telephone or mail survey.^71–73^ None of the studies recruiting from emergency departments explicitly excluded participants with injuries that would be indicative of abuse, although most studies did exclude participants who were too ill to participate or who needed immediate medical attention. Two studies were set in Canada,^75,^ ^76^ and one was set in the United Kingdom.^68^ The remainder were conducted in the United States. Sample sizes ranged from 53 to 5,604 across included studies, with a median size of 232.

Across all included studies, 12 different screeners were assessed: AAS; BRFSS; HARK screener; HITS screener; E-HITS; OAS; OVAT; Parent Screening Questionnaire (PSQ); PVS; Slapped, Things Threatened (STaT) screen; WAST; and an unnamed tool that includes five domestic violence screening questions with nongraphic language. Copies of the screeners are found in Appendix E; the tools contained between three and eight items, and all except the unnamed five question screener^69^ include specific questions about physical abuse (eight include questions about emotional/psychological abuse, and five include questions about sexual abuse and safety issues). Some of these tools were examined in multiple studies; however, in some studies assessing the same tool, the authors used different criteria for determining a positive screen. This is the case for studies that included the HITS^62,^ ^66,^ ^71^ and the WAST.^75,^ ^76^

Included studies used the following validated reference standards to establish screening test accuracy: CAS, CTS/Conflict Tactics Scale-2 (CTS-2), and ISA. One study^65^ used a semistructured interview as the gold standard to determine the presence of IPV. In a few studies, two reference standards were used to assess accuracy of the screener. Although the CAS, CTS/CTS-2, and ISA each provide scale scores for different types of IPV (e.g., physical, psychological), as well as an overall classification of IPV, most studies included only the overall measure of IPV. When authors only provided results for specific categories of abuse, we included those data in Appendix G Table 2.

Prevalence of current or recent IPV, as measured by the reference standards, ranged from 11 to 29 percent with a median of 24 percent; two studies^62,^ ^67^ reported prevalence for IPV subtypes only (Appendix G Table 2). Most screeners were designed to measure whether a participant was experiencing IPV within the past year or in the context of a current relationship. However, one study assessed the accuracy of the STaT for detecting lifetime abuse,^65^ and one assessed the accuracy of a three-item tool for predicting future (3- to 5-month abuse).^73^

All 15 studies were rated fair quality. Most screeners were assessed by only one study. Methodological limitations included exclusion of missing data or unclear handling of missing data; few studies noted the number of participants excluded because of incomplete data, although one study noted that 19 percent of women did not complete one or more questionnaires.^74^ Studies assessing the same screener sometimes used different cut points to determine test positivity or determined positive scores on a reference standard using different criteria (Appendix G Table 2).

#### Results of Included Studies

##### Accuracy of Detecting Past-Year IPV

Seven studies reported on the accuracy of six different screeners (HARK, HITS, E-HITS, PVS, PSQ, and WAST) for detecting past-year IPV (Appendix G Table 2).^62,^ ^64,^ ^67,^ ^68,^ ^71,^ ^72,^ ^76^ Of these, five studies enrolled only women (or a majority of women) and reported on accuracy of a tool for detecting any type of past-year IPV; across all screeners, sensitivity ranged from 65 to 87 percent, and specificity ranged between 80 and 95 percent (Figure 6). Three screeners (WAST, HARK, and PVS) were assessed by only one study; the HITS was assessed in two study populations (both women veterans) along with a modified version of the HITS (E-HITS). The largest study (N=5,605) evaluated the WAST in a population of women enrolled from mixed clinical settings and found a sensitivity of 87 percent (95% CI, 85 to 90) and specificity of 89 percent (95% CI, 88 to 90) compared with the reference standard (CAS).^76^ One study enrolling women from primary care (N=232) assessed the accuracy of HARK compared with the CAS; sensitivity was 81 percent (95% CI, 0.69 to 0.90) and specificity was 95 percent (95% CI, 91 to 98).^77^ One study enrolling women from an emergency department evaluated the accuracy of the PVS against two different gold standards (the CTS and ISA); results were similar with estimates of sensitivity ranging from 64 to 71 percent and specificity ranging from 80 to 84 percent.^64^ Two studies (both enrolling women veterans) assessed the accuracy of HITS, and one assessed the accuracy of E-HITS; estimates were generally consistent but imprecise (Figure 6), with sensitivity ranging from 75 to 78 percent and specificity ranging from 80 to 83 percent (Figure 6).

Figure 6 Accuracy of IPV Screening Tools for Detecting Past-Year or Current IPV Exposure (KQ2)

Abbreviations: AAS=Abuse Assessment Screen; CAS=Composite Abuse Scale; CI=confidence interval; CTS=Conflict Tactics Scale; CTS-2=Conflict Tactics Scale 2; E-HITS=Extended - Hurt, Insulted, Threaten, Scream; ER=emergency room; HARK=Humiliation, Afraid, Rape, Kick; HITS=Hurt, Insulted, Threaten, Scream; ISA=Index of Spouse Abuse; OAS=Ongoing Abuse Screen; OVAT=Ongoing Violence Assessment Tool; PVS=Partner Violence Screen; VA=Veterans Administration; WAST=Woman Abuse Screening Tool.

Figure 6 displays the sensitivity and specificity of five studies that evaluated the accuracy of five different screening tools (HARK, HITS, E-HITS, PVS, and WAST) for detecting any past-year IPV in adult women. Sensitivity ranged from 65% to 87% and specificity ranged from 80% to 95%. The figure also displays the sensitivity and specificity of five studies that evaluated the accuracy of screening tools for identifying ongoing or current relationship violence. Of these, four studies reported on the accuracy of detecting any category of IPV. Accuracy varied widely; sensitivity ranged from 46% to 94%, and specificity ranged from 38% to 95%. Only one tool, OVAT, had a sensitivity and specificity greater than 80%.

One study enrolling mostly women reported on the accuracy of a tool for detecting past-year subcategories of violence only.^67^ The study enrolled adult caregivers from a pediatric primary care clinic (N=200, 94% mothers) and assessed the accuracy of the PSQ; results were reported for subtypes of violence only. Compared with the CTS-2, the tool had poor sensitivity for detecting physical assault (19%), injury (29%), and psychological aggression (27%); specificity was higher (>90%) for all three subtypes of violence.

One study enrolling men only (N=53) from an emergency department reported on the accuracy of the PVS in detecting past-year IPV (Appendix G Table 2). This study examined the accuracy of both the HITS and PVS compared with the CTS-2 scores for physical and psychological abuse; sensitivities were low for both PVS and HITS for detecting psychological abuse (30% and 35%, respectively) and for detecting physical abuse (46% for both tools).^62^

##### Accuracy of Detecting Current (Ongoing) IPV

Five studies reported on the accuracy of a tool in identifying ongoing or current relationship violence.^63,^ ^66,^ ^69,^ ^70,^ ^74^ Of these, four reported on the accuracy of a tool for detecting any category of IPV.^63,^ ^69,^ ^70,^ ^74^ As shown in Figure 6, accuracy varied widely; sensitivity ranged from 46 to 94 percent, and specificity ranged from 38 to 95 percent. Only one tool, the OVAT, had a sensitivity and specificity greater than 80 percent (86% and 83%, respectively).^63^ One study (N=113) assessed the accuracy of HITS for detecting physical abuse only compared with the ISA-P; among women enrolled from a primary care setting, HITS had a sensitivity of 86 percent and a specificity of 99 percent.^66^

##### Accuracy for Predicting Future Abuse

One study (N=409) evaluated the accuracy of a three-item tool for predicting future partner abuse.^73^ The unnamed tool is derived from questions administered in the Colorado BRFSS; the full tool is shown in Appendix E. At baseline, 24 percent of the sample reported partner abuse (verbal, sexual, or physical) on the CTS. The sensitivity and specificity for predicting IPV over 3 to 5 months was 20 percent (95% CI, 13 to 30) and 96 percent (95% CI, 93 to 98), respectively.^73^

##### Accuracy of Detecting Lifetime IPV

One study evaluated the accuracy of the STaT tool for detecting lifetime occurrence of IPV among women presenting to an urgent care center.^65^ Using the recommended cut point of at least one endorsed item on the STaT, sensitivity was high (95%) but specificity was low (37%) compared with the ISA.

### KQ3 What Are the Harms of Screening for IPV in Adults and Adolescents?

#### Characteristics of Included Studies

We included two fair-quality RCTs reporting on harms of screening;^58,^ ^59^ both were included in KQ 1 (benefits of screening). Study characteristics are described in detail under KQ 1 and shown in Table 1. Both RCTs enrolled only adult women; one (N=399)^58^ enrolled women presenting to an emergency department of a New Zealand hospital for nonacute care, and the other trial (N=591) enrolled women presenting for their own health care at various settings (12 primary care sites, 11 emergency departments, and 3 OBGYN clinics).^59^ Our study design criteria for harms of screening (Appendix B2) included RCTs and prospective cohort studies with a concurrent control group; we did not identify any cohort studies meeting our full eligibility criteria.

#### Results of Included Studies

In one RCT, authors developed a specific tool, the Consequences of Screening Tool (COST),^78^ to measure the consequences of IPV screening.^59^ The COST questions included an eight-item Effects on Quality of Life subscale that applies to women who received the screening intervention regardless of their abuse status; items are scored on a 5-point scale from two to minus two (range 16 to −16), with negative scores reflecting harm. The full questionnaire is shown in Appendix E. Example questions from the COST tool include the following: “Because the questions on partner violence were asked, I feel my home life has become (less difficult … more difficult)”; “Because the questions on partner violence were asked, I see the quality of my own life as being (better … worse); “Because the questions on partner violence were asked, I feel that the problems in my relationship with my partner are my fault” (disagree … agree); and “Because the questions on partner violence were asked, my financial situation has become (better … worse).” Results of scores were not reported in the main trial; however, the authors of another systematic review obtained and reported unpublished data from the RCT authors.^79^ The COST was administered to a subset of 591 women out of 3,271 screened (227 women who screened positive for abuse, 206 with mixed screen results, and 158 who screened negative). At baseline (within 14 days of being screened), the mean score on the eight-item Effects on Quality of Life subscale was 3.52 (standard deviation [SD] 3.24), indicating that being asked IPV screening questions was not harmful to women immediately after screening. Scores were similar across abuse groups; the mean scores were 3.7 (SD 3.2) for women who scored negative on both the WAST and CAS, 3.3 (SD 3.3) for those who had mixed results, and 3.5 (SD 3.4) for those who scored positive on both measures.^79^ Harms were not assessed beyond the baseline visit.^59^

The second trial reported that no adverse events were reported by participants, clinicians or research staff; however, it is not clear whether adverse events were prespecified or how they were monitored.^58^

### KQ4 How Well Do Interventions Reduce Exposure to IPV, Physical or Mental Morbidity, or Mortality Among Screen-Detected Adults and Adolescents With Current, Past, or Increased Risk for IPV?

#### Summary

Eleven RCTs (6,740 participants) evaluated an IPV intervention among adult women with screen-detected IPV or who were considered at risk for IPV; overall, results were imprecise and often inconsistent. Five RCTs enrolled women during the perinatal period; all reported on IPV outcomes. Two home-visiting interventions^80,^ ^81^ found lower rates of IPV among women assigned to the intervention group compared with controls; however, the difference between groups was small (standardized mean difference [SMD] −0.04 and −0.34), results were imprecise, and only one found a statistically significant difference (SMD −0.34; 95% CI, −0.59 to −0.08).^81^ Three RCTs enrolling pregnant women with screen-detected IPV evaluated a counseling intervention, two found benefit in favor of the intervention^82,^ ^83^ and one found an association between the intervention and higher rates of IPV, although results were not statistically significant (SMD 0.22; 95% CI, −0.37 to 0.80).^84^ One of the counseling trials that found benefit in favor of the intervention only reported on subtypes of violence; the benefit was significant for some subtypes of violence (psychological and minor physical abuse) but not others (severe physical and sexual abuse).^83^ One RCT evaluating a brief prenatal counseling intervention reported on SF-36 subdomains and found mixed results (significant improvement in some subdomains, no difference in others, and significant worse scores for bodily pain).^83^ One RCT assessing an integrated behavioral counseling intervention for women with one or more risk factors (smoking, environmental tobacco smoke exposure, depression and IPV) reported on birth outcomes among the subgroup who had IPV at baseline (N=306); there was no significant difference between groups in rates of low birth weight neonates (<2,500 g), very low birth weight neonates (<1,500 g) or preterm birth (<37 weeks); however, significantly fewer women in the intervention group had very preterm neonates (≤33 weeks) (2 vs. 9 women; p=0.03).^85^ Many women with IPV at baseline (62%) also screened positive for depression and received counseling for depression in addition to counseling for IPV; improvement in outcomes may be attributable to counseling for depression as opposed to IPV counseling. Two RCTs reported on depression and both found benefit in favor of the intervention (only one found a statistically significant benefit^83^); one of these also reported on PTSD symptoms and found similar scores in both groups.^84^

The six RCTs enrolling nonpregnant women all measured IPV incidence; four found no significant difference between groups in rates of overall IPV^86,^ ^87^ or combined physical and sexual violence;^88,^ ^89^ measures of IPV were either similar between groups or slightly higher in the intervention group. One trial reported on subtypes of violence only and found benefit for psychological aggression but not for physical assault or sexual coercion (scores were similar for both groups).^90^ Two RCTs measured changes in quality of life following an intervention for IPV; in both trials, scores were similar between intervention and control groups and differences were not statistically significant.^86,^ ^90^ Three RCTs reported on depression outcomes; two found benefit in favor of the intervention group (although one found a difference below the threshold considered clinically meaningful),^86,^ ^90^ and one found similar scores between groups.^91^ One RCT found no difference between groups in the percentage of women who had anxiety at 6 and 12 months; results slightly favored the intervention group, however the differences between groups were small and not statistically significant.^86^

#### Characteristics of Included Studies

Eleven good- or fair-quality RCTs reported in 14 publications met inclusion criteria.^80–86,^ ^88–94^ Four used cluster rather than parallel randomization designs;^81,^ ^86,^ ^88,^ ^89^ of these, two were clustered by clinic,^88,^ ^89^ one was clustered by physician,^86^ and one was clustered by home visiting program.^81^ Study characteristics are summarized in Table 3.

Table 3 IPV KQ4: Characteristics of Included Randomized, Controlled Trials

Author, Year Study Design Study Name Quality | Population | Intervention | Control | Recruitment Setting, Country | Source Population | Total N | % F | % Non-white | Mean Age (SD), Range
Blair-Merrit et al, 2010^80^ Fair | Pregnant/postpartum | Family-based intervention involving weekly home visits from paraprofessionals over 3 years;^*^ direct services related to parenting, conflict resolution, emotional support; linking families to community services as needed, including IPV shelters/advocacy groups | Usual care | Hawaiian hospitals U.S. | Mothers (≥18 years) who gave birth between 1994–1995 on Oahu to children rated as high risk for maltreatment | 643 | 100 | 88 | NR
El-Mohandes et al, 2008^82^ Kiely et al, 2010^85^ El-Mohandes et al, 2011^92^ Fair | Pregnant/postpartum | Individual cognitive behavioral intervention delivered during prenatal care visits (4–8 prenatal sessions and 2 postpartum sessions) aimed at reducing behavioral risks (depression, IPV, smoking, and tobacco exposure); sessions targeted toward specific risk factors based on prenatal screening | Usual care | 6 prenatal care sites in the District of Columbia U.S. | African American women ≥18 years, ≤28 weeks’ gestation and reporting any of four risk factors (including any IPV in year before pregnancy) | 913 | 100 | 100 | 25 (SE 0.2)
Hegarty et al, 2013^86^ Fair | Nonpregnant | Physician training to respond to women and deliver a brief IPV counseling intervention (1–6 sessions, depending on needs) | Usual care | Family practice clinics in Victoria Australia | Women (16–50 years of age) who screened positive for fear of their partner in the past 12 months^†^ | 272 (52 physicians) | 100 | NR | 38 (8)
Miller et al, 2011^89^ Fair | Nonpregnant | Clinician training to deliver enhanced IPV screening, education, and counseling for IPV/reproductive coercion and assistance contacting resources (one session during clinic visit) | Usual care^ǂ^ | 4 family planning clinics in Northern California U.S. | Women 16–29 years of age who agreed to a followup interview | 904 (4 clinics) | 100 | 77 | 16–20 years=44% 21–24 years=33% 25–29 years=24%
Miller et al, 2016^88^ Fair | Nonpregnant | Clinician and staff training (1/2 day) focused on IPV education, assessment, harm reduction counseling, and supported referrals to victims’ services. Discussion of IPV encouraged for all encounters, guided by palm-sized brochure (one session during clinic visit) | Usual care^§^ | 25 family planning clinics in Western Pennsylvania U.S. | Women 16–29 years of age who agreed to a followup interview | 3,540 (17 clinics) | 100 | 19 | 16–20 years=38% 21–24 years=36% 25–29 years=27%
Rhodes et al, 2015^87^ Fair | Nonpregnant | Brief motivational intervention, manual-guided (one session during ED visit, telephone booster 10 days later) | Assessed control No contact control | 2 affiliated urban academic EDs in Philadelphia, PA U.S. | Women 18–64 years who screened positive for IPV and heavy drinking | 592 | 100 | 82 | 32 (31–33) 18–64
Saftlas et al, 2014^91^ Fair | Nonpregnant | Motivational interviewing conducted by field coordinator (1 60-min in-person session at baseline; three 10- to 15-min telephone sessions at 1, 2, and 4 months post-enrollment) | Provision of written materials; referral to community-based resources on request | 2 family planning clinics in rural Iowa U.S. | Women ≥18 years who screened positive for past-year IPV (current partner) | 204 | 100 | 12 | NR
Sharps et al, 2016^81^ DOVE Trial Fair | Pregnant/postpartum | Brochure-based IPV empowerment intervention embedded into a home visiting program; tailored to a woman’s expressed needs and level of danger; three 15- to 25-min sessions during pregnancy and three postpartum sessions during home visits | Standard home- visiting protocol^‖^ | Urban and rural perinatal home-visiting programs U.S. | Women ≥14 years and ≤32 weeks’ gestation; low income (i.e., Medicaid eligible); enrolled in a perinatal home visiting program at a participating agency; screened positive for IPV (current or past partner) | 239 | 100 | 57 | 24.0 (5.2)
Tiwari et al, 2005^83^ Fair | Pregnant/postpartum | In-person counseling (single, 30-min session delivered by midwife counselor) focused on empowerment to enhance independence (advice in areas of safety, choice making, and problem solving), followed by brochure reinforcing information | Usual care (wallet sized card with community resources for abused women) | Public antenatal clinic Hong Kong | Women <30 weeks’ gestation who screened positive for abuse by a partner during their first antenatal appointment | 110 | 100 | NR | 28 (NR)
Tiwari et al, 2012^94^ Tiwari et al, 2010^90^ Good | Nonpregnant | Advocacy intervention, in-person interview, empowerment pamphlet, weekly telephone calls, 24-hour access to a hotline for additional support One 30-min session, followed by 12 weekly telephone calls (3 months and 9 months post-baseline) | Usual community care | Community center Hong Kong | Screened positive for IPV; ≥18, able to speak Cantonese or Putonghua | 200 | 100 | 100 | 38 (7) NR
Zlotnick et al, 2011^84^ Fair | Pregnant/postpartum | Individual counseling (based on Interpersonal psychotherapy); delivered over four 60-min sessions during pregnancy and one session within 2 weeks of delivery) | Control (educational materials and list of IPV resources) | Primary care and OBGYN clinics U.S. | Women (18–40 years) who screened positive for past-year IPV | 54 | 100 | 61 | 23.8 (4.6)

* Over the course of the intervention, 13.6 weekly visits occurred in year 1 (on average), tapering to 25% participation by year 3.

† Eligible physicians (for training) included those who worked ≥3 sessions per week, used electronic records, and ≥70% of their patients spoke English. Patients of eligible providers were mailed a survey regarding participant and screening for fear of partner.

ǂ Usual care described as two violence screening questions on clinic intake form and usual clinic protocol for positive disclosures during encounters.

§ Usual care described as standard IPV question on intake sheet and referral if IPV was discussed.

‖ Standard care includes assessment and referral for IPV during first home visit; during subsequent visits, discussion of perinatal IPV only if indication or if woman raises a concern.

Abbreviations: DOVE=Domestic Violence Enhanced Home Visitation Program; ED=emergency department; IPV=intimate partner violence; min=minute; N=sample size; NR=not reported; OBGYN=obstetrics and gynecology; SD=standard deviation; SE=standard error; U.S.=United States.

All included studies enrolled women only, five of these focused on women during the perinatal period.^80–84^ Among the eight studies conducted in the United States,^59,^ ^80–82,^ ^84,^ ^87–89,^ ^91^ the percentage of nonwhite participants varied, ranging from 75 percent or more in four studies,^80,^ ^82,^ ^87,^ ^89^ between 50 percent and 74 percent in three studies,^81,^ ^84,^ ^95^ and less than 50 percent in two studies.^88,^ ^91^ No study identified participants as LGBTQ. Studies conducted in countries other than the United States included one in Australia^86^ and two in Hong Kong.^83,^ ^90^

Included studies assessed heterogeneous interventions. Appendix G Table 4 shows a detailed summary of intervention components, delivery personnel, and intensity (e.g., number and length of sessions). Five RCTs enrolled women during the perinatal period who screened positive for IPV or were considered at risk;^80^ two assessed multiple home visits that included components to address IPV,^80,^ ^81^ and three assessed counseling interventions offered during one or more prenatal clinic visits.^82–84^ Six studies enrolled populations for whom perinatal status was not an inclusion criterion; all assessed brief counseling interventions. Four RCTs enrolled women with screen-detected IPV, and two cluster RCTs (by the same author) evaluated an intervention focused on clinician training and education that encouraged discussion of IPV during all patient encounters in family planning clinics.^88,^ ^89^ Three RCTs consisted of one in-person intervention session followed by telephone followup;^87,^ ^90,^ ^91^ two consisted of one-session counseling sessions during a clinic visit;^88,^ ^89^ and one study included one to six counseling sessions, depending on the woman’s need.^86^

All 11 RCTs were rated as good or fair quality (Appendix E Table 7). Common methodological limitations included overall attrition (20% or higher in seven RCTs); but most had no differential attrition and accounted for missing data using multiple imputation.

#### Characteristics of Studies Enrolling Pregnant and Postpartum Women

Five RCTs enrolled pregnant or postpartum women determined to be at risk for IPV during a routine maternity care;^80–84^ of these, two were included in the 2012 review for the USPSTF.^80,^ ^82^ Study characteristics are summarized in Table 1. Three RCTs based eligibility criteria for IPV using a validated tool,^81,^ ^83,^ ^84^ and one asked women whether they had experienced physical or sexual abuse from a current or former partner in the past year or were afraid of their current partner.^82^ One RCT, the Hawaiian Health Start Program (HSP), enrolled mothers during the postpartum period (primarily from hospitals) based on the infant’s risk of maltreatment determined by chart review and score on the Kempe’s Family Stress Checklist for screening;^80,^ ^96^ however, known involvement by Child Protective Services was an exclusion criterion.^80^ Four RCTs limited enrollment to mothers age 18 years or older; one also enrolled adolescents.^81^ The mean age of participants was reported in four RCTs and ranged from 24 to 32.^81–84^ Of the four RCTs reporting race/ethnicity, all enrolled a majority of nonwhite participants.^80–82,^ ^84^ Four trials were set in the United States, and one was set in Hong Kong.^83^

Interventions focused on two main types: home visiting interventions and brief clinic-based counseling. Two RCTs evaluated IPV interventions delivered during multiple home visits during the perinatal period.^80,^ ^81^ Home visiting interventions were conducted by paraprofessionals or trained nonprofessionals and focused on empowerment, support, and linkages to needed services.^80,^ ^81^ One RCT, the Domestic Violence Enhanced Home Visitation (DOVE) trial, compared two home visiting arms (with and without a structured IPV intervention),^81^ and the other compared home visits with usual clinical care.^80^ The Hawaiian HSP compared weekly home visits for an intended duration of 3 years,^80^ and one (the DOVE trial) included an abuse assessment and six IPV “empowered” sessions embedded into ongoing perinatal home visits.^81^

Three RCTs enrolling pregnant women or young mothers evaluated a brief clinic-based counseling intervention.^82–84^ One RCT (N=913), the NIH-DC Initiative to Reduce Infant Mortality in Minority Populations, enrolled women screening positive for one of several risk factors known to contribute to adverse perinatal outcomes (cigarette smoking, environmental tobacco smoke exposure, depression, and IPV); women randomized to the intervention group received prenatal behavioral counseling (two to eight sessions, approximately 35 minutes in length), with up to two additional postpartum sessions provided by professional counselors delivered during routine prenatal care visits (specific to each identified risk). Overall, 32 percent of women (N=336) screened positive for past-year IPV at baseline (rates were similar for intervention and usual care groups); in terms of other risk factors, 22 percent smoked, 78 percent had environmental smoke exposure, 62 percent were depressed, 32 percent used alcohol, and 17 percent used illicit drugs.^82^ The IPV (N=336) counseling emphasized danger assessment, safety behaviors, and information on community resources.^82^

The other two RCTs assessing counseling interventions focused only on IPV. One compared counseling based on principles of interpersonal psychotherapy delivered over four sessions during pregnancy by trained research personnel (four additional sessions were also offered after delivery).^84^ The second RCT assessed a brief counseling intervention immediately following screening delivered by a research assistant (a midwife with a degree in counseling); the intervention consisted of advice regarding safety, problem solving, other content developed to enhanced women’s independence and control, and a brochure reinforcing the information provided.^83^

Of the five RCTs enrolling pregnant or postpartum women, four reported on IPV incidence following the intervention.^80–82,^ ^84^ Although all studies measured IPV outcomes using the CTS-2, outcome measures were reported using different metrics (e.g., average IPV events per person year, change from baseline CTS-2 score, and mean frequency of IPV acts), and one study reported only on specific subtypes of violence^83^ (but not rates of any type of IPV) (Table 4). One RCT reported on pregnancy outcomes (e.g., preterm birth and low birth weight neonates).^82^ Two studies reported on measures of postpartum depression using the Edinburgh Postnatal Depression Scale (EPDS).^83,^ ^84^ One trial each reported on PTSD symptoms^97^ and quality of life.^83^

Table 4 Summary of IPV Exposure Results for RCTs Enrolling Pregnant or Postpartum Women (KQ 4)

Author, Year | Study name | G1 G2 | N analyzed | Main Results
Blair-Merritt et al, 2010^80^ | Hawaiian HSP | G1: Weekly home visits from paraprofessionals, linkage to services G2: Usual care | G1: 373 G2: 270 | CTS-2, adj. IRR, of average IPV events per person year^*^ 3 years: 7.50 vs. 9.55, IRR: 0.86 (0.73 to 1.01) 7–9 years:^†^ 3.35 vs. 4.01, IRR: 0.95 (0.77 to 1.17)
El-Mohandes et al, 2008^82,^ ^85,^ ^92^ | NA | G1: Individual cognitive behavioral counseling delivered during prenatal care visits G2: Usual prenatal care | G1: 452 (169 IPV subgroup) G2: 461 (167 IPV subgroup) | CTS-2, change from baseline (13 weeks’ gestation) to postpartum % of participants experiencing IPV (G1 vs. G2): −28.8 vs. −24.9; p=0.074 Subgroup of women with IPV at baseline, % experiencing IPV recurrence (baseline to postpartum) Adj. ORs (95% CI),^‡^ 0.48 (0.29 to 0.80) Women in the intervention group had lower rates of very preterm neonates (≤33 weeks) (1.5% vs. 6.6%; p=0.03) and very low birthweight neonates (<1,500 g) (0.8% vs. 4.6%; p=0.052); no statistically significant difference between groups in rates of low birth weight neonates (<2,500 g) (12.8% vs. 18.5%; p=0.204) or preterm births (<37 weeks) (13.0% vs. 19.7%; p=0.135)
Tiwari et al, 2005^83^ | NA | G1: Brief clinic-based counseling and safety advice delivered by a midwife G2: Usual care (wallet-sized card with information on community resources) | G1: 51 G2: 55 | Women in the intervention group had significantly lower CTS scores than controls on subdomains of psychological abuse (−1.1; 95% CI, −2.2 to −0.04) and minor physical violence (‑1.0; 95% CI, −1.8 to −0.17), but no statistically significant difference for severe physical abuse (0.08; 95% CI, −0.26 to 0.42) or sexual abuse (−0.07; 95% CI, −0.30 to 0.16) Postpartum depression, % of women with EPDS score ≥ 10 (G1 vs. G2): RR, 0.36 (0.15 to 0.88) SF-36 (component scores): Women in the intervention group had significantly higher scores on three component scores (physical functioning, role-physical, and role-emotional, p≤0.05) but significantly lower (worse) scores for bodily pain (≤0.05); scores were similar between groups for general health, mental health, vitality, and social functioning (p=NS)
Sharps et al, 2016^81^ | DOVE trial | G1: Domestic Violence Enhanced Home Visitation Program (DOVE), structured brochure-based IPV intervention added to standard home visitation G2: Standard home visiting protocol (4–6 prenatal visits, 6–12 postnatal visits over 2 years) | G1: 124 G2: 115 | Women in the intervention group had a significantly lower mean decrease in CTS-2 scores from baseline compared with controls at 24 months (−40.82 vs. −35.87; difference: ‑4.95; p<0.01)
Zlotnick et al, 2011^84^ | NA | G1: Interpersonal psychotherapy-based counseling G2: Usual care (educational material and a list of IPV resources) | G1: 25 G2: 21 | No statistically significant difference between groups in frequency of IPV acts (p=0.44), postpartum depression (EPDS mean scores; p=0.20), or PTSD symptoms (Davidson Trauma Scores) (p=0.24) at followup during pregnancy, 3 weeks postpartum, or 3 months postpartum

* Analyses adjusted for missing data; imputed data adjusted for child age, program site, maternal mental health comorbidity, problem alcohol use, and past-year employment with control group as referent. Overall IPV rates also adjusted for baseline IPV (continuous term).

† The values for the long-term followup reflect the time period when the child was approximately 7 to 9 years of age (4–6 years after the home visiting intervention ended).

‡ Adjusted for depression and substance use. Authors also report outcomes at each specific time point during pregnancy and postpartum visit. Women in the intervention group were less likely to be victimized at all time points, but the difference between groups at the postpartum visit was not statistically significant (12.7% vs. 21.2%; p=0.063).

Abbreviations: CI=confidence interval; CTS=Conflict Tactics Scale; CTS-2=Conflict Tactics Scale-2; EPDS=Edinburgh Postnatal Depression Scale; G=group; HSP=Health Start Program; IPV=intimate partner violence; IRR=incidence rate ratio; KQ=key question; N=sample size; NA=not available; NR=not reported; NS=not sufficient; OR=odds ratio; RCT=randomized, controlled trial; RR=relative risk; SF-36=Short Form Health Survey-36 Item; vs.=versus.

#### Results of Studies Enrolling Pregnant or Postpartum Women

##### IPV

Five RCTs enrolling pregnant or postpartum women reported on IPV outcomes (Figure 7). Of these, four reported on overall IPV (any type) and one reported on specific categories of IPV only.^84^ Of those reporting on overall IPV, two assessed home-visiting interventions and found evidence of benefit in favor of the intervention (although the magnitude of difference was small and results were imprecise). In one home-visiting intervention (enrolling mothers at risk of child maltreatment), overall IPV victimization was lower in the intervention group at 3 years compared with controls; however, results were not statistically significant (incidence rate ratio [IRR] of average IPV events per person year: 0.86; 95% CI, 0.73 to 1.01).^80^ At one year, the difference between groups in the occurrence of any IPV events slightly favored the intervention group but was not statistically significant (SMD, −0.04; 95% CI, −0.23 to 0.14). The average numbers of IPV events per person year over 3 years in the intervention and control groups was 7.50 and 9.55, respectively. Results were similar for physical assault victimization (IRR, 0.85; 95% CI, 0.71 to 1.00);^80^ rates of verbal abuse, sexual violence, and injury were similar between intervention and control groups (Appendix G Table 5). Long-term followup rates (average of 6 years, 3 years after the intervention ended) of overall IPV victimization decreased in both groups, with no significant difference between groups (IRR, 0.95; 95% CI, 0.77 to 1.17); there was no statistically significant difference between groups for rates of physical assault, sexual violence or injury, or verbal abuse (Appendix G Table 5). The second RCT compared two different home-visiting programs in women who screened positive for IPV (postpartum visits with and without a structured IPV assessment and empowerment intervention); both groups experienced a decrease in CTS-2 scores from baseline to followup at 1, 3, 6, 12, 18, and 24 months postpartum (p<0.001).^81^ Women in the intervention group experienced a larger mean decrease in IPV scores from baseline than controls (−40.82 vs. −35.87; mean difference in change from baseline scores: −4.95, p <0.001).^81^

Figure 7 Benefit of IPV Interventions in Studies Enrolling Pregnant or Postpartum Women (KQ4)

Abbreviations: C=counseling; CI=confidence interval; CTS-2=Conflict Tactics Scale 2; EPDS=Edinburgh Postnatal Depression Scale; HV=home visiting; IPV=intimate partner violence; LBW=low birth weight; N=sample size; PTB=preterm birth; SMD=standardized mean difference; VLBW=very low birth weight; VPTB=very preterm birth.

Figure 7 displays a forest plot stratified by outcome (IPV any type, IPV specific type, birth outcomes, depression, PTSD symptoms, and QOL) reporting standardized mean differences comparing IPV interventions to controls. For IPV any type, four studies reported standardized mean differences ranging from −0.40 to 0.22. For specific IPV type, one study reported standardized mean differences ranging from −0.47 to −0.09. For birth outcomes (very low birth weight, low birth weight, very preterm delivery, and preterm delivery), one study reported standardized mean differences ranging from −0.98 to −0.16. For depression, two studies reported standardized mean differences ranging from −0.75 to −0.32. For PTSD symptoms, one study reported a standardized mean difference of −0.05. For QOL, one study reported standardized mean differences ranging from −0.50 to 0.48.

Two RCTs assessing a counseling intervention reported on overall IPV. In the NIH-DC Initiative to Reduce Infant Mortality in Minority Populations RCT, results are described for the overall sample and women who reported IPV at baseline (and thus received an intervention specific to IPV). As described above, women were randomized to an integrated behavioral counseling intervention or control (usual care); the counseling intervention was individually tailored to address one or more risk factors reported by women at enrollment. In the overall sample (N=913), the difference between groups in percentage of women experiencing IPV (based on CTS-2) was not statistically different (change in percentage from baseline to postpartum: −28.8 vs. −24.9; p=0.074). Among women who screened positive for IPV at baseline, those randomized to the intervention had significantly fewer recurrent episodes of IPV during pregnancy and postpartum (adjusted OR, 0.48; 95% CI, 0.29 to 0.80)^82,^ ^85^ Results based on outcome timing (during pregnancy vs. postpartum) and for specific subtypes of violence are shown in Appendix G Table 5. In the RCT comparing counseling based on principles of interpersonal psychotherapy with usual care (five sessions delivered during routine prenatal/postnatal care), there were no differences between groups in mean reduction of CTS-2 scores over time (baseline, postpartum, 2 weeks postpartum, and 3 months postpartum; p=0.44); at 6 months (3 months postpartum), women in the intervention group had a slightly higher mean CTS-2 score although differences were not statistically significant (Figure 7).

One RCT (N=110) assessing a counseling intervention reported on subtypes of IPV only. The study enrolled women from Hong Kong who screened positive for IPV and compared brief counseling with usual care; at 6 weeks postpartum, women in the intervention group had lower CTS scores than women in the control group on subdomains of psychological abuse (mean difference −1.1; 95% CI, −2.2 to −0.04) and minor physical violence (mean difference −1.0; 95% CI, −1.8 to −0.17), but no statistically significant difference between groups was observed for severe physical abuse (mean difference 0.08; 95% CI, −0.26 to 0.42) or sexual abuse (mean difference −0.07; 95% CI, −0.30 to 0.16) (Table 4).^83^

##### Quality of Life

One RCT enrolling pregnant women who screened positive for IPV reported on quality of life using the SF-36.^83^ The RCT compared brief counseling with usual care for Chinese women who screened positive for IPV; results were reported only for the SF-36 individual domains (Appendix G Table 6);^83^ at 6 weeks postpartum, the intervention group had significantly higher physical functioning and role limitation measures (for both physical and emotional problems) but lower (worse) scores on the bodily pain domain compared with the control group (p≤0.05). Scores for other domains were similar across groups and differences were not statistically significant.^83^

##### Birth Outcomes

The NIH-DC Initiative to Reduce Infant Mortality in Minority Population trial reported on birth outcomes.^82,^ ^85,^ ^92^ Among the subgroup of women who screened positive for IPV at baseline (N=306), fewer women in the intervention group had very preterm neonates (≤33 weeks) (2 vs. 9 women; p=0.03) compared with women in the control group.^85^ However, when using the full sample of the subgroup of women who had IPV at baseline and IPV measured at followup (N=306) (as opposed to the analytic approach used by the study—i.e., dropping participants with missing data), we found that the effect size for very preterm neonates was similar to the value reported in the study, but the result was not statistically significant (Figure 7). There was no statistically significant difference between intervention and control groups in rates of low birth weight neonates (<2,500 g) (17 vs. 24 women; p=0.204) or preterm birth (<37 weeks) (18 vs. 27 women; p=0.135). As noted above, women in the intervention group also had counseling to address other risk factors for adverse pregnancy outcomes; in the overall sample, women in the intervention group had significantly reduced smoking and environmental some exposure compared with controls. In addition, among women experiencing IPV at baseline, 62 percent reported being depressed. It is unclear how modification of these risk factors influenced birth outcomes among women who had interventions targeting both IPV and other risk factors such as depression.

##### Depression

Two RCTs evaluating counseling interventions reported on depression outcomes (Figure 8).^83,^ ^84^ The RCT comparing brief counseling with usual care in Chinese prenatal clinics measured postnatal depression on the EPDS at 6 weeks postpartum;^83^ fewer women in the intervention group had postnatal depression (defined as EPDS score ≥10) compared with the control group (relative risk [RR], 0.36; 95% CI, 0.15 to 0.88).^83^ The second RCT evaluated an interpersonal psychotherapy–based intervention and found no differences between intervention and control groups in incident cases of major depressive episodes (five women in the control group and six women in the intervention group) measured by a standardized interview;^84^ the same trial also measured EPDS scores and found an association between the intervention and lower depression scores at 6 months; however, differences between groups were not statistically significant (SMD, −0.32; 95% CI, −0.91 to 0.26).^84^

Figure 8 Benefit of IPV Interventions in Studies Enrolling Nonpregnant Women (KQ4)

Abbreviations: CAS=Composite Abuse Scale; CBDI-II=Chinese Beck Depression Inventory-II; CESD-R10=Center for Epidemiologic Studies Short Depression Scale-10 Revised; CI=confidence interval; CTS-2=Conflict Tactics Scale 2; FP=family planning clinic; HADS=Hospital Anxiety and Depression Scale; IPV=intimate partner violence; N=sample size; PC=primary care; PC(pre.)=indicates women were recruited from routine prenatal care; SF-12= Short Form Health Survey-12 Item; SMD=standardized mean difference; QOL=quality of life; WHO=World Health Organization.

Figure 8 displays a forest plot stratified by outcome (IPV any type, IPV specific type, depression, anxiety, and QOL) reporting standardized mean differences comparing IPV interventions to controls. For IPV any type, three studies reported standardized mean differences ranging from 0.01 to 0.13. For specific IPV type, two studies reported standardized mean differences ranging from −0.68 to −0.06. For depression, three studies reported standardized mean differences ranging from −0.38 to −0.02. For anxiety, one study reported a standardized mean difference of −0.08. For QOL, two studies reported standardized mean differences ranging from −0.19 to −0.02.

##### PTSD

One RCT evaluating a counseling intervention reported on PTSD outcomes (Figure 8).^84^ Per the authors, only one woman (in the intervention group) met criteria for PTSD for the duration of the study measured by a standardized interview. PTSD symptoms were also assessed using the Davidson Trauma Scale; women in the intervention and control groups had similar scores at 6 months (SMD, −0.05; 95% CI, −0.63 to 0.53).^84^

#### Characteristics of Studies Enrolling Nonpregnant Adults and Adolescents

Six RCTs enrolled women without specifying perinatal or postnatal status as an inclusion criterion. Studies used various IPV screening tools and criteria to determine eligibility. One RCT that focused on physician training to deliver a brief IPV counseling intervention enrolled women who responded to a validated mail survey, sent from their health care provider, that included a question asking how often in the past 12 months the woman was afraid of her partner or ex-partner.^86^ One RCT assessing motivational interviewing screened for past-year IPV using the AAS and Women’s Experience with Battering (WEB) Scale, administered through an in-person computer-assisted tool.^91^ A trial assessing a brief motivational intervention identified women experiencing IPV in the past 3 months based on responses to the CTS, with a further requirement that women indicated heavy drinking, based on their Alcohol Use Disorders Identification Test score.^87^ A trial assessing brief in-person counseling used the Chinese version of the AAS to identify emotional, physical, or sexual abuse by an intimate partner in the past year.^90^ Two cluster RCTs focused on provider education and training related to IPV and sexual coercion and did not use a specific screening tool to determine eligibility; discussion of IPV was encouraged at all family planning clinic encounters.^88,^ ^89^

Three RCTs included one in-person intervention session followed by telephone followup.^87,^ ^90,^ ^91^ One trial consisted of motivational interviewing through one 1-hour, in-person session followed by three 10- to 15-minute telephone calls over a 4-month period;^91^ one involved a single in-person empowerment session followed by 12 weekly telephone support calls over 9 months;^90^ and one consisted of a brief motivational interviewing intervention and a telephone call 10 days later.^87^ Two studies provided women with one session of counseling during a clinic visit by clinical staff who had received special IPV training.^88,^ ^89^ In a study focused on physician training to respond to IPV, the intervention was described as one to six counseling session, depending on the participant’s needs; most participants received just one or a few visits (median=1, mean=2.4).^86^ Across RCTs, in five studies the comparison group received usual care,^86–89,^ ^95^ and in one study the comparison group received resources and referrals by meeting with a field coordinator or an advocate.^91^

Five RCTs reported on a measure of IPV following the intervention.^80–82,^ ^84,^ ^86–90^ Studies measured IPV using different scales and metrics (e.g., percentage of women with CTS-2 score ≥1 for past-week violence, mean CTS-2 scores), and some reported only on subtypes of violence. Two studies reported on quality-of-life outcomes (both used the SF-12 and one also used the WHOQOL-Bref). Three studies reported on depression outcomes and one of these also reported on anxiety.

#### Results of Studies Enrolling Nonpregnant Adults and Adolescents

##### IPV

Five RCTs measured IPV incidence (Table 5). Two reported on a measure of overall IPV and found similar rates of IPV among groups with no statistically significant difference (Figure 8).^86,^ ^87^ Two trials that focused on IPV education and training for family planning staff reported on recent (past 3 months) physical or sexual violence; neither trial found a statistically significant difference between groups (women in the intervention group had a slightly higher rate of IPV).^88,^ ^89^ One of these^89^ found a greater reduction in pregnancy coercion among the subgroup of women experiencing IPV at baseline in the intervention group (OR, 0.29; 95% CI, 0.09 to 0.91) but no difference between groups in reduction in birth control sabotage (OR, 0.71; 95% CI, 0.17 to 2.94).^89^ One trial reported on subtypes of violence only and found lower scores on the CTS-2 for psychological aggression over 3 to 9 months (difference between groups in mean scores: −1.87; 95% CI, −3.34 to −0.40) but not for physical assault (0.35; 95% CI, −0.80 to 0.10) or sexual coercion (−0.02; 95% CI, −0.12 to 0.09).^90^

Table 5 Summary of Results for RCTs Enrolling Nonpregnant Populations (KQ4)

Author, Year | Study Name | G1 (N analyzed) G2 (N analyzed) | N Analyzed | Main Results
Hegarty et al, 2013^86^ | WEAVE trial | G1: Physician training to deliver a brief IPV counseling intervention G2: Usual care | G1: 137 G2: 135 | No difference between groups in change from baseline to 12 months in % of women with CAS score ≥7 (G1 vs. G2): −28 vs. −29; p=NS Fewer women in the intervention group had a HADS depression score ≥ 8 at 6 months (OR, 0.4; 0.1 to 1.0; p=0.05) and 12 months (OR, 0.3; 01 to 0.7; p=0.005) than controls No difference between groups in % of women with HADS anxiety score ≥ 8 at 6 months (OR, 0.5; 0.2 to 1.3; p=0.14) or 12 months (OR, 0.4; 0.2 to 1.2; p=0.11) No difference between groups in SF-12 MCS mean scores (G1 vs. G2) at 6 months (0.8; −2.3 to 3.9) or 12 months (1.9; −1.7 to 5.5); no difference between groups on mean WHOQOL-Bref component scores at 6 or 12 months
Miller et al, 2011^89^ | NA | G1: Clinican and staff IPV education; enhanced screening; counseling for IPV and appropriate referrals G2: Usual care (standard IPV question on intake sheet; referral if IPV disclosed) | G1: 453 G2: 451 | No difference between groups in change from baseline to 3- to 6-month followup % of women reporting recent IPV^*^ (defined as past 3-month physical or sexual violence) (0.9% vs. 2.2%), pregnancy coercion (−1.8% vs. −0.3%), or birth control sabotage (6.3% vs. 2.2%) In the subgroup of women with recent IPV at baseline, fewer women in the intervention group reported pregnancy coercion at followup (OR, 0.29; 0.09 to 0.91); there was no significant difference between groups in birth control sabotage (OR, 0.71; 0.17 to 2.94)
Miller et al, 2016^88^ | NA | G1: Clinicians and staff IPV education training; discussion of IPV encouraged for all encounters, guided by palm-sized brochure G2: Usual care (standard IPV question on intake sheet; referral if IPV disclosed) | G1: 1429 G2: 1396 | No difference between groups in change from baseline to 3- to 6-month followup in % of women reporting recent IPV (defined as past 3-month physical or sexual violence) (Adj. RR,^t^ 1.07; 0.84 to 1.38) or reproductive coercion (Adj. RR,^‡^ 1.50; 0.95 to 2.35) In the subgroup of women with recent IPV at baseline, there was no difference between groups in change from baseline to followup in % of women reporting recent IPV (Adj. RR, 1.16; 0.82 to 1.64) or reproductive coercion (Adj. RR; 1.19; 0.63 to 2.22)
Rhodes et al, 2015^87^ | NA | G1: Brief motivational intervention during ED visit G2: Assessed control G3: No contact control | G1: 232 G2: 121 | No difference between groups in IPV at 3 months (CTS-2 score ³1, in reference to abuse in the past week), G1 vs. G2: OR, 1.02 (0.98 to 1.06; p=0.33). No difference between groups on mean CTS scores at 3, 6, or 12 months
Saftlas et al, 2014^91^ | NA | G1: Motivational interviewing G2: Written information on community-based resources | G1: 98 G2: 106 | No statistically significant difference between groups in mean change from baseline depression scores (Center for Epidemiologic Studies Short Depression Scale), G1 vs. G2: −4.2 vs. −2.6; p=0.07
Tiwari et al, 2012^94^ Tiwari et al, 2010^90^ | NA | G1: Advocacy intervention (in-person interview, written materials, scheduled weekly calls, access to a 24-hour hotline) G2: Usual care | G1: 100 G2: 100 | No difference between groups over 3 to 9 months in mean adj.^‡^ CTS-2 scores for physical assault (0.35; −0.80 to 0.10; p=0.13) or sexual coercion (−0.02; ‑0.12 to 0.09; p=0.60). Women in the intervention group had significantly lower scores on CTS-2 for psychological aggression (−1.87; −3.34 to −0.40; p=0.01) Women in the intervention groups had lower depression scores (CBDI-II)^§^ at 3-9 months: −2.66 (−5.06 to −0.26); p=0.03. However, change is less than the 5-point difference considered clinically meaningful. No statistically significant difference between groups at 3 to 9 months on mean SF-12 PCS scores (0.37; −0.91 to 1.65; p=0.58) or SF-12 MCS scores (0.80; −1.16 to 2.77; p=0.42)

* Per authors, recent (past 3-month) experiences of physical and sexual violence were assessed using items modified from the Conflict Tactics Scales and the Sexual Experiences Survey.

† Models adjusted for baseline values, survey time point, interaction between baseline and time point, and clustering; missing data accounted for using multiple imputation.

‡ Between-group difference adjusted for baseline values.

§ Chinese version of the Beck Depression Inventory II; range of scores is from 0 to 36, higher scores indicate higher levels of depression.

Abbreviations: CBDI-II=Chinese Beck Depression Inventory-II; CTS=Conflict Tactics Scale; CTS-2=Conflict Tactics Scale-2; G=group; HADS=Hospital Anxiety and Depression Scale; KQ=key question; IPV=intimate partner violence; MCS=Mental Composite Score; N=sample size; NS=not sufficient; OR=odds ratio; PCS=Physical Composite Score; RCT=randomized, controlled trial; RR=relative risk; SF-12=Short Form Health Survey-12 Item; WEAVE=Women who have Experienced intimate partner Violence trial; WHOQOL-Bref=World Health Organization Quality of Life-Bref instrument; vs.=versus.

##### Quality of Life

Two RCTs measured changes in quality of life following an intervention for IPV; although changes in mean scores favored the intervention group, differences between groups were small and not statistically significant.^86,^ ^90^ One trial found no significant difference between intervention and control groups on SF-12 Mental Composite Score mean scores at 6 months (0.80; 95% CI, −2.3 to 3.9) or 12 months (1.9; 95% CI, −1.7 to 5.5) and no difference between groups on mean WHOQOL-Bref component scores at 6 or 12 months (mean difference between groups ranged from 1 to 5 points on all 4 component scores) (Appendix G Table 6).^86^ Another trial found no statistically significant difference between groups at 3 to 9 months on mean SF-12 Physical Composite Scores (0.37; 95% CI, −0.91 to 1.65) or SF-12 Mental Composite Scores (0.80; 95% CI, −1.16 to 2.77).^90^

##### Depression

Three RCTs reported on depression outcomes (Figure 8). One RCT found a greater reduction in depression among the intervention group (percentage of participants with Hospital Anxiety and Depression Scale [HADS] depression score ≥8) at 6 months (OR, 0.4; 0.1 to 1.0) and 12 months (OR, 0.3; 95% CI, 0.1 to 0.7).^86^ A second RCT also found a greater reduction in depression scores in the intervention group (Chinese Beck Depression Inventory-II) between 3 and 9 months (adjusted difference in score change: −2.66 (95% CI, −5.06 to −0.26), p=0.03; however, the difference was below the threshold considered clinically meaningful (5-point difference).^90^ One other study that measured depression found similar changes in scores on the Center for Epidemiologic Studies Short Depression Scale over 6 months (SMD, −0.02; 95% CI, −0.29 to 0.26).^91^

##### Anxiety

One RCT assessing physician training to deliver brief IPV counseling reported on anxiety symptoms (Figure 8). There was no difference between groups in the percentage of women with HADS anxiety score ≥8 at 6 months (OR, 0.5; 95% CI, 0.2 to 1.3) or 12 months (OR, 0.4; 0.2 to 1.2).^86^

### KQ5 What Are the Harms of Interventions for IPV in Adults and Adolescents?

Five good- or fair-quality RCTs assessing interventions for IPV reported on harms; all are included in KQ 4. Characteristics of the studies are described above and shown in Table 3.

One RCT^86^ assessing a brief counseling intervention surveyed women at 6 and 12 months about survey participation (including potential harms); there was no difference between groups in the percentage of women who reported potential harms, and authors concluded no harms were associated with the intervention. Items measured (5-point Likert scale from “strongly agree” to “strongly disagree”) included “I am glad to be a participant in the project” (at 6 months, 2% in the intervention group responded “strongly disagree” compared with 0% of controls) and “I felt judged negatively by practice staff for being a participant in this trial” (at 6 months, no intervention group members strongly agreed compared with 1% of controls). To the item “As a result of participating in this trial, I see the quality of my own life as …” (respondents answered on a 5-point scale from “better” to “worse”), no intervention or control groups chose “worse” at 6 months. At 6 months, 28 percent in the intervention group and 10 percent in the control group reported that their abusive partners were aware that they had talked to a doctor about relationship issues; at 12 months, the percentage of women reporting abusive partner awareness of participation was 24 percent and 13 percent in the intervention and control arms, respectively. Among women who reported abusive partner awareness of trial participation, the number of negative partner behaviors (e.g., got angry, made her more afraid for herself or her children, or restricted her freedom) was not significantly different between groups. Women in the intervention group reported 0.5 negative behaviors (per 15 women) and 0.7 behaviors (per 23 women) at 6 and 12 months, respectively. In the control arm, the number of negative partner behaviors associated with abusive partner awareness of trial participation was 3.0 (per 5 women) and 0.2 (per 12 women) at 6 and 12 months, respectively. Across all items, the authors report no between-group differences in harms.

In one RCT,^83^ conducted at the antenatal clinic of a public hospital in Hong Kong, participants were asked by telephone whether the frequency of violence had increased as a result of their taking part in the study. According to the authors, no adverse events related to participation were reported by women in either group.^83^

Three other RCTs reported that no harms were associated with the intervention but did not comment on how harms were measured and assessed.^81,^ ^87,^ ^90^

## Elder Abuse and Abuse of Vulnerable Adults

### KQ1 Does Screening in Health Care Settings for Current, Past, or Increased Risk for Abuse and Neglect in Older and Vulnerable Adults Reduce Exposure to Abuse and Neglect, Physical or Mental Morbidity, or Mortality?

We identified no studies addressing this KQ.

### KQ2 How Effective Are Screening Questionnaires or Tools in Identifying Older and Vulnerable Adults With Current, Past, or Increased Risk for Abuse and Neglect?

#### Characteristics of Included Studies

We included one fair-quality study assessing the accuracy of screening for abuse in older adults.^98^ No studies were found on the effectiveness of screening questionnaires or tools in identifying abuse and neglect of vulnerable adults.

The study enrolled English- or Spanish-speaking participants age 65 years or older (N=139) presenting for routine dental care at an academic dental clinic in New York State. Eligible participants included those who received caregiver assistance (paid or unpaid) for at least 2 hours per week, agreed to be rescreened 6 months after the first interview, and scored 18 or more on the Mini Mental Status Examination.^99^ The mean age of enrolled participants was 75, and the majority were female (60%). Screening was conducted using the Hwalek-Sengstock Elder Abuse Screening Test (H-S/EAST), which includes 15 items. For this analysis, the study authors examined the proportion of participants who had a positive response (≥3) to a group of seven questions (questions 5, 7, 9, 10, 11, 13, and 15) determined by authors to be particularly indicative of abuse. The full H-S/EAST tool is shown in Appendix E. Screening test accuracy was compared against the CTS; participants were considered positive for elder maltreatment based on the CTS violence/verbal aggression scales combined if they reported that at least one item occurred once or more in the previous year in more than one of the following subscales: verbal aggression, minor violence, and severe violence. The number of participants identified who reported that at least one of the subscale items occurred once or more in the previous year were considered positive for that subscale.

#### Results of Included Studies

The gold standard, CTS, found elder maltreatment based on CTS violence/verbal aggression scales combined to be 41 percent. Compared with the CTS (violence/verbal aggression scales combined), the H-S/EAST had a sensitivity of 46 percent (95% CI, 32 to 59) and specificity of 73.2 percent (95% CI, 62 to 82). The positive likelihood ratio was 2 (95% CI, 2 to 2), and the negative likelihood ratio was 1 (95% CI, 1 to 1) for this comparison. The positive predictive value of this comparison was 54 percent (95% CI, 43 to 65), and the negative predictive value was 66 percent (95% CI, 60 to 72).

When comparing the individual components of the CTS to the H-S/EAST, the H-S/EAST has a sensitivity of 46 percent (95% CI, 32 to 59) to detect verbal aggression, 67 percent (95% CI, 22 to 96) to detect minor violence, and 75 percent (95% CI, 19 to 99) to detect severe violence. When comparing the individual components of the CTS to the H-S/EAST, the H-S/EAST has a specificity of 73 percent (95% CI, 62 to 82) to detect verbal aggression, 67 percent (95% CI, 58 to 75) to detect minor violence, and 67 percent (95% CI, 58 to 74) to detect severe violence. Positive likelihood ratios were 2 for all subtypes of violence, and negative likelihood ratios ranged from 0.4 to 1.0. Positive predictive values for individual subtypes of violence ranged from 6 to 54 percent; similarly, negative predictive values ranged from 99 to 66 percent.

### KQ3 What Are the Harms of Screening for Abuse and Neglect in Older and Vulnerable Adults?

We identified no studies addressing this KQ.

### KQ4 How Well Do Interventions Reduce Exposure to Abuse and Neglect, Physical or Mental Morbidity, or Mortality Among Screen-Detected Older and Vulnerable Adults With Current, Past, or Increased Risk for Abuse and Neglect?

We identified no studies addressing this KQ.

### KQ5 What Are the Harms of Interventions for Abuse and Neglect in Older and Vulnerable Adults?

We identified no studies addressing this KQ.