# Chapter 2 Methods

## Key Questions and Analytic Framework

The Evidence-based Practice Center (EPC) investigators, USPSTF members, and Agency for Healthcare Research and Quality (AHRQ) Medical Officers developed the scope and key questions (KQs). Figures 1 and 2 show the analytic framework and KQs that guided the review. KQs for IPV (Figure 1) are the following:

1. Does screening for current, past, or increased risk for intimate partner violence (IPV) in adults and adolescents reduce exposure to IPV, physical or mental morbidity, or mortality?
2. What is the accuracy of screening questionnaires or tools for identifying adults and adolescents with current, past, or increased risk for IPV?
3. What are the harms of screening for IPV in adults and adolescents?
4. How well do interventions reduce exposure to IPV, physical or mental morbidity, or mortality among screen-detected adults and adolescents with current, past, or increased risk for IPV?
5. What are the harms of interventions for IPV in adults and adolescents?

Figure 1 Intimate Partner Violence Analytic Framework

^a^ Includes reduction in the frequency or severity of IPV.

^b^ Includes acute and chronic morbidity from physical abuse (e.g., fractures, dislocations, brain injury), sexual abuse (e.g., unwanted pregnancy, sexually transmitted infections), psychological abuse (e.g., depression, anxiety, posttraumatic stress disorder), and financial abuse (e.g., limiting access to money or other resources); health care utilization attributed to any form of abuse/neglect and associated physical and mental morbidity (e.g., rates of emergency room visits); adverse perinatal outcomes (e.g., miscarriage, low birth weight); social isolation; and quality of life.

Abbreviations: IPV=intimate partner violence; KQ=key question.

Key Questions to Be Systematically Reviewed

1. Does screening for current, past, or increased risk for intimate partner violence (IPV) in adults and adolescents reduce exposure to IPV, physical or mental morbidity, or mortality?
2. What is the accuracy of screening questionnaires or tools for identifying adults and adolescents with current, past, or increased risk for IPV?
3. What are the harms of screening for IPV in adults and adolescents?
4. How well do interventions reduce exposure to IPV, physical or mental morbidity, or mortality among screen-detected adults and adolescents with current, past, or increased risk for IPV?
5. What are the harms of interventions for IPV in adults and adolescents?

This figure depicts the analytic framework that outlines the key questions (KQs) that were addressed in the evidence review. The population of interest is adults and adolescents without recognized signs or symptoms of intimate partner violence (IPV). The figure illustrates the overarching question: Does screening for current, past, or increased risk for IPV in adults and adolescents reduce exposure to IPV, physical or mental morbidity, or mortality (KQ 1)? The figure depicts the pathway from screening to reduction in IPV, physical or mental morbidity, and mortality, as well as improvement in quality of life (KQ 2). Screening may result in harms (KQ 3). The figure also illustrates the question: For screen-detected adults and adolescents with current, past, or increased risk for IPV, how well do interventions reduce exposure to IPV, physical or mental morbidity, or mortality (KQ 4)? Interventions may result in harms (KQ 5).

Figure 2 Elder Abuse and Abuse of Vulnerable Adults Analytic Framework

^a^ Includes reduction in the level of violence or abuse or leaving an unsafe situation.

^b^ Includes acute and chronic morbidity from physical abuse (e.g., fractures, dislocations, brain injury), sexual abuse (e.g., unwanted pregnancy, sexually transmitted infections), psychological abuse (e.g., depression, anxiety, posttraumatic stress disorder), and financial abuse (e.g., misuse of assets by a caregiver); health care utilization attributed to any form of abuse/neglect and associated physical and mental morbidity (e.g., rates of emergency department visits); adverse perinatal outcomes (e.g., miscarriage, low birth weight); social isolation; and quality of life.

Abbreviation: KQ=key question.

Key Questions to Be Systematically Reviewed

1. Does screening in health care settings for current, past, or increased risk for abuse and neglect in older and vulnerable adults reduce exposure to abuse and neglect, physical or mental morbidity, or mortality?
2. How effective are screening questionnaires or tools in identifying older and vulnerable adults with current, past, or increased risk for abuse and neglect?
3. What are the harms of screening for abuse and neglect in older and vulnerable adults?
4. How well do interventions reduce exposure to abuse and neglect, physical or mental morbidity, or mortality among screen-detected older and vulnerable adults with current, past, or increased risk for abuse and neglect?
5. What are the harms of interventions for abuse and neglect in older and vulnerable adults?

This figure depicts the analytic framework that outlines the key questions (KQs) that were addressed in the evidence review. The population of interest is specified as older or vulnerable adults without recognized signs or symptoms of abuse or neglect. The figure illustrates the overarching question: Does screening for current, past, or increased risk for abuse and neglect in older or vulnerable adults reduce exposure to abuse/neglect, physical or mental morbidity, or mortality (KQ 1)? The figure depicts the pathway from screening to reduction in abuse/neglect, physical or mental morbidity, and mortality, as well as improvement in quality of life (KQ 2). Screening may result in harms (KQ 3). The figure also illustrates the question: For screen-detected older or vulnerable adults with current, past, or increased risk for abuse/neglect, how well do interventions reduce exposure to abuse/neglect, physical or mental morbidity, or mortality (KQ 4)? Interventions may result in harms (KQ 5).

KQs for elder abuse and abuse of vulnerable adults (Figure 2) are the following:

1. Does screening in health care settings for current, past, or increased risk for abuse and neglect in older and vulnerable adults reduce exposure to abuse and neglect, physical or mental morbidity, or mortality?
2. How effective are screening questionnaires or tools in identifying older and vulnerable adults with current, past, or increased risk for abuse and neglect?
3. What are the harms of screening for abuse and neglect in older and vulnerable adults?
4. How well do interventions reduce exposure to abuse and neglect, physical or mental morbidity, or mortality among screen-detected older and vulnerable adults with current, past, or increased risk for abuse and neglect?
5. What are the harms of interventions for abuse and neglect in older and vulnerable adults?

In addition to addressing our KQs, we also looked for evidence related to two Contextual Questions (CQs) that focused on the factors that limit the applicability of IPV and older/vulnerable adult screening and treatment studies conducted in emergency department settings to primary care settings. These CQs were not a part of our systematic review. They are intended to provide additional background information. Literature addressing these questions is summarized in Appendix A.

## Data Sources and Searches

We searched PubMed/MEDLINE, the Cochrane Library, and Embase for English-language articles published through October 4, 2017. We used Medical Subject Headings as search terms when available and keywords when appropriate, focusing on terms to describe relevant populations, screening tests, interventions, outcomes, and study designs. The search relied, in part, on the prior systematic reviews for the USPSTF^45,^ ^51^ to identify potentially relevant studies published before 2011 (we reassessed all articles included in the 2004 and 2011 systematic reviews using the eligibility criteria). We conducted new searches for studies relevant to screening and treatment for IPV victimization in men and adolescents because these populations were excluded in prior reviews for the USPSTF. Appendix B describes the complete search strategies. We conducted targeted searches for unpublished literature by searching ClinicalTrials.gov, the National Institutes of Health’s Research Portfolio Online Report Tools, and the WHO’s International Clinical Trials Registry Platform. To supplement electronic searches, we reviewed the reference lists of pertinent review articles and studies meeting our inclusion criteria and added all previously unidentified relevant articles. We will review all literature suggested by peer reviewers or public comment respondents and incorporate eligible studies into the final review. In addition, since October 2017, ongoing surveillance is being conducted through article alerts and targeted searches of high-impact journals to identify major studies published in the interim that may affect the conclusions or understanding of the evidence and, therefore, the related USPSTF recommendation. The last surveillance was conducted on August 1, 2018.

## Study Selection

We developed inclusion and exclusion criteria for populations, interventions, comparators, outcomes, settings, and study designs (Appendix B).^52^ We included English-language studies of adolescents and adults presenting for primary care and other health care settings (e.g., emergency departments) without recognized signs or symptoms of IPV or abuse. We also included English-language studies enrolling older adults (age 60 years or older) and vulnerable adults (age 18 years or older) presenting for primary care services without recognized signs or symptoms of abuse or neglect. All studies were conducted in the United States or in similar populations with services and interventions applicable to U.S. practice. We also searched for evidence on subgroups defined by age; sex; race/ethnicity; pregnancy status; lesbian, gay, bisexual, transgender, and queer (LGBTQ) identification; type of abuse (e.g., physical abuse, sexual abuse); history of abuse; or presence of comorbid conditions for all KQs.

The following descriptions of study selection criteria by KQ pertain to both IPV and abuse or neglect of older/vulnerable adults. For KQ 1 (direct evidence that screening improves health outcomes), we included only RCTs comparing groups that were screened (for IPV victimization or for abuse and neglect among older/vulnerable adults) with groups that were not screened. Eligible outcomes for KQ 1 included reduction in abuse or neglect, health outcomes, health care utilization attributed to IPV, quality of life, and mortality.

For KQ 2 (screening test accuracy), we searched for studies that assessed the accuracy (e.g., sensitivity, specificity) of screening tests designed to detect IPV (current or past victimization or risk status for victimization) or, among older/vulnerable adults, current, past, or increased risk of abuse or neglect. Only tools feasible for use in U.S. primary care settings (i.e., brief, easy to interpret, acceptable to patients and clinicians) and appropriate when abuse is not suspected were eligible. We included only studies that compared a screening test with an acceptable reference standard, such as the Conflicts Tactics Scale (CTS), Composite Abuse Scale (CAS), or Index of Spouse Abuse (ISA). We excluded studies designed to identify perpetrators of IPV. For KQ 3 (harms of screening), we included RCTs and cohort studies with a concurrent control group comparing screened groups with unscreened groups. Eligible harm outcomes included labeling, stigma, false-positive and false-negative results, increased abuse and retaliation, and other harms (Appendix B2).

For KQ 4 (benefits of interventions) and KQ 5 (harms of intervention), we included studies assessing interventions that could be offered in or referred to by primary care (e.g., counseling, case management, home visitation, mentor or peer support, safety planning, and referral to community services). We included RCTs comparing intervention groups with no treatment, usual care, attention control, or waitlist control. For studies assessing the harms of interventions (KQ 5), cohort studies with a concurrent control group were also eligible. For KQ 5, all harms associated with the intervention (e.g., increased abuse or other forms of retaliation, emotional distress) were eligible.

Two investigators independently reviewed titles and abstracts. Two investigators independently reviewed the full text of articles marked for potential inclusion by either reviewer. Two experienced team members resolved any disagreements.

## Quality Assessment and Data Abstraction

For each included study, one investigator extracted pertinent information about the methods, populations, interventions, comparators, outcomes, timing, settings, and study designs. A second investigator checked all data extractions for completeness and accuracy.

We assessed the quality of studies as good, fair, or poor using predefined criteria developed by the USPSTF and adapted for this topic (Appendix B3).^53^ Two independent reviewers assigned quality ratings for each study. Disagreements were resolved by discussion with an experienced team member. We included only studies rated as having good or fair quality.

## Data Synthesis and Analysis

Findings for each KQ were qualitatively synthesized by summarizing the characteristics and results of included studies in tables, figures, and narrative format. To determine whether meta-analyses were appropriate, we assessed the clinical and methodological heterogeneity of studies following established guidance.^54^ We qualitatively assessed the populations, screening tests, interventions, comparators, outcomes, and study designs, looking for similarities and differences. For IPV, we did not estimate pooled effects of screening or treatment because we identified few trials focused on heterogeneous populations, intervention types, and outcomes. For screening test accuracy (KQ 2), we identified a larger body of literature (15 studies) but were unable to perform meta-analyses due to substantial heterogeneity in study populations, settings, screening tests, and diagnostic reference standards. No more than two included studies assessed the same screener in a similar population and reported on the same type of measure (e.g., accuracy for detecting past year IPV, accuracy for detecting current or ongoing IPV). In addition, accuracy studies not only varied in the reference measure used (i.e., Composite Abuse Scale, Conflict Tactics Scale/Conflict Tactics Scale-2, Index of Spouse Abuse), but also in how the reference measure categorized IPV (e.g., overall IPV, physical violence only, or combined physical or sexual violence). In a few cases, accuracy studies using the same screener sometimes used different cut points for determining test positivity.

When possible, for studies reporting on similar outcomes, we created forest plots to display effect estimates from individual studies using Comprehensive Meta-Analysis version 3.3 (Biostat, Inc.) and Stata version 14 (StataCorp). In both figures and text, we show study estimates based on multiple imputation or other methods to address missing data when these were provided by authors. For KQ 4 (benefits of IPV interventions), studies reported on similar outcomes (e.g., incidence of IPV based on the Conflict Tactics Scale-2) using both continuous and dichotomous measures. To create figures displaying commonly reported outcomes, we re-expressed results as a standardized mean difference (SMD) when possible (i.e., when sufficient data was available).

When synthesizing evidence and making conclusions on screening test accuracy, we focused on studies that report the accuracy of screening tools for detecting past-year or current IPV as the outcomes most relevant for clinical practice (rather than lifetime IPV prevalence or prediction of future abuse). In the detailed Results and tables, we summarize all IPV test accuracy measures (current, past year, lifetime and prediction of future abuse).

Two independent reviewers assessed the overall strength of the body of evidence for each KQ as high, moderate, low, or insufficient using methods developed for the USPSTF (based on methods of the EPC program^55,^ ^56^), based on the overall quality of studies, consistency of results between studies, precision of findings, and risk of reporting bias. The applicability of the findings to U.S. primary care populations and settings was also assessed. Discrepancies were resolved through consensus discussion.

## Expert Review and Public Comment

A draft report was reviewed by content experts, representatives of Federal partners, USPSTF members, and AHRQ Medical Officers and was revised based on comments, as appropriate. The draft report was also posted for public comment between April 24, 2018, and May 21, 2018. References suggested by the public were reviewed and evaluated for inclusion/exclusion. For IPV, the report was revised to include an additional recommendation in the table of recommendations from other groups, to highlight risk factors for victimization in the introduction, and to include limiting access to money as an example of coercive tactics. For elderly and vulnerable adults, minor edits were made to clarify that eligible elder abuse screening tools for this report are those feasible for use in U.S. primary care settings (i.e., brief, easy to interpret, acceptable to patients and clinicians) and appropriate for screening when abuse is not suspected, and the team ensured that the prevalence estimates of elder abuse cited in the introduction are from the most recent, nationally representative studies enrolling U.S. adults.

## USPSTF Involvement

This review was funded by AHRQ. AHRQ staff and USPSTF members participated in developing the scope of the work and reviewed draft manuscripts, but the authors are solely responsible for the content.