# Chapter 1 Introduction

## Scope and Purpose

The U.S. Preventive Services Task Force (USPSTF) will use this report to inform an update of its 2013 recommendation on screening for intimate partner violence (IPV), elder abuse, and abuse of vulnerable adults.^1^ In 2013, the USPSTF recommended screening women of childbearing age for IPV, such as domestic violence, and providing or referring women who screen positive to intervention services (B recommendation). For asymptomatic older and vulnerable adults, the USPSTF concluded that evidence was insufficient to assess the balance of benefits and harms of screening for abuse and neglect (I statement). The purpose of this report is to systematically evaluate the current evidence on screening for IPV, elder abuse, and abuse of vulnerable adults for populations and settings relevant to primary care in the United States. This report focuses on screening individuals who do not have symptoms, complaints, or obvious signs of abuse, such as physical injuries.

## Condition Definition

IPV refers to physical violence, sexual violence, psychological aggression (including coercive tactics, such as limiting access to money), or stalking by a person with whom one has a close personal relationship,^2^ such as a current or former boyfriend/girlfriend, dating partner, ongoing sexual partner, or spouse. Appendix A Table 1 shows the categories of IPV recognized by the Centers for Disease Control and Prevention (CDC).^3^

CDC defines elder abuse as “an intentional act or failure to act by a caregiver or another person in a relationship involving an expectation of trust that causes or creates a serious risk of harm to an older adult.”^4,^ ^p. 28^ An older adult is considered to be age 60 years or older. For this update review, abuse and neglect of vulnerable adults is also considered with elder abuse. A vulnerable adult is a person age 18 years or older whose ability to perform the normal activities of daily living or to provide his or her own care or protection is impaired because of a mental, emotional, long-term physical, or developmental disability or dysfunction or brain damage.^5^ Appendix A Table 2 shows CDC’s definitions of categories of elder abuse; these apply also to abuse of vulnerable adults. The legal definition of “vulnerable adult” varies by State.^6^

## Prevalence and Burden

### Prevalence

Estimates of IPV prevalence vary because of nonstandardized definitions, differences in reporting requirements, and other factors. In addition, prevalence estimates are believed to underrepresent true rates of abuse because of underreporting.^7^ Victims may be reluctant to report IPV for many reasons, including economic dependence on the abuser, shame, embarrassment, and fear of reprisal.^8^ The CDC conducts a periodic nationally representative random survey of U.S. adults to obtain estimates of IPV prevalence, the National Intimate Partner and Sexual Violence Survey (NISVS). The 2015 NISVS (N=10,081) estimated that 5.4 percent of women and 5.1 percent of men experienced any past-year contact sexual violence, physical violence, and/or stalking by an intimate partner.^9^ The prevalence of past-year psychological victimization was not reported in the 2015 NISVS; however, NISVS data from 2011 (N=12,727) estimated that 14.2 percent of women and 18.0 percent of men experienced past-year psychological victimization.^10^ In terms of lifetime prevalence of abuse, 2015 NISVS data estimated that 36.4 percent of women and 33.4 percent of men had experienced contact sexual violence, physical violence, and/or stalking.^9^ Rates of lifetime psychological abuse were similar: 36.4 percent in women and 34.3 in men.

Rates of IPV prevalence vary by age, ethnicity, and household income. For example, according to 2011 NISVS estimates, reported rates of lifetime physical violence are higher among American Indian/Alaskan Native women (51.7%), multiracial women (51.3%), and non-Hispanic black women (41.2%) than non-Hispanic white women (30.5%) and Hispanic women (29.7%).^10^ Results from the 2010 NISVS survey (N=16,507) found reported rates of intimate partner rape, physical violence, or stalking victimization decline as women age from 14.8 percent among women ages 18 to 25 years, 4.1 percent among women ages 45 to 54 years, and 1.4 percent among women age 55 years or older.^11^ In addition, the 12-month prevalence of rape, physical violence, or stalking by an intimate partner was 9.7 percent among women with a combined household income of less than $25,000 versus 2.8 percent for women with a combined household income over $75,000.^11^ Few nationally representative surveys report recent data on IPV victimization among adolescents and other subgroups. Among respondents to the 2015 Youth Risk Behavior Survey who dated or went out with someone during the prior 12 months, 11.7 percent of girls and 7.4 percent of boys in 9^th^ through 12^th^ grade reported physical dating violence (being hit, slapped, or physically hurt on purpose by a boyfriend or girlfriend) and 15.6 percent of girls and 5.4 percent of boys reported sexual dating violence (defined as forced to kiss, touch, or have sexual intercourse they did not want to do).^12^

Prevalence estimates of elder abuse and abuse of vulnerable adults vary for many of the reasons noted for IPV estimates (e.g., nonstandardized definitions, differences in reporting requirements); in addition, features of study design, such as exclusion of the cognitively impaired, may result in underestimation of prevalence.^13^ A 2004 nationally representative survey (N=3,005) of past-year abuse among community-residing adults ages 57 to 85 years estimated 9 percent for verbal mistreatment, 3.5 percent for financial mistreatment, and 0.2 percent for physical mistreatment by a family member.^14^ In data from a 2008 nationwide telephone survey (N=5,777), 4.6 percent of respondents reported past-year emotional abuse, 1.6 percent physical abuse, 0.6 percent sexual abuse, 5.1 percent potential neglect, and 5.2 percent current financial abuse by a family member.^15^ Ten percent of respondents reported emotional, physical, or sexual mistreatment or potential neglect in the previous year.^15^ Among older adults, intimate partners constitute a minority of perpetrators in substantiated reports of elder abuse; according to data from a 2004 national survey of Adult Protective Services (APS) agencies, across all substantiated abuse reports involving a known perpetrator among adults over 60 (N=2,074), approximately 11 percent involved a spouse or intimate partner.^16^ The most common perpetrators of elder abuse are adult children (33% of cases) and other family members (20% of cases).^16^

We identified few studies reporting recent estimates of the prevalence of abuse among populations of vulnerable adults. The 1995–1996 National Violence Against Women Survey (N=6,273) found that women with severe disability impairments were four times more likely to experience sexual assault in the past year than women without disabilities,^17^ whereas analysis of data from the National Longitudinal Study of Adolescent Health (collected from 1994 through 2008) concluded that the odds of experiencing forced sex were about 1.5 times greater for female respondents ages 26 to 32 years with a physical disability compared with those without disabilities.^18^ In results from a 2004 survey of State APS, APS tallied 40,848 substantiated reports of vulnerable adult (ages 18 to 59 years) abuse in 19 States.^6^

### Burden

Abuse (IPV, elder abuse, and abuse of vulnerable adults) can cause adverse physical and mental outcomes. These outcomes can be immediate effects of violent episodes (e.g., acute physical injury, distress, or death), as well as long-term consequences that may result from one or more episodes of violence (e.g., development of post-traumatic stress disorder [PTSD]).^19^ In addition to adverse health outcomes, IPV can lead to adverse social consequences such as homelessness and isolation from social networks.^19^ IPV is also associated with significant economic burden due to direct medical and mental health care services and indirect costs from lost productivity.^20^

Approximately 15 percent of women who experienced IPV on the 2010 NISVS had been injured in violent episodes.^11^ Among postmenopausal participants in the Women’s Health Initiative, all types of abuse exposure were found to be associated with reductions in physical functioning scores;^21^ in the same cohort, women who reported physical, verbal, or both types of abuse in the previous year had a higher adjusted risk for mortality than women who did not report abuse.^22^ IPV also has adverse consequences on the reproductive health of women. IPV victimization is linked to higher rates of sexually transmitted infection^23^ and unintended pregnancy.^24^ Violence during pregnancy is associated with preterm birth, low birth weight, and decreased mean gestational age;^25^ its adverse effects on maternal and infant health include perinatal mental health problems^26^ and neonatal and post-neonatal hospitalization.^27^ The literature on health outcomes in male victims of IPV is sparse; in general, men are considered to have less severe physical consequences associated with IPV than women.^10^ Multivariate analysis of data from the Behavioral Risk Factor Surveillance System (BRFSS) 2006 survey (N=13,765) showed that IPV increased the odds of depression fourfold for nonveteran men and doubled them for veterans.^28^ In a study using data from two survey waves of the National Longitudinal Study of Adolescent Health (Add Health), both male and female young adults who reported experiencing IPV in the form of threats, physical violence, or sexual violence had more depressive symptoms and poorer self-rated health status, even after controlling for childhood abuse, an important confounder that both confers increased risk of IPV and is associated with adverse health outcomes.^29^

Among older adults, in a study of 5-year all-cause mortality for five types of elder abuse, caregiver neglect and financial exploitation were associated with the highest mortality rates.^30^ Among community-dwelling elders in the Chicago Health and Aging Project, abuse reported to social services agencies was associated with increased risk of overall mortality (hazard ratio [HR], 1.39; 95% confidence interval [CI], 1.07 to 1.84).^31^ Other consequences of elder abuse include a higher risk of nursing home placement^32^ among victims referred to APS, increased rates of hospitalization,^33^ and adverse psychological consequences (distress, anxiety and depression).^33^

## Risk Factors

A variety of factors at the individual, relationship, community, and societal levels contribute to the risk of IPV and other forms of interpersonal violence.^7,^ ^34,^ ^35^ Risk factors at various levels (e.g., individual and relationship) often overlap and are risks of both future victimization and perpetration. For example, multiple studies have concluded that exposure to violence as a child (directly or as a witness) is a predictor of future violence exposure as an adolescent or adult, as well as the perpetration of violence as an adolescent or adult.^36–38^ Systematic reviews of IPV risk factors have concluded that multiple demographic factors are associated with increased risk of IPV (either victimization or perpetration), including younger age (late adolescents to young adulthood), unemployment, and developmental or behavioral problems (e.g., antisocial behavior, poor impulse control).^34^ One systematic review^39^ that examined longitudinal predictors of IPV victimization in adults reported many of the same risk factors as above; specifically, they reported significant associations between IPV victimization and child and adolescent maltreatment, childhood family risks (e.g., family structure, quality of family relationships), child and adolescent behavioral problems, adolescent peer difficulties (e.g., not dating, poor friendship quality), and sociodemographic risks. Risk factors for elder abuse victimization specifically include isolation and a lack of social support, functional impairment and poor physical health (regardless of the cause), and age (increased risk among adults in their 50s and 60s compared with older adults).^14,^ ^40^ For older adults, lower income and living in a shared living environment with a large number of household members (other than a spouse) is associated with an increased risk of financial and physical abuse.^41^

## Rationale for Screening

Routine screening in populations without signs or symptoms of abuse could identify abuse not otherwise known, prevent future abuse from occurring, and reduce morbidity and mortality. Because of fear, intimidation, and lack of support, many individuals do not disclose abuse unless directly questioned, and many who are directly questioned will not disclose. For older adults, many victims do not seek help from the police, APS, or social and health service providers, especially when the perpetrators are their children.^42,^ ^43^ Preventing, identifying, and stopping abuse may prevent both short- and long-term serious health outcomes.^44^

There is no consensus regarding the most acceptable screening setting or modality.^45^ Many screening questionnaires are available that could be used in primary care settings, these include the Humiliation, Afraid, Rape, Kick (HARK); Hurt/Insult/Threaten/Scream (HITS); Woman Abuse Screening Tool (WAST); and others. Appendix G Table 1 details the questions they include, their score ranges, and interpretation. For older adults, there is uncertainty about how to conduct screening when potential victims may be accompanied by perpetrators or may be unable to answer questions themselves due to physical or cognitive disability.^41^

Several types of interventions are available for victims of IPV and other forms of interpersonal abuse, such as advocacy (e.g., assistance finding safe housing), counseling, home visits, referrals to community services, provision of education and resources, mentoring support, or combinations of intervention components.^45^ Interventions may be provided by clinicians, nurses, social workers, nonclinician mentors, or community workers. For older or vulnerable adults, interventions may also include money management, out-of-home placement, or conservatorship (a court-appointed guardian to manage financial and other affairs). Some interventions for older adults identified with abuse (or at risk for abuse) may include components targeted toward perpetrators (e.g., family members or other caregivers).^46^ The availability and accessibility of services vary by community. Potential harms of interventions may include increased abuse, shame, guilt, self-blame, loss of privacy, and fear of retaliation by perpetrators.

## Recommendations and Clinical Practice in the United States

Appendix A Table 3 summarizes recommendations from other organizations on screening for IPV in clinical settings. There is some disagreement among guidelines on screening for IPV. Similar to the current (2013) USPSTF recommendation, the American Academy of Family Physicians, American Academy of Obstetricians and Gynecologists, and others recommend screening. However, both the Canadian Task Force on Preventive Health Care and World Health Organization (WHO) indicate that current evidence does not justify universal screening.

Recommendations of other groups about screening for elder abuse in health care settings are summarized in Appendix A Table 4. Health care organizations have mixed recommendations about screening for elder and vulnerable adult abuse. The American Academy of Neurology, American College of Emergency Physicians, and the American Congress of Obstetricians and Gynecologists all specifically suggest screening for elder abuse. The USPSTF, American Academy of Family Physicians, WHO, the American Geriatrics Society, and the Canadian Task Force on Preventive Health Care conclude that the current evidence is insufficient to warrant a recommendation to screen.

A recent systematic review focused on screening and counseling practices for IPV among women in clinical settings.^47^ Across all included studies (k=35), rates of routine screening were variable and typically low, ranging from 2 to 50 percent of providers reporting “always” or “almost always” routinely screening for IPV.^47^ Definitions of “routine screening” varied; in some studies, this meant at every visit, and in others, this meant at every annual exam (or first prenatal visit for obstetricians).

The clinical practice implications of identifying abuse in some populations may require reporting by health care professionals. For example, some States require clinicians (including primary care physicians) to report abuse to legal authorities, and most require reporting of injuries resulting from firearms, knives, or other weapons.^48^ For elder abuse specifically, mandatory reporting laws and regulations also vary by State; however, most require reporting.^49^ For IPV, by Federal law (through the passage of the 1994 Violence Against Women Act and the 2005 reauthorization),^50^ shelter workers and other advocates are not mandatory reporters, unless they hold a clinical license that otherwise requires them to report abuse, thereby making it easier for women to seek refuge from abuse without fear of losing their children. There is significant controversy in the field over whether legal reporting for IPV should be mandatory to ensure victim safety.