# Appendix F Screening Instruments

Appendix F Table 1 IPV Screening Instruments

Abbreviated Name | Complete Name | Description | Items | Scoring, Range, and Cutoff for Positive Screen
HITS^66,^ ^72,^ ^160^ | Hurt, Insulted, Threaten, Scream | 4 items assess the frequency of IPV | 1. How often does your partner physically hurt you?; 2. How often does your partner insult or talk down to you?; 3. How often does your partner threaten you with physical harm?; 4. How often does you partner scream or curse at you? | Each item is answered on a 5-point Likert scale:; - 1=never; - 2=rarely; - 3=sometimes; - 4=fairly often; - 5=frequently; Score range: 4–20 Cutoff for IPV:^*^ ≥10
E-HITS^72^ | Extended–Hurt, Insulted, Threaten, Scream | 5 items (including all 4 HITS items and an additional sexual violence item) | Over the last 12 months, how often did your partner:; 1. Physically hurt you?; 2. Insult your or talk down to you?; 3. Threaten you with harm?; 4. Scream or curse at you?; 5. Force you to have sexual activities? | Each item is answered on a 5-point Likert scale:; - 1=never; - 2=rarely; - 3=sometimes; - 4=fairly often; - 5=frequently; Score range: 5–25 Cutoff for IPV: ≥7
PSQ^67^ | Parent Screening Questionnaire | 3 items assess occurrence of physical IPV and fear in the past year | 1. Have you ever been in a relationship in which you were physically hurt or threatened by a partner?; 2. In the past year, have you been afraid of a partner?; 3. In the past year, have you thought of getting a court order for protection? | Each item is answered yes/no Cutoff for IPV: Affirmative response to ≥1 items
OVAT^63,^ ^160^ | Ongoing Violence Assessment Tool | 4 items assess ongoing physical and emotional IPV | 1. At the present time, does your partner threaten you with a weapon?; 2. At the present time, does your partner beat you up so badly that you must seek medical help?; 3. At the present time, does your partner act like he/she would like to kill you?; 4. My partner has no respect for my feelings | Items 1, 2, and 4 are answered true/false Item 3 is answered on a 5-point Likert scale:; - 1=Never; - 2=Rarely; - 3=Occasionally; - 4=Frequently; - 5=Very frequently; Cutoff for IPV: Affirmative response to items 1+H5, 2, or 4; Response of ≥3 for item 3
PVS^64,^ ^160^ | Partner Violence Screen | 3 items that assess physical IPV in the last year and current safety | 1. Have you been hit, kicked, punched, or otherwise hurt by someone within the past year? If so, by whom?; 2. Do you feel safe in your current relationship?; 3. Is there a partner from a previous relationship who is making you feel unsafe now? | Each item is answered yes/no Cutoff for IPV: Affirmative response to ≥1 items (assuming person harming or making the respondent feel unsafe is a current or past partner)
HS-EAST^98,^ ^131^ | Hwalek-Sengstock Elder Abuse Screening Test | 15 items that screen for elder abuse | 1. Do you have anyone who spends time with you, taking you shopping or to the doctor?; 2. Are you helping to support someone?; 3. Are you sad or lonely often?; 4. Who makes decisions about your life-like how you should live or where you should live?; 5. Do you feel uncomfortable with anyone in your family?; 6. Can you take your own medication and get around by yourself?; 7. Do you feel that nobody wants you around?; 8. Does anyone in your family drink a lot?; 9. Does someone in your family make you stay in bed or tell you you’re sick when you know you’re not?; 10. Has anyone forced you to do things you didn’t want to do?; 11. Has anyone taken things that belong to you without your O.K.?; 12. Do you trust most of the people in your family?; 13. Does anyone tell you that you give them too much trouble?; 14. Do you have enough privacy at home?; 15. Has anyone close to you tried to hurt you or harm you recently? | All items (except item 4) are answered yes/no; item 4 answered by free response Responses associated with abuse are: “No” to items 1, 6, 12, and 14; “Someone else” to item 4; “Yes” to all other items Unclear cutoff for positive test^†^
BRFSS^73^ | Behavioral Risk Factor Surveillance Survey (modified by authors) | 3 items from Colorado BRFFS | 1. Thinking back over the past year, on any occasion were you hit, slapped, kicked, raped, or otherwise physically hurt by someone you know or knew intimately, such as a spouse, partner, ex-spouse or partner, boyfriend, girlfriend, or date?; 2. Considering your current partners or friends, or any past partners or friends, is there anyone who is making you feel unsafe now?; 3. In the past year, have the police ever been called to your home because of a fight or argument, no matter who was fighting or who was at fault?” | Each item is answered yes/no Cutoff for IPV: Affirmative response to ≥1 item(s)
WAST^75,^ ^160^ | Woman Abuse Screening Tool | 8 items assess physical and emotional IPV | 1. In general, how would you describe your relationship?; 2. Do you and your partner work out arguments with…; 3. Do arguments ever result in you feeling down or bad about yourself?; 4. Do arguments ever result in hitting, kicking or pushing?; 5. Do you ever feel frightened by what your partner says or does?; 6. Has your partner ever abused you physically?; 7. Has your partner ever abused you emotionally?; 8. Has your partner ever abused you sexually? | Item 1 is answered with: A lot of tension some tension, or no tension Item 2 is answered with great difficulty, some difficulty, or no difficulty Items 4–8 are answered with often, sometimes, or never Responses recoded such that higher score indicates higher frequency of experiences; scores should be summed for individuals who answer all items Cutoff for IPV: None provided
STaT^65,^ ^70^ | Slapped, Things, Threatened | 3 items (2 assess physical IPV, 1 assesses threats) | Have you ever been in a relationship where:; 1. Your partner has pushed or slapped you?; 2. Your partner threatened you with violence?; 3. Your partner has thrown, broken or punched things? | Each item is answered yes/no Scoring: Each affirmative response is given a score of 1 Cutoff for IPV: Score of ≥1
HARK^68^ | Humiliation, Afraid, Rape, Kick | 4 items assess emotional and physical IPV in the past year | 1. Within the last year, have you been humiliated or emotionally abused in other ways by your partner or your ex-partner?; 2. Within the last year, have you been afraid of your partner or ex-partner?; 3. Within the last year, have you been raped or forced to have any kind of sexual activity by your partner or ex-partner?; 4. Within the last year, have you been kicked, hit, slapped or otherwise physically hurt by your partner or ex-partner? | Each item is answered yes/no Scoring: Each affirmative response is given a score of 1 Cutoff for IPV: Score of ≥1
OAS^74,^ ^160^ | Ongoing Abuse Screen | 5 items adapted from the AAS that assess ongoing physical, sexual, emotional IPV, and fear | 1. Are you presently emotionally or physically abused by your partner or someone important to you?; 2. Are you presently being hit, slapped, kicked, or otherwise physically hurt by your partner or someone important to you?; 3. Are you presently forced to have sexual activities?; 4. Are you afraid of your partner or anyone of the following (circle if appropriate): husband/wife, ex-husband/ex-wife, boyfriend/girlfriend, stranger; 5. (If pregnant) Have you ever been hit, slapped, kicked, or otherwise physically hurt by your partner or someone important to you during pregnancy? | Each item is answered yes/no Cutoff for IPV: Affirmative response to ≥1 item(s)
AAS^74,^ ^160^ | Abuse Assessment Screen | 5 items assess physical, emotional, and sexual violence | 1. Have you ever been emotionally or physically abused by your partner or someone important to you?; 2. Within the last year, have you ever been hit, slapped, kicked, or otherwise physically hurt by someone?; 3. Since you’ve been pregnant, have you been slapped, kicked, or otherwise physically hurt by someone?; 4. Within the last year, has anyone forced you to have sexual activities?; 5. Are you afraid of your partner or anyone listed above? | Items 1 and 5 are answered yes/no; if items 2, 3, or 4 are answered yes, participant is asked to indicate category of abuser (Circle all that apply: husband, ex-husband, boyfriend, stranger, other, multiple); for items 2 and 3, participants are asked to mark the area of injury on a body map. For each violence incident, items are scored based on severity of (1–6)^ǂ^ Cutoff for IPV: Affirmative response to ≥1 item(s)

* Cutoff for positive score here reflects widely accepted value; one included IPV test accuracy study^72^ used a cutoff value of ≥6.

† We found no widely agreed upon standard for what constitutes a positive test. In general, higher scores indicate higher risk of being abused, neglected, or exploited. The one included study in this review considered positive responses to questions 5, 7, 9, 10, 11, 13, and 15 to indicate high risk of elder mistreatment.^98^

ǂ Scores are based on the following: 1=Threats of abuse including use of weapon; 2=Slapping, pushing; no injuries and/or lasting pain; 3=Punching, kicking, bruises, cuts, and/or continuing pain; 4=Beating up, severe contusions, burns, broken bones; 5=Head injury, internal injury, permanent injury; 6=Use of weapon; wound from weapon.

Abbreviation: IPV=intimate partner violence.

Appendix F Table 2 IPV Consequences of Screening Tool (COST) Effects on Quality-of-Life Subscale^*^

Consequences of Item (Response Options) | Scoring, Range, and Interpretation
1. For me, I feel that being asked the questions on partner violence was (Good, Somewhat good, Neither good nor bad, Somewhat bad, or Bad); 2. Because the questions on partner violence were asked, I feel my home life has become (Less difficult, Somewhat less difficult, Neither less nor more difficult, Somewhat more difficult, or More difficult); 3. Because the questions on partner violence were asked, my feelings about my relationship with my partner are (More positive, Somewhat more positive, Neither more nor less positive, Somewhat more negative, or More negative); 4. Because the questions on partner violence were asked, I see the quality of my own life as being (Better, Somewhat better, Neither better nor worse, Somewhat worse, or Worse); 5. Because the questions on partner violence were asked, the people in my community who are usually ‘there’ for me for emotional support are (More available, Somewhat more available, Neither more nor less available, Somewhat less available, or Less available); 6. Because the questions on partner violence were asked, my feelings about myself as a person are (Better, Somewhat better, Neither better nor worse, Somewhat worse, or Worse); 7. Because the questions on partner violence were asked, I feel that the problems in my relationship with my partner are my fault. (Disagree, Somewhat disagree, Neither disagree not agree, Somewhat agree, or Agree); 8. Because the questions on partner violence were asked, my financial situation has become (Better, Somewhat better, Neither better nor worse, Somewhat worse, or Worse) | Each item is answered on a 5-point Likert scale; items are coded 2 through −2 (range 16 to −16). Positive scores indicate benefit while negative scores reflect harm.

* As Described in MacMillan et al, 2009.

Abbreviations: COST=Consequences of Screening Tool; IPV=intimate partner violence.