# Appendix E Quality Assessments

Appendix E Table 1 Quality Assessment of Randomized, Controlled Trials (KQs 1 and KQ 3): Part 1

Author, Year | Was randomization adequate? | Was allocation concealment adequate? | Are baseline characteristics similar between groups? | Did the study have cross-overs or contamination raising concern for bias? | Was the eligibility criteria specified? | Were outcome assessors masked? | Were providers masked? | Were patients masked?
Klevens et al, 2012^57^ Klevens et al, 2015^60^ | Yes | Unclear | Yes | No | Yes | Yes | NA | No
Koziol-McLain et al, 2010^58^ | Yes | Yes | Mostly | No | Yes | Unclear | NA | NA
MacMillan et al, 2009^59^ | Unclear | Unclear | Mostly | No | Yes | Yes | No | No

Abbreviations: KQ=key question; NA=not available.

Appendix E Table 2 Quality Assessment of Randomized, Controlled Trials (KQs 1 and KQ 3): Part 2

Author, Year | What was the overall attrition? | What was the differential attrition? | Did the study have differential attrition or overall high attrition raising concern for bias? | Did the study use acceptable statistical methods? | Were outcome measures valid and reliable? | Was the duration of followup adequate to assess the outcome?
Klevens et al, 2012^57^ Klevens etl al, 2015^60^ | 1 year: 13%; 3 years (health care utilization only): 1% | 1 year: 0–2% across groups; 3 years: 0% | No | Yes | Yes | Yes
Koziol-McLain et al, 2010^58^ | 14% | 4% | No | Yes | Yes | Yes
MacMillan et al, 2009^59^ | 42% at 18 months | 2% at 18 months | Yes | Yes | Yes | Yes

Abbreviations: ITT=intention to treat; KQ=key question; vs.=versus.

Appendix E Table 3 Quality Assessment of Randomized, Controlled Trials (KQs 1 and KQ 3): Part 3

Author, Year | Was an appropriate method used to handle missing data? | Quality Rating | Comments
Klevens et al, 2012^57^ Klevens, 2015^60^ | Yes | Good | Overall attrition was relatively low (13% for primary outcomes at 1 year); authors also used imputation in models to assess the effect of missing data. Allocation concealment was not described in detail, but this is unlikely to lead to significant bias.
Koziol-McLain et al, 2010^58^ | Yes | Fair | Compared with the control group (no screening group), women in the treatment group were older, more likely to be New Zealand European, and more likely to have been admitted to the hospital before randomization.
MacMillan et al, 2009^59^ | Yes | Fair | Clinic days (or shifts) were randomized to screening vs. control condition; randomization procedure is not described. Population characteristics reported for screened and nonscreened groups who were “retained” vs. “lost” to followup. For those who were retained, characteristics are mostly similar across groups. Women lost to followup had higher IPV scores on WAST and CAS. Risk of selection bias due to high attrition; for primary outcomes, analyses used multiple imputation to address missing data.

Abbreviations: CAS=Composite Abuse Scale; IPV=intimate partner violence; KQ=key question; WAST=Woman Abuse Screening Tool.

Appendix E Table 4 Quality Assessment of Diagnostic Accuracy Studies (KQ 2): Part 1

Author, Year | Were population selection criteria clearly described? | Was the spectrum of participants representative of patients who will receive the test in primary care? | Did the whole or a random selection of participants receive the test? | Adequate sample size? (>50) | What is the response rate? | What was the overall attrition? | Was attrition explained? | Did the study have high attrition raising concern for bias?
Buri et al, 2009^154^ | Partially | Unclear | Whole | No | 70% | 35% (see notes) | Yes | Unclear
Chen et al, 2005^66^ | Yes | Yes | Whole | Yes | 52% of those eligible participated | Unclear | Yes | Unclear
Dubowitz et al, 2008^67^ | Yes | Yes | Whole | Yes | 75% (382/507) of eligible mothers agreed to participate; of these 81% (308/382) completed the study protocol | 35% (108/308) excluded from analyses for not completing the protocol within 2 months or not answering all questions on the CTS-2 | Yes | Yes
Ernst et al, 2004^63^ | Partially | Unclear | Whole | Yes | NA (see comments) | 15% (306/362 eligible participants) | Yes | No
Feldhaus et al, 1997^64^ | Yes | Yes | Whole | Yes | NA | ISA: 21.7%; CTS: 14% | Partially | Yes
Fulmer et al, 2012^98^ | Partially | Unclear | Whole | Yes | NA | 0% (none reported) | NA | No
Houry et al, 2004^140^ | Yes | Unclear | Whole | Yes | 22% of eligible participants declined to participate | 55.3% (119/215) did not participate in 4-month interview | Partially | Yes
Iverson et al, 2013^71^ | Yes | Unclear | Whole | Yes | 64% | 11% (see notes) | Yes | No
Iverson et al, 2015^72^ | Yes | Unclear | Whole | Yes | 50% | 49% (see notes) | Partially | Yes
Kita et al, 2017^155^ | Yes | Yes | Whole | Yes | 87% (initial survey); 60%) postnatal survey | 54% (see notes) | Partially | Yes
Koziol-McLain et al, 2001^73^ | Yes | Yes | Whole | Yes | 98% | 60% | Yes | Yes
MacMillan et al, 2006^75^ | Yes | Yes | Whole | Yes | NA (see comments) | NR | No | Unclear
McNut, et al, 2002^156^ | Yes | Unclear | Random | Yes | NA | Unclear | No | Unclear
Mills et al, 2006^62^ | Partially | Unclear | Whole | Yes | 47% | 4% | Yes | No
Paranjape et al, 2003^65^ | Yes | Yes | Whole | Yes | NA | 0 | Yes | No
Paranjape et al, 2006^70^ | Yes | Yes | Whole | Yes | NA | NR | Yes | No
Shakil et al, 2005^157^ | Yes | Yes | Whole | Yes | NA | 19% | Yes | No
Sohal et al, 200 | Yes | Yes | Whole | Yes | 54% | 0 | Yes | No
Wathen et al, 2008^76^ | Yes | Yes | Whole | Yes | NA | 17% | Yes | No
Weiss et al, 2003^74^ | Yes | Yes | Whole | Yes | NA | 19% | Yes | No
Zink et al, 2007^69^ | Yes | Yes | Whole | Yes | NA | 2% | Yes | No

Abbreviations: CTS=Conflicts Tactics Scale; ISA=Index of Spouse Abuse; KQ=key question; NA=not available; NR=not reported.

Appendix E Table 5 Quality Assessment of Diagnostic Accuracy Studies (KQ 2): Part 2

Author, Year | Credible reference standard used? | Is the screening test relevant, available for primary care and adequately described? | Were the test results interpreted independently (blinded)? | Did all patients receive the reference standard regardless of screening results? | Was the cut-point (or threshold) used to determine test positivity adequately described (or referenced)?
Buri et al i, 2009^154^ | Yes | See comments | Unclear | Yes | Yes
Chen, 2005^66^ | Unclear | Yes | Unclear | Yes | Yes
Dubowitz et al, 2008^67^ | Yes | Yes | NA | Yes | Yes
Ernst et al, 2004^63^ | Yes | See comments | Unclear | Yes | Yes
Feldhaus et al, 1997^64^ | Yes | Yes | Unclear | Yes | Yes
Fulmer et al, 2012^98^ | Yes | Yes | Unclear | Yes | Yes
Houry et al, 2004^140^ | Yes | Yes | Yes | Yes | Yes
Iverson et al, 2013^71^ | Yes | Yes | Unclear | Yes | Yes
Iverson et al, 2015^72^ | Yes | Yes | Unclear | Yes | Yes
Kita et al, 2017^155^ | Yes | Yes | Unclear | Yes | Yes
Koziol-McLain et al, 2001^73^ | Yes | Yes | Unclear | Yes | Yes
MacMillan et al, 2006^75^ | Yes | Yes | Unclear | Yes | Yes
McNutt et al, 2002^156^ | Yes | Yes | Unclear | Yes | Yes
Mills et al, 2006^62^ | Yes | Yes | NA | Yes | Yes
Paranjape et al, 2003^65^ | Yes | Yes | Unclear | Yes | Yes
Paranjape et al, 2006^70^ | Yes | Yes | Yes | Yes | Yes
Shakil et al, 2005^157^ | Unclear | Yes | NA | Yes | Yes
Sohal et al, 2007^68^ | Yes | Yes | Yes | Yes | Yes
Wathen et al, 2008^76^ | Yes | Yes | Yes | Yes | Yes
Weiss et al, 2003^74^ | Yes | Yes | Yes | Yes | Yes
Zink et al, 2007^69^ | Yes | Yes | Unclear | Yes | Yes

Abbreviations: KQ=key question; NA=not available.

Appendix E Table 6 Quality Assessment of Diagnostic Accuracy Studies (KQ 2): Part 3

Author, Year | Were methods for calculating accuracy clearly reported and valid? | Quality Rating | Comments
Buri et al, 2009^154^ | No | Poor | Eligible participants were those referred to a social service agency; reasons for referrals are not clear. High risk of selection bias; 49 of 70 invited elders agreed to participate, of these 32 completed both questionnaires. The “gold standard” was one of the following: expert social worker assessment of abuse or report of abuse to state services or police. Authors assessed the accuracy of four different screening tools at the same time, meaning 34 abuse questions were asked during the same phone interview. Screening process does not reflect conditions in primary care.
Chen et al, 2005^66^ | Yes | Fair | Of 386 women eligible to participate, 56 did not complete the questionnaire “due to the long waiting period for an available private room” and 128 refused to participate. Reasons for refusal were not described. The extent to which ISA-P is a credible reference standard is not clear.
Dubowitz et al, 2008^67^ | Yes | Fair | Risk of selection bias, primarily due to high rate of missing data.
Ernst et al, 2004^63^ | Yes | Fair | Applicability to primary care settings unclear; patients recruited from one ED setting who were presenting for medical complaints (79%), trauma complaints (18%), and 1% specifically for IPV-related complaints.
Feldhaus et al, 1997^64^ | Yes | Fair | Applicability to primary care unclear; participants were recruited from an ED setting, and a small minority of the population were presenting with acute injuries related to IPV.
Fulmer et al, 2012^98^ | NA (calculated) | Fair | Participants were those presenting for routine dental care; no details were provided regarding whether patients had signs or symptoms of abuse. The method of scoring the screening test and gold standard are described but were determined by the authors (and are of unclear validity). Screening tests results were compared with subscores of the CTS; any CTS subscore >0 was considered positive.
Houry et al, 2004^140^ | Yes | Poor | High risk of selection bias due to high rates of missing data. Women who could not be contacted for the 4-month followup interview had a higher positive IPV screen compared with women who participated (22% vs. 9%, respectively).
Iverson et al, 2013^71^ | Yes | Good | Overall response rate to survey was 63%; of those that responded, 49% (N=179) were eligible (had an intimate partner relationship in the past year). Women who completed only one or neither of the IPV instruments were excluded from the study sample (11%) used to measure screening test accuracy.
Iverson et al, 2015^72^ | Yes | Fair | Spectrum of patients appears to be representative of women veterans seeking care at VA primary care centers; this may or may not be representative of non-VA primary care centers. Authors note that of the survey responders 55% reported past-year involvement in an intimate relationship, completed all IPV instruments and were included in the study. It is not clear how many were excluded because they did not complete one instrument vs. not being involved in a relationship.
Kita et al, 2017^155^ | No | Poor | High rate of missing data. Of those invited, 87% (832/955) completed surveys during pregnancy; of those who gave birth to a live infant at the research hospital (n=824), 60% (n=610) responded to postnatal survey. Of these, 453 were analyzed; reasons for exclusion were excessive blanks (n=116) and late responses (>2 months; n=41). In total, attrition was 54%. Unclear why authors do not provide sensitivity/specificity for the inital sample who completed the WAST and ISA; no characteristics are described for the initial and analyzed sample to determine whether IPV incidence and other characteristics differ.
Koziol-McLain et al, 2001^73^ | Yes | Fair | High attrition; of those who responded to the initial survey, 40% did not have followup data. The tool was designed to assess the predictive ability of an IPV screen for future violence.
MacMillan et al, 2006^75^ | No | Fair | Study reports on accuracy but is primarily focused on comparing different screening modalities. Flow of participants is shown in figure. However, methods used to handle missing data/attrition for accuracy measures are not reported. Unclear whether screening test and gold standard are interpreted independently.
McNutt et al, 2002^156^ | Yes | Poor | The study is part of a nonrandomized trial assessing a multicomponent IPV screening and treatment intervention. Women with a known history of IPV were eligible for screening (in addition to those who had not been screened in the past). The flow of participants eligible for assessment of screening test accuracy is unclear; the results of a random sample of telephone interviews were compared with results of screening tests performed independently. Based on the way data are presented, the amount of missing data is unclear. Authors only present data that allow comparison of sensitivity/specificity of screening to predict severe or moderate-to-severe levels of abuse (not any abuse).
Mills et al, 2006^62^ | Yes | Fair | Spectrum of patients likely to be higher risk than those seen in primary care settings; the overall sample size is adequate but small (N=53 analyzed).
Paranjape et al, 2003^65^ | Yes | Fair | Unclear whether the interviewer administering the semistructured interview or categorizing individuals is the same person as who administered the screening items. No missing data described; 7% of the population reported never being in an intimate relationship.
Paranjape et al, 2006^70^ | Yes | Fair | Extent of missing data is not clear; no statement of whether tests were interpreted blindly.
Shakil et al, 2005^157^ | No | Poor | Spectrum of patients is representative for Phase 1 only. The self-identified group was not administered the gold standard (CTS). Unclear how accuracy measures were calculated; CTS appears to be used for correlational purposes only.
Sohal et al, 2007^68^ | No | Fair | Study considers response rate to be those who agreed (54%), but this was in person and not by mail/email. Text says CAS identified 53 women experiencing IPV, but Figure 1 says it is 50; sensitivity calculated using numbers in figure do not match those in Table 3.
Wathen et al, 2008^76^ | Yes | Fair | Potential selection bias related to attrition and unclear handling of missing data.
Weiss et al, 2003^74^ | Yes | Fair | Applicability to primary care unclear (population recruited from an ED setting); 19% of sample did not complete one or more questionnaires.
Zink et al, 2007^69^ | Yes | Fair | There are minor discrepancies in the article in terms of the number of participants analyzed; unclear whether results are interpreted blindly (per methods, study PI checked data).

Abbreviations: CAS=Composite Abuse Scale; CTS=Conflict Tactics Scale; CTS2=Revised Conflict Tactics Scale; ED=emergency department; IPV=intimate partner violence; ISA-P=Index of Spouse Abuse-Physical Scale; KQ=key question; N=sample; NA=not applicable; PI=primary investigator; VA=Veterans Affairs.

Appendix E Table 7 Quality Assessment of Randomized, Controlled Trials (KQs 4 and 5): Part 1

Author, Year | Was randomization adequate? | Was allocation concealment adequate? | Are baseline characteristics similar between groups? | Did the study have cross-overs or contamination raising concern for bias? | Was the eligibility criteria specified? | Were outcome assessors masked? | Were providers masked? | Were patients masked?
Bair-Merritt et al, 2010^80^ | Yes | NA | Mostly | Unclear | Yes | Yes | No | No
Curry et al, 2006^139^ | Unclear | Unclear | No | Unclear | Yes | Unclear | No | No
El-Mohandes et al, 2008^82^ El-Mohandes, 2011^92^ Kiely, 2010^85^ | Yes | NA | Yes | Unclear | Yes | Unclear | No | No
Hegarty et al, 2013^86^ | Yes | Yes | Mostly | Unclear | Yes | Yes | No | No
McFarlane et al, 2000^128^ | Unclear | Yes | Yes | Yes | Yes | Unclear | No | No
McFarlane et al, 2006^158^ | No | No | Mostly | No | Yes | Unclear | No | No
Miller et al, 2011^89^ | Yes | Unclear | Mostly | No | Yes | Yes | No | No
Miller et al, 2016^88^ | Yes | Unclear | Yes | Unclear | Yes | Yes | No | Yes
Rhodes et al, 2015^87^ | Yes | Yes | Mostly | No | Yes | Unclear | No | No
Saftlas et al, 2014^91^ | Yes | Yes | Mostly | Unclear | Yes | No | NA | NA
Sharps et al, 2015^81^ | Unclear | Yes | Mostly | No | Yes | Yes | No | No
Tiwari et al, 2005^83^ | Yes | Yes | Mostly | No | Yes | Yes | No | No
Tiwari et al, 2010^94^ Tiwari et al, 2012^90^ | Yes | Yes | Yes | No | Yes | Yes | NA | NA
Zhang et al, 2013^159^ | Unclear | Unclear | Unclear | No | Yes | Yes | NA | NA
Zlotnick et al, 2011^84^ | Yes | Yes | Mostly | No | Yes | Unclear | No | No

Abbreviations: KQ=key question; NA=not available

Appendix E Table 8 Quality Assessment of Randomized, Controlled Trials (KQs 4 and 5): Part 2

Author, Year | What was the overall attrition | What was the differential attrition? | Did the study have differential attrition or overall high attrition raising concern for bias? | Did the study use acceptable statistical methods? | Were outcome measures valid and reliable? | Was the duration of followup adequate to assess the outcome?
Bair-Merritt et al, 2010^80^ | 11% lost to followup | 6% across groups | No | Yes | Yes | Yes
Curry et al, 2006^139^ | NR | NR | Unclear | Unclear | Unclear | Yes
El-Mohandes et al, 2008^82^ El-Mohandes et al, 2011^92^ Kiely et al, 2010^85^ | 26% (190/723 with risk factors) | 4% | Yes | Yes | Unclear | Yes
Hegarty et al, 2013^86^ | 6% (doctors); 28% (individual patients) | 4% (doctors); 4% (individual patients) | No | Yes | Yes | Yes
McFarlane et al, 2000^128^ | 2 months: 11%; 6 months: 15%; 12 months: 18%; 18 months: 21%; 24 months: 44% | 3 groups: maximum differential attrition is 9% | Yes | No | Yes | Yes
McFarlane et al, 2006^158^ | 11% at 24 months | 1.70% | No | No | Yes | Yes
Miller et al, 2011^89^ | 25% | NR | Yes | Yes | Yes | Yes
Miller et al, 2016^88^ | 21% at 12 months (see comments) | 0% at 3 months; 5% at 12 months | Yes | Yes | Yes | Yes
Rhodes et al, 2015^87^ | 22%, 21% and 29% did not complete the 3-, 6-, and 12-month interview (respectively) | 1–2% across groups at 3 months | Yes | Yes | Yes | Yes
Saftlas et al, 2014^91^ | 33% (includes two with missing data) | 8% | Yes | Yes | Yes | Yes
Sharps et al, 2015^81^ | Varied by outcome timing; at 24 months: 55% | 8% at 24 months | Yes | Yes | Yes | Yes
Tiwari et al, 2005^83^ | 4% | 7% | No | Yes | Yes | Yes
Tiwari et al, 2010^94^ Tiwari et al, 2012^90^ | 0% | 0% | No | NA | Yes | Yes
Zhang et al, 2013^159^ | 59% | 14% | Yes | No | Yes | Yes
Zlotnick et al, 2011^84^ | 15% | Unclear | Unclear | Yes | Yes | Yes

Abbreviations: ITT=intention to treat; KQ=key question; NA=not available; NR=not reported.

Appendix E Table 9 Quality Assessment of Randomized, Controlled Trials (KQs 4 and 5): Part 3

Author, Year | Was an appropriate method used to handle missing data? | Quality Rating | Comments
Bair-Merritt et al, 2010^80^ | Yes | Fair | Slightly more women in the control group had baseline problem alcohol use and fewer were employed in the past year compared with the intervention group. Compliance with intervention home visits waned over time: 90% families participated at 3 months, 70% at 6 months, 49% at 12 months, and 25% at 36 months; overall, 75% discontinued intervention by year 3. Overall and differential attrition were high, but authors addressed missing data using imputation.
Curry et al, 2006^139^ | No | Poor | Randomization and allocation concealment are not described. Attrition is not well described. Potential measurement bias (validity of stress scores is not clear); and comparison is only made between subgroups that were labeled as high risk.
El-Mohandes et al, 2008^82^ El-Mohandes et al, 2011^92^ Kiely et al, 2010^85^ | Yes | Fair | Risk of selection bias; 31% of women approached declined to participate. Of those who agreed and met eligibility criteria, 15% declined further participation. For primary analysis of risk factor reduction, only those with risk at baseline were analyzed. Among this subgroup, 26% (overall) did not complete a postpartum interview. Analyses used imputation to control for missing data. Self-report of some risks may be subject to measurement bias (e.g., recall bias).
Hegarty et al, 2013^86^ | Yes | Fair | This is a cluster-randomized trial. Individual physicians (one in each practice) was randomized to intervention or control. Individual patient characteristics are mostly similar; however, slightly more women in the comparison group were married, living with a partner, and had children younger than 18 years of age. Characteristics of physicians randomized were similar.
McFarlane et al, 2000^128^ | Unclear | Poor | High attrition and unclear number of participants analyzed at various time points. Unclear handling of missing data. Randomization is not described well.
McFarlane et al, 2006^158^ | No | Poor | High risk of selection bias; method of randomization may not be adequate (randomization was by week, nurse was informed at the beginning of each week as to whether it was an active intervention or control week). Slightly higher percentage of Hispanic women and lower percentage of white women in the case-management group compared with controls.
Miller et al, 2011^89^ | No | Fair | Participants differed slightly at baseline for IPV and birth control sabotage; overall attrition is high (differential attrition is not clear).
Miller et al, 2016^88^ | Yes | Fair | Overall attrition was 21% at 12 months (defined as % of eligible patients who completed the survey); participants lost to followup had a higher baseline prevalence of IPV. Analyses controlled for missing data by using imputation. Usual care (related to IPV screening/referral practices) at control sites is not well described.
Rhodes et al, 2015^87^ | Yes | Fair | Baseline characteristics are mostly similar between groups; exceptions include fewer women in the no-contact group had higher rates of IPV at baseline, and more women in the assessed control group had previously used community-based IPV services compared with intervention group (10% vs. 4%). Although overall attrition is >20%, there was no differential attrition and the majority of those randomized (592 of 600) were included in the primary analyses (days of heavy drinking and number of IPV events).
Saftlas et al, 2014^91^ | Unclear | Fair | High overall attrition, but no significant differential attrition.
Sharps et al, 2015^81^ | Yes | Fair | Risk of selection bias and high overall attrition (55% at 24 months). Randomization procedures varied by site; at urban centers, randomization was by participant (using computer-generated number assignments) and rural health agencies (six sites were cluster randomized. Method of cluster randomization unclear.
Tiwari et al, 2005^83^ | Yes | Fair | More women in the intervention group were married, had a paid job, and had a higher family income compared with women in the control group.
Tiwari et al, 2010^94^ Tiwari et al, 2012^90^ | Yes | Good
Zhang et al, 2013^159^ | No | Poor | Very high attrition with unclear handling of missing data. Randomization procedure unclear; there were some baseline differences between groups.
Zlotnick et al, 2011^84^ | Unclear | Fair | Unclear whether outcome assessors were masked to treatment group. Overall sample size is small (N=54) with 15% overall attrition. Authors do not describe or provide data to calculate differential attrition.

Abbreviations: IPV=intimate partner violence; KQ=key question; N=sample; vs.=versus.

Appendix E Table 10 Quality Assessment of Randomized, Controlled Trials: Additional Questions for Studies Reporting Harms (KQ 5 only)

Author, Year | Were harms prespecified and defined? | Were ascertainment techniques for harms adequately described? | Were ascertainment techniques for harms equal, valid, and reliable? | Was duration of followup adequate for harms assessment? | Harms Quality Rating | Comments
Hegarty et al, 2013^86^ | Yes | Yes | Unclear | Yes | Fair
Rhodes et al, 2015^87^ | Unclear | Unclear | Unclear | Yes | Fair | Authors note that “participant safety was carefully tracked … no harms related to the intervention were identified.” The scope of harms ascertained (outside of main outcomes) is not clear. Ascertainment techniques for IPV events appears equal, valid, and reliable. Not clear whether authors assessed other harms (e.g., labeling).
Sharps et al, 2015^81^ | No | Unclear | Unclear | Yes | Fair | Unclear whether intervention-related harms were prespecified and how they were ascertained.
Tiwari et al, 2005^83^ | Yes | Yes | Unclear | Yes | Fair | Women were asked if they experienced an increase in violence due to participation in the study. Unclear if this is a reliable measure of harm.
Tiwari et al, 2010^94^ Tiwari et al, 2012^90^ | Unclear | Partially | Unclear | Yes | Fair

Abbreviations: IPV=intimate partner violence; KQ=key question.