# Appendix D Overview of 2004/2012 Studies Excluded From Current Report

Authors, Year | KQ; Exclusion Reason | Additional Information
Included in 2004 report
Brown et al, 2000^120^ | KQ 2; Wrong outcome | No eligible outcomes assessed
Canterino et al, 1999^121^ | KQ 2; Wrong outcome | No eligible outcomes assessed
Coker et al, 2001^122^ | KQ 2; Wrong comparator | No gold standard/validated instrument used as a comparator
Ernst et al, 2002^123^ | KQ 2; Wrong comparator | No gold standard/validated instrument used as a comparator
Furbee et al, 1998^124^ | KQ 2; Wrong comparator | No gold standard/validated instrument used as a comparator
Glass et al, 2001^125^ | KQ 2; Wrong design | No comparison group and no eligible outcomes
McFarlane et al, 1991^126^ | KQ 2; Wrong comparator | No gold standard/validated instrument used as a comparator
McFarlane et al, 1992^127^ | KQ 2; Wrong outcome | No relevant outcomes assessed
McFarlane et al, 2000^128^ | KQ 2; Poor quality | High attrition (no or unclear handling of missing data); unclear number of participants analyzed at various time points
Moody et al, 2000^129^ | KQ 2 (EA); Wrong comparator | No gold standard/validated instrument used as a comparator
Morrison et al, 2000^130^ | KQ 2; Wrong comparator | No eligible comparator and no eligible outcomes
Neale et al, 1991^131^ | KQ 2 (EA); Wrong comparator | No gold standard/validated instrument used as a comparator
Norton et al, 1995^132^ | KQ 2; Wrong comparator | No gold standard/validated instrument used as a comparator
Pan et al, 1997^133^ | KQ 2; Wrong outcome | No eligible outcomes assessed
Parker et al. 1999^134^ | KQ 2; Wrong outcome | No eligible outcomes assessed
Reis et al. 1995^135^ | KQ 2 (EA); Wrong comparator | No gold standard/validated instrument used as a comparator
Sherin et al, 1998^136^ | KQ 2; Wrong outcome | No eligible outcomes assessed
Smith et al, 1995^137^ | KQ 2; Not original research | Expert review
Included in 2012 report
Chang et al, 2003^138^ | KQ 5; Wrong design | Wrong design (focus group study, no comparator)
Curry et al, 2006^139^ | KQ 4; Poor quality | Randomization and allocation concealment not described; attrition is not well described; risk of measurement bias (validity of stress scores is not clear); comparison is only made between subgroup that was labeled as high risk
Fulfer et al, 2007^77^ | KQ 2; Wrong comparator | No gold standard/validated instrument used as a comparator
Houry et al, 2004^140^ | KQ 2; Poor quality | High rates of missing data; women who could not be contacted for the 4-month followup interview had a higher IPV exposure compared with women who participated (22% vs. 9%, respectively)
Houry et al, 2008^141^ | KQ 5; Wrong design | Cohort study; single group, no eligible comparator
Hurley et al, 2005^142^ | KQ 5; Wrong design | Survey of patients’ opinion related to screening
Koziol-McLain et al, 2008^143^ | KQ 5; Wrong design | Focus group study
Liebschutz et al, 2008^144^ | KQ 5; Wrong design | Focus group study
McFarlane et al, 2006^128^ | KQ 5; KQ 4; Poor quality | High attrition (with no or unclear handling of missing data); unclear number of participants analyzed at various time points.
Peralta et al, 2003^145^ | KQ 2; Wrong comparator | No gold standard/validated instrument used as a comparator
Reichenheim et al,^146^ | KQ 2; Wrong country | Conducted in Brazil
Renker et al, 2006^147^ | KQ 5; Wrong design | Cohort study, no concurrent control group
Sethi et al, 2004^148^ | KQ 5; Wrong design | Cohort study; no concurrent control group
Spangaro et al, 2010^149^ | KQ 5; Wrong design | Qualitative study and no comparison group.
Spangaro et al, 2010^150^ | KQ 5; Wrong design | Cohort study; no concurrent control group
Taft et al, 2011^100^ | KQ 4; Wrong population | Participants identified based on abuse symptoms (“case-finding”) or self-disclosure
Thombs et al, 2007^151^ | KQ 2; Wrong screening tool | Tool detects childhood abuse among adults, not IPV or elder abuse.
Weinsheimer et al, 2005^152^ | KQ 5; Wrong population | Participants are trauma patients
Zeitler et al, 2006^153^ | KQ 5; Wrong design | Cohort study; no concurrent control group

Abbreviation: EA=Elder abuse; IPV=intimate partner violence; KQ=key question.