# Appendix C Excluded Studies

- X1: Not Original Research
- X2: Ineligible population
- X3: Ineligible screening tool/intervention
- X4: Ineligible treatment intervention
- X5: Ineligible or no comparator
- X6: No relevant outcome reported
- X7: ineligible study design
- X8: Ineligible setting
- X9: Ineligible country
- X10: Non-English
- X11: Irretrievable
- X12: Excluded by previous report
- X13: Poor quality

1 Allen CT, Swan SC, Maas CD, . A Comparison of the Structural Factors of the Propensity for Abusiveness Scale for Women and Men in a Domestic Violence Treatment Program. J Interpers Violence. 2015 Aug;30(13):2326–43. doi: 10.1177/0886260514552450. PMID: 25304668. Exclusion Code: X 2.25304668
2 Alon S, Berg-Warman A. Treatment and prevention of elder abuse and neglect: where knowledge and practice meet-a model for intervention to prevent and treat elder abuse in Israel. J Elder Abuse Negl. 2014;26(2):150–71. doi: 10.1080/08946566.2013.784087. PMID: 24499281. Exclusion Code: X 11.24499281
3 Alpert EJ. Domestic violence and clinical medicine: learning from our patients and from our fears. J Gen Intern Med. 2002 Feb;17(2):162–3. doi: [pii]. PMID: 11841533. Exclusion Code: X 1.11841533
4 Alvarez CP, Davidson PM, Fleming C, . Elements of Effective Interventions for Addressing Intimate Partner Violence in Latina Women: A Systematic Review. PLoS One. 2016;11(8):e0160518. doi: 10.1371/journal.pone.0160518. PMID: 27504833. Exclusion Code: X 7.27504833
5 Amar A, Laughon K, Sharps P, . Screening and counseling for violence against women in primary care settings. Nurs Outlook. 2013 May-Jun;61(3):187–91. PMID: 23814797. Exclusion Code: X 1.23814797
6 Ameh N, Shittu SO, Abdul MA. Risk scoring for domestic violence in pregnancy. Niger J Clin Pract. 2008 Mar;11(1):18–21. PMID: 18689133. Exclusion Code: X 5.18689133
7 An S, Choi YJ. A Review and Assessment of Intimate Partner Violence Interventions and Trainings for Service Providers and Frontline Staff. Violence Vict. 2017 Jun 01;32(3):379–404. doi: 10.1891/0886-6708.VV-D-14-00111. PMID: 28516836. Exclusion Code: X 7.28516836
8 Anglin D, Sachs C. Preventive care in the emergency department: screening for domestic violence in the emergency department. Acad Emerg Med. 2003 Oct;10(10):1118–27. PMID: 14525748. Exclusion Code: X 7.14525748
9 Attala JM, Hudson WW, McSweeney M. A partial validation of two short-form Partner Abuse Scales. Women Health. 1994;21(2-3):125–39. doi: 10.1300/J013v21n02_08. PMID: 8073783. Exclusion Code: X 5.8073783
10 Aupperle RL, Allard CB, Simmons AN, . Neural responses during emotional processing before and after cognitive trauma therapy for battered women. Psychiatry Res. 2013 Oct 30;214(1):48–55. doi: 10.1016/j.pscychresns.2013.05.001. PMID: 23916537. Exclusion Code: X 2.23916537
11 Ayalon L, Lev S, Green O, . A systematic review and meta-analysis of interventions designed to prevent or stop elder maltreatment. Age Ageing. 2016;45(2):216–27. Exclusion Code: X 7.26744361
12 Bacchus LJ, Bewley S, Vitolas CT, . Evaluation of a domestic violence intervention in the maternity and sexual health services of a UK hospital. Reprod Health Matters. 2010 Nov;18(36):147–57. doi: 10.1016/S0968-8080(10)36526-8. PMID: 21111359. Exclusion Code: X 5.21111359
13 Bair-Merritt MH, Lewis-O’Connor A, Goel S, . Primary care-based interventions for intimate partner violence: a systematic review. Am J Prev Med. 2014 Feb;46(2):188–94. doi: 10.1016/j.amepre.2013.10.001. PMID: 24439354. Exclusion Code: X 7.24439354
14 Baker PR, Francis DP, Hairi NN, . Interventions for preventing abuse in the elderly. Cochrane Database Syst Rev. 2016 Aug 16(8):CD010321. doi: 10.1002/14651858.CD010321.pub2. PMID: 27528431. Exclusion Code: X 7.27528431
15 Beck AF, Klein MD. Moving From Social Risk Assessment and Identification to Intervention and Treatment. Acad Pediatr. 2016 Mar;16(2):97–8. doi: 10.1016/j.acap.2016.01.001. PMID: 26791277. Exclusion Code: X 1.26791277
16 Bender AK. Using the Consolidated Framework for Implementation Research to Increase Provider Screening for Intimate Partner Violence in Rural Health Clinics. Womens Health Issues. 2016 Jul-Aug;26(4):384–92. doi: 10.1016/j.whi.2016.05.005. PMID: 27365285. Exclusion Code: X 2.27365285
17 Bennett L, Riger S, Schewe P, . Effectiveness of hotline, advocacy, counseling, and shelter services for victims of domestic violence: a statewide evaluation. J Interpers Violence. 2004 Jul;19(7):815–29. doi: 10.1177/0886260504265687. PMID: 15186538. Exclusion Code: X 5.15186538
18 Bergman B, Brismar B. A 5-year follow-up study of 117 battered women. Am J Public Health. 1991 Nov;81(11):1486–9. PMID: 1951810. Exclusion Code: X 4.1951810
19 Bhattacherjee S. Intimate partner violence affects men as well as women. BMJ. 2014;348:g3771. PMID: 24943739. Exclusion Code: X 1.24943739
20 Bloom TL, Glass NE, Case J, . Feasibility of an online safety planning intervention for rural and urban pregnant abused women. Nurs Res. 2014 Jul-Aug;63(4):243–51. doi: 10.1097/NNR.0000000000000036. PMID: 24977721. Exclusion Code: X 6.24977721
21 Boland B, Burnage J, Chowhan H. Safeguarding adults at risk of harm. BMJ. 2013;346:f2716. PMID: 23674331. Exclusion Code: X 1.23674331
22 Bonomi AE, Thompson RS, Anderson M, . Ascertainment of intimate partner violence using two abuse measurement frameworks. Inj Prev. 2006 Apr;12(2):121–4. doi: 10.1136/ip.2005.009563. PMID: 16595428. Exclusion Code: X 5.16595428
23 Boyle A, Jones PB. The acceptability of routine inquiry about domestic violence towards women: A survey in three healthcare settings. Br J Gen Pract. 2006;56(525):258–61. Exclusion Code: X 6.16611513
24 Brandl B, Raymond J. Older abused and battered women: an invisible population. Wis Med J. 1996 May;95(5):298–300. PMID: 8936033. Exclusion Code: X 1.8936033
25 Brief motivational interventions to reduce excessive drinking, intimate partner violence fail to positively impact outcomes. ED Manag. 2015 Oct;27(10):117–9. Exclusion Code: X 1.26447261
26 Brierley G, Agnew-Davies R, Bailey J, . Psychological advocacy toward healing (PATH): study protocol for a randomized controlled trial. Trials. 2013;14:221. doi: 10.1186/1745-6215-14-221. PMID: 23866771. Exclusion Code: X 6.23866771
27 Brown PD, O’Leary KD. Therapeutic alliance: predicting continuance and success in group treatment for spouse abuse. J Consult Clin Psychol. 2000 Apr;68(2):340–5. PMID: 10780135. Exclusion Code: X 5.10780135
28 Brownell P, Heiser D. Psycho-educational support groups for older women victims of family mistreatment: a pilot study. J Gerontol Soc Work. 2006;46(3-4):145–60. doi: 10.1300/J083v46n03_09. PMID: 16803782. Exclusion Code: X 4.16803782
29 Brownell P, Wolden A. Elder abuse intervention strategies. J Gerontol Soc Work. 2003 2003/09/24;40(1-2):83–100. doi: 10.1300/J083v40n01_06. Exclusion Code: X 5.
30 Buckler A, Bernhard J. Screening for intimate partner violence and abuse of elderly and vulnerable adults. Am Fam Physician. 2013 Apr 15;87(8):577–8. doi: [pii]. PMID: 23668448. Exclusion Code: X 1.23668448
31 Buri HM, Daly JM, Jogerst GJ. Elder abuse telephone screen reliability and validity. J Elder Abuse Negl. 2009 Jan-Mar;21(1):58–73. doi: 10.1080/08946560802571912. PMID: 19197621. Exclusion Code: X 13.19197621
32 Buri HM, Daly JM, Jogerst GJ. Elder abuse telephone screen reliability and validity. J Elder Abuse Negl. 2009 Jan-Mar;21(1):58–73. doi: 10.1080/08946560802571912. PMID: 19197621. Exclusion Code: X 13.19197621
33 Bybee D, Sullivan CM. Predicting re-victimization of battered women 3 years after exiting a shelter program. Am J Community Psychol. 2005 Sep;36(1-2):85–96. doi: 10.1007/s10464-005-6234-5. PMID: 16134046. Exclusion Code: X 4.16134046
34 Campbell DW, Campbell J, King C, . The reliability and factor structure of the index of spouse abuse with African-American women. Violence Vict. 1994 Fall;9(3):259–74. PMID: 7647047. Exclusion Code: X 6.7647047
35 Campbell JC, Abrahams N, Martin L. Perpetration of violence against intimate partners: health care implications from global data. CMAJ. 2008 Sep 9;179(6):511–2. doi: 10.1503/cmaj.081145. PMID: 18779521. Exclusion Code: X 1.18779521
36 Campbell JC, Webster DW, Glass N. The danger assessment: validation of a lethality risk assessment instrument for intimate partner femicide. J Interpers Violence. 2009 Apr;24(4):653–74. doi: 10.1177/0886260508317180. PMID: 18667689. Exclusion Code: X 2.18667689
37 Carlson CE, Chen J, Chang M, . Reducing intimate and paying partner violence against women who exchange sex in Mongolia: results from a randomized clinical trial. J Interpers Violence. 2012 Jul;27(10):1911–31. doi: 10.1177/0886260511431439. PMID: 22366477. Exclusion Code: X 8.22366477
38 Carolyn Olson E, Rickert VI, Davidson LL. Identifying and supporting young women experiencing dating violence: what health practitioners should be doing NOW. J Pediatr Adolesc Gynecol. 2004 Apr;17(2):131–6. doi: 10.1016/j.jpag.2004.01.008. PMID: 15050990. Exclusion Code: X 1.15050990
39 Carroll AE. Finding what works to reduce violence against women. JAMA. 2015 Sep 15;314(11):1105–6. doi: 10.1001/jama.2015.11233. PMID: 26372564. Exclusion Code: X 1.26372564
40 Cesario SK, Nava A, Bianchi A, . Functioning outcomes for abused immigrant women and their children 4 months after initiating intervention. Rev Panam Salud Publica. 2014 Jan;35(1):8–14. doi: [pii]. PMID: 24626442. Exclusion Code: X 4.24626442
41 Chan E, Cavacuiti C. Gay Abuse Screening Protocol (GASP): screening for abuse in gay male relationships. J Homosex. 2008;54(4):423–38. doi: 10.1080/00918360801991455. PMID: 18826169. Exclusion Code: X 5.18826169
42 Chang JC, Dado D, Schussler S, . In person versus computer screening for intimate partner violence among pregnant patients. Patient Educ Couns. 2012 Sep;88(3):443–8. doi: 10.1016/j.pec.2012.06.021. PMID: 22770815. Exclusion Code: X 5.22770815
43 Choo EK, Ranney ML, Aggarwal N, . A systematic review of emergency department technology-based behavioral health interventions. Acad Emerg Med. 2012;19(3):318–28. Exclusion Code: X 7.22435865
44 Christian A. Home care of the battered pregnant woman: one battered woman’s pregnancy. J Obstet Gynecol Neonatal Nurs. 1995 Nov-Dec;24(9):836–42. doi: [pii]. PMID: 8583274. Exclusion Code: X 7.8583274
45 Christofides N, Jewkes R. Acceptability of universal screening for intimate partner violence in voluntary HIV testing and counseling services in South Africa and service implications. AIDS Care. 2010 Mar;22(3):279–85. doi: 10.1080/09540120903193617. PMID: 20390507. Exclusion Code: X 8.20390507
46 Clark CJ, Lewis-Dmello A, Anders D, . Trauma-sensitive yoga as an adjunct mental health treatment in group therapy for survivors of domestic violence: a feasibility study. Complement Ther Clin Pract. 2014 Aug;20(3):152–8. doi: 10.1016/j.ctcp.2014.04.003. PMID: 25129883. Exclusion Code: X 5.25129883
47 Cleary Bradley RP, Gottman JM. Reducing situational violence in low-income couples by fostering healthy relationships. J Marital Fam Ther. 2012 Jun;38: Suppl 1:187–98. doi: 10.1111/j.1752-0606.2012.00288.x. PMID: 22765333. Exclusion Code: X 8.22765333
48 Cohen LR, Field C, Campbell AN, . Intimate partner violence outcomes in women with PTSD and substance use: a secondary analysis of NIDA Clinical Trials Network “Women and Trauma” Multi-site Study. Addict Behav. 2013 Jul;38(7):2325–32. doi: 10.1016/j.addbeh.2013.03.006. PMID: 23584194. Exclusion Code: X 2.23584194
49 Cohen M. The process of validation of a three-dimensional model for the identification of abuse in older adults. Arch Gerontol Geriatr. 2013 Nov-Dec;57(3):243–9. doi: 10.1016/j.archger.2013.06.009. PMID: 23876433. Exclusion Code: X 2.23876433
50 Coker AL, Garcia LS, Williams CM, . Universal psychosocial screening and adverse pregnancy outcomes in an academic obstetric clinic. Obstet Gynecol. 2012 Jun;119(6):1180–9. doi: 10.1097/AOG.0b013e318253d76c. PMID: 22617583. Exclusion Code: X 7.22617583
51 Coker AL, Smith PH, Whitaker DJ, . Effect of an in-clinic IPV advocate intervention to increase help seeking, reduce violence, and improve well-being. Violence Against Women. 2012 Jan;18(1):118–31. doi: 10.1177/1077801212437908. PMID: 22411302. Exclusion Code: X 7.22411302
52 Coker AL. Primary prevention of intimate partner violence for women’s health: a response to Plichta. J Interpers Violence. 2004 Nov;19(11):1324–34. doi: 10.1177/0886260504269686. PMID: 15534334. Exclusion Code: X 1.15534334
53 Colarossi LG, Breitbart V, Betancourt GS. Screening for intimate partner violence in reproductive health centers: an evaluation study. Women Health. 2010 Jun;50(4):313–26. doi: 10.1080/03630242.2010.498751. PMID: 20711946. Exclusion Code: X 6.20711946
54 Colvin JD, Bettenhausen JL, Anderson-Carpenter KD, . Multiple behavior change intervention to improve detection of unmet social needs and resulting resource referrals. Acad Pediatr. 2016 Mar;16(2):168–74. doi: 10.1016/j.acap.2015.06.001. PMID: 26183003. Exclusion Code: X 7.26183003
55 Connelly CD, Newton RR, Landsverk J, . Assessment of intimate partner violence among high-risk postpartum mothers: concordance of clinical measures. Women Health. 2000;31(1):21–37. doi: 10.1300/J013v31n01_02. PMID: 11005218. Exclusion Code: X 6.11005218
56 Constantino R, Crane PA, Noll BS, . Exploring the feasibility of email-mediated interaction in survivors of abuse. J Psychiatr Ment Health Nurs. 2007;14(3):291–301. Exclusion Code: X 5.17430453
57 Cooper C, Barber J, Griffin M, . Effectiveness of START psychological intervention in reducing abuse by dementia family carers: Randomized controlled trial. Int Psychogeriatr. 2016;28(6):881–7. Exclusion Code: X 2.26652193
58 Cooper C, Maxmin K, Selwood A, . The sensitivity and specificity of the Modified Conflict Tactics Scale for detecting clinically significant elder abuse. Int Psychogeriatr. 2009 Aug;21(4):774–8. doi: 10.1017/S1041610209009387. PMID: 19493378. Exclusion Code: X 2.19493378
59 Cornelius TL, Truba N, Bell KM. Using the Internet to prescreen participants for research on interpersonal violence: experimental design considerations. Violence Vict. 2011;26(3):319–28. PMID: 21846020. Exclusion Code: X 2.21846020
60 Costa D, Barros H. Instruments to Assess Intimate Partner Violence: A Scoping Review of the Literature. Violence Vict. 2016;31(4):591–621. doi: 10.1891/0886-6708.VV-D-14-00122. PMID: 27302566. Exclusion Code: X 7.27302566
61 Coulthard P, Yong Sin L, Adamson L, . Domestic violence screening and intervention programmes for adults with dental or facial injury. In Cochrane Database of Systematic Reviews Exclusion Code: X 7.
62 Covington DL, Dalton VK, Diehl SJ, . Improving detection of violence among pregnant adolescents. J Adolesc Health. 1997 Jul;21(1):18–24. doi: [pii]. PMID: 9215506. Exclusion Code: X 6.9215506
63 Covington DL, Diehl SJ, Wright BD, . Assessing for violence during pregnancy using a systematic approach. Matern Child Health J. 1997 Jun;1(2):129–33. PMID: 10728235. Exclusion Code: X 6.10728235
64 Crespo M, Arinero M. Assessment of the efficacy of a psychological treatment for women victims of violence by their intimate male partner. Span J Psychol. 2010 Nov;13(2):849–63. PMID: 20977033. Exclusion Code: X 5.20977033
65 Culver Wygant CR, Bruera E, Hui D. Intimate partner violence in an outpatient palliative care setting. J Pain Symptom Manage. 2014 Apr;47(4):806–13. doi: 10.1016/j.jpainsymman.2013.05.018. PMID: 23948161. Exclusion Code: X 7.23948161
66 Cunningham RM, Whiteside LK, Chermack ST, . Dating violence: outcomes following a brief motivational interviewing intervention among at-risk adolescents in an urban emergency department. Acad Emerg Med. 2013 Jun;20(6):562–9. doi: 10.1111/acem.12151. PMID: 23758302. Exclusion Code: X 2.23758302
67 Curry MA, Durham L, Bullock L, . Nurse case management for pregnant women experiencing or at risk for abuse. J Obstet Gynecol Neonatal Nurs. 2006 Mar-Apr;35(2):181–92. doi: 10.1111/j.1552-6909.2006.00027.x. PMID: 16620243. Exclusion Code: X 13.16620243
68 Curry MA, Durham L, Bullock L, . Nurse case management for pregnant women experiencing or at risk for abuse. J Obstet Gynecol Neonatal Nurs. 2006 Mar-Apr;35(2):181–92. doi: 10.1111/j.1552-6909.2006.00027.x. PMID: 16620243. Exclusion Code: X 13.16620243
69 Dantas RB, Oliveira GL, Silveira AM. Psychometric properties of the Vulnerability to Abuse Screening Scale for screening abuse of older adults. Rev Saude Publica. 2017 Apr 10;51:31. doi: 10.1590/S1518-8787.2017051006839. PMID: 28423137. Exclusion Code: X 9.28423137
70 Dao J. Preventing domestic violence in families of veterans. J Clin Psychiatry. 2013 Oct;74(10):974–80. doi: 10.4088/JCP.12124co1c. PMID: 24229747. Exclusion Code: X 1.24229747
71 Datner EM, O’Malley M, Schears RM, . Universal screening for interpersonal violence: inability to prove universal screening improves provision of services. Eur J Emerg Med. 2004 Feb;11(1):35–8. doi: [pii]. PMID: 15167191. Exclusion Code: X 5.15167191
72 Davis RC. Results from an elder abuse prevention experiment in New York City [electronic resource]. 2001. Exclusion Code: X 2.
73 De Donder L, Lang G, Penhale B, . Item non-response when measuring elder abuse: influence of methodological choices. Eur J Public Health. 2013 Dec;23(6):1021–6. doi: 10.1093/eurpub/cks172. PMID: 23220629. Exclusion Code: X 6.23220629
74 Dennis ML, Chan YF, Funk RR. Development and validation of the GAIN Short Screener (GSS) for internalizing, externalizing and substance use disorders and crime/violence problems among adolescents and adults. Am J Addict. 2006;15(SUPPL. 1):80–91. Exclusion Code: X 3.17182423
75 Deprince AP, Labus J, Belknap J, . The impact of community-based outreach on psychological distress and victim safety in women exposed to intimate partner abuse. J Consult Clin Psychol. 2012;80(2):211–21. Exclusion Code: X 5.22329822
76 Dichter ME, Rhodes KV. Reports of police calls for service as a risk indicator for intimate partner violence. Acad Emerg Med. 2009 Jan;16(1):83–6. doi: 10.1111/j.1553-2712.2008.00294.x. PMID: 19007347. Exclusion Code: X 5.19007347
77 Domestic violence. Int J Gynaecol Obstet. 2000 Oct;71(1):79–87. PMID: 11185444. Exclusion Code: X 1.11185444
78 Dong X. Screening for elder abuse in healthcare settings: why should we care, and is it a missed quality indicator? J Am Geriatr Soc. 2015 Aug;63(8):1686–8. doi: 10.1111/jgs.13538. PMID: 26277299. Exclusion Code: X 1.26277299
79 Dong XQ. Elder abuse: systematic review and implications for practice. J Am Geriatr Soc. 2015 Jun;63(6):1214–38. doi: 10.1111/jgs.13454. PMID: 26096395. Exclusion Code: X 7.26096395
80 Echeburua E, Fernandez-Montalvo J, de Corral P, . Assessing risk markers in intimate partner femicide and severe violence: a new assessment instrument. J Interpers Violence. 2009 Jun;24(6):925–39. doi: 10.1177/0886260508319370. PMID: 18544750. Exclusion Code: X 2.18544750
81 Eckhardt CI, Murphy CM, Whitaker DJ, . The effectiveness of intervention programs for perpetrators and victims of intimate partner violence (Provisional abstract). Partner Abuse. 2013;2:196–231. PMID: DARE-12013063578. Exclusion Code: X 7.
82 Eden KB, Perrin NA, Hanson GC, . Use of online safety decision aid by abused women: Effect on decisional conflict in a randomized controlled trial. Am J Prev Med. 2015;48(4):372–83. Exclusion Code: X 6.25547929
83 Elder justice: Preventing and intervening in elder mistreatment. Nurs Outlook. 2015 Sep-Oct;63(5):610–3. Exclusion Code: X 1.26598770
84 El-Khorazaty MN, Johnson AA, Kiely M, . Recruitment and retention of low-income minority women in a behavioral intervention to reduce smoking, depression, and intimate partner violence during pregnancy. BMC Public Health. 2007;7:233. doi: 10.1186/1471-2458-7-233. PMID: 17822526. Exclusion Code: X 6.17822526
85 Emerson CR, Sacks R. Assessing the sexual violence services currently provided in genitourinary medicine clinics. Sex Transm Infect. 2013 Aug;89(5):371. doi: 10.1136/sextrans-2013-051127. PMID: 23858497. Exclusion Code: X 1.23858497
86 Espino SR, Fletcher J, Gonzalez M, . Violence screening and viral load suppression among HIV-positive women of color. AIDS Patient Care STDS. 2015 Jan;29: Suppl 1:S36–41. doi: 10.1089/apc.2014.0275. PMID: 25561308. Exclusion Code: X 5.25561308
87 Eulitt PJ, Tomberg RJ, Cunningham TD, . Screening elders in the emergency department at risk for mistreatment: a pilot study. J Elder Abuse Negl. 2014;26(4):424–35. doi: 10.1080/08946566.2014.903549. PMID: 24635639. Exclusion Code: X 3.24635639
88 Falb KL, Diaz-Olavarrieta C, Campos PA, . Evaluating a health care provider delivered intervention to reduce intimate partner violence and mitigate associated health risks: study protocol for a randomized controlled trial in Mexico City. BMC Public Health. 2014;14:772. doi: 10.1186/1471-2458-14-772. PMID: 25079882. Exclusion Code: X 9.25079882
89 Fanslow J. Partner violence screening and women’s quality of life. JAMA. 2012 Dec 12;308(22):2334; author reply 5-6. doi: 10.1001/jama.2012.14870. PMID: 23232885. Exclusion Code: X 1.23232885
90 Fanslow JL, Norton RN, Robinson EM, . Outcome evaluation of an emergency department protocol of care on partner abuse. Aust N Z J Public Health. 1998 Aug;22(5):598–603. PMID: 9744216. Exclusion Code: X 6.9744216
91 Fanslow JL, Norton RN, Robinson EM. One year follow-up of an emergency department protocol for abused women. Aust N Z J Public Health. 1999 Aug;23(4):418–20. PMID: 10462868. Exclusion Code: X 7.10462868
92 Feder G, Ramsay J, Dunne D, . How far does screening women for domestic (partner) violence in different health-care settings meet criteria for a screening programme? Systematic reviews of nine UK National Screening Committee criteria. Health Technol Assess. 2009 Mar;13(16):iii–iv, xi–xiii, 1–113, 37–347. doi: 10.3310/hta13160. PMID: 19272272. Exclusion Code: X 7.19272272
93 Feldman MD. Screening for intimate partner violence: the time is now. J Gen Intern Med. 2013 Oct;28(10):1251–2. doi: 10.1007/s11606-013-2576-0. PMID: 24002620. Exclusion Code: X 1.24002620
94 Fellmeth GL, Heffernan C, Nurse J, . Educational and skills-based interventions for preventing relationship and dating violence in adolescents and young adults. Cochrane Database Syst Rev. 2013(6):CD004534. doi: 10.1002/14651858.CD004534.pub3. PMID: 23780745. Exclusion Code: X 2.23780745
95 Filinson R. An evaluation of a program of volunteer advocates for elder abuse victims. J Elder Abuse Negl. 1993;5(1):77–93. Exclusion Code: X 7.
96 Ford-Gilboe M, Varcoe C, Scott-Storey K, . A tailored online safety and health intervention for women experiencing intimate partner violence: the iCAN Plan 4 Safety randomized controlled trial protocol. BMC Public Health. 2017 Mar 21;17(1):273. doi: 10.1186/s12889-017-4143-9. PMID: 28327116. Exclusion Code: X 1.28327116
97 Frazier T, Yount KM. Intimate partner violence screening and the comparative effects of screening mode on disclosure of sensitive health behaviours and exposures in clinical settings. Public Health. 2017 Feb;143:52–9. doi: 10.1016/j.puhe.2016.10.021. PMID: 28159027. Exclusion Code: X 5.28159027
98 Fulmer T, Paveza G, Vandeweerd C, . Neglect assessment in urban emergency departments and confirmation by an expert clinical team. J Gerontol A Biol Sci Med Sci. 2005 Aug;60(8):1002–6. doi: [pii]. PMID: 16127103. Exclusion Code: X 3.16127103
99 Gerard M. Domestic violence. How to screen and intervene. RN. 2000 Dec;63(12):52–6; quiz 8. PMID: 11151827. Exclusion Code: X 1.11151827
100 Gerber MR, Ganz ML, Lichter E, . Adverse health behaviors and the detection of partner violence by clinicians. Arch Intern Med. 2005 May 9;165(9):1016–21. doi: 10.1001/archinte.165.9.1016. PMID: 15883240. Exclusion Code: X 3.15883240
101 Gerbert B, Caspers N, Bronstone A, . A qualitative analysis of how physicians with expertise in domestic violence approach the identification of victims. Ann Intern Med. 1999;131(8):578–84. Exclusion Code: X 7.10523218
102 Gerlach LB, Datner EM, Hollander JE, . Does sex matter? Effect of screener sex in intimate partner violence screening. Am J Emerg Med. 2007 Nov;25(9):1047–50. doi: 10.1016/j.ajem.2007.06.010. PMID: 18022500. Exclusion Code: X 7.18022500
103 Gibbs A, Washington L, Willan S, . The Stepping Stones and Creating Futures intervention to prevent intimate partner violence and HIV-risk behaviours in Durban, South Africa: study protocol for a cluster randomized control trial, and baseline characteristics. BMC Public Health. 2017 Apr 20;17(1):336. doi: 10.1186/s12889-017-4223-x. Exclusion Code: X 1.28427380
104 Gilbert L, Goddard-Eckrich D, Hunt T, . Efficacy of a Computerized Intervention on HIV and Intimate Partner Violence Among Substance-Using Women in Community Corrections: A Randomized Controlled Trial. Am J Public Health. 2016 Jul;106(7):1278–86. doi: 10.2105/AJPH.2016.303119. PMID: 27077342. Exclusion Code: X 8.27077342
105 Gilbert L, Shaw SA, Goddard-Eckrich D, . Project WINGS (Women Initiating New Goals of Safety): A randomised controlled trial of a screening, brief intervention and referral to treatment (SBIRT) service to identify and address intimate partner violence victimisation among substance-using women receiving community supervision. Crim Behav Ment Health. 2015 Dec 10;25(4):314–29. doi: 10.1002/cbm.1979. PMID: 26482019. Exclusion Code: X 8.26482019
106 Glass N, Clough A, Case J, . A safety app to respond to dating violence for college women and their friends: the MyPlan study randomized controlled trial protocol. BMC Public Health. 2015;15:871. doi: 10.1186/s12889-015-2191-6. PMID: 26350482. Exclusion Code: X 6.26350482
107 Glass NE, Perrin NA, Hanson GC, . The Longitudinal Impact of an Internet Safety Decision Aid for Abused Women. Am J Prev Med. 2017;52(5):606–15. doi: 10.1016/j.amepre.2016.12.014. Exclusion Code: X 8.28108189
108 Goldy D, Goldy R, Jr. Behind closed doors. Detecting and responding to marital rape. Adv Nurse Pract. 1999 Nov;7(11):75–7. PMID: 10887790. Exclusion Code: X 1.10887790
109 Goodyear-Smith F, Arroll B, Coupe N. Asking for help is helpful: validation of a brief lifestyle and mood assessment tool in primary health care. Ann Fam Med. 2009;7(3):239–44. Exclusion Code: X 3.19433841
110 Goodyear-Smith F. National screening policies in general practice: a case study of routine screening for partner abuse. Appl Health Econ Health Policy. 2002;1(4):197–209. PMID: 14619249. Exclusion Code: X 1.14619249
111 Gottlieb AS. Intimate partner violence: a clinical review of screening and intervention. Womens Health (Lond Engl). 2008 Sep;4(5):529–39. doi: 10.2217/17455057.4.5.529. PMID: 19072491. Exclusion Code: X 1.19072491
112 Graham-Bermann SA, Miller LE. Intervention to reduce traumatic stress following intimate partner violence: an efficacy trial of the Moms’ Empowerment Program (MEP). Psychodyn Psychiatry. 2013 Summer;41(2):329–49. doi: 10.1521/pdps.2013.41.2.329. PMID: 23713623. Exclusion Code: X 7.23713623
113 Graham-Bermann SA, Miller-Graff L. Community-based intervention for women exposed to intimate partner violence: A randomized control trial. J Fam Psychol. 2015 Aug;29(4):537–47. doi: 10.1037/fam0000091. PMID: 26030027. Exclusion Code: X 7.26030027
114 Greenberg EM, McFarlane J, Watson MG. Vaginal bleeding and abuse: assessing pregnant women in the emergency department. MCN Am J Matern Child Nurs. 1997 Jul-Aug;22(4):182–6. PMID: 9234605. Exclusion Code: X 8.9234605
115 Gupta J, Falb KL, Lehmann H, . Gender norms and economic empowerment intervention to reduce intimate partner violence against women in rural Cote d’Ivoire: a randomized controlled pilot study. BMC Int Health Hum Rights. 2013;13:46. doi: 10.1186/1472-698X-13-46. PMID: 24176132. Exclusion Code: X 5.24176132
116 Gupta J, Falb KL, Ponta O, . A nurse-delivered, clinic-based intervention to address intimate partner violence among low-income women in Mexico City: Findings from a cluster randomized controlled trial. BMC Med. 2017;15(1). doi: 10.1186/s12916-017-0880-y. Exclusion Code: X 9.
117 Hackett S, McWhirter PT, Lesher S. The Therapeutic Efficacy of Domestic Violence Victim Interventions. Trauma Violence Abuse. 2016 Apr;17(2):123–32. doi: 10.1177/1524838014566720. PMID: 25612799. Exclusion Code: X 7.25612799
118 Haggerty LA, Hawkins JW, Fontenot H, . Tools for screening for interpersonal violence: state of the science. Violence Vict. 2011;26(6):725–37. PMID: 22288092. Exclusion Code: X 1.22288092
119 Haile-Mariam T. Family/domestic violence: How to intervene? How to prevent? Ethn Dis. 2003 Summer;13(3 Suppl 3):S3-104–5. PMID: 14552466. Exclusion Code: X 1.14552466
120 Halpern LR, Perciaccante VJ, Hayes C, . A protocol to diagnose intimate partner violence in the emergency department. J Trauma. 2006 May;60(5):1101–5. doi: 10.1097/01.ta.0000218247.58465.db. PMID: 16688077. Exclusion Code: X 3.16688077
121 Hamberger LK, Rhodes K, Brown J. Screening and intervention for intimate partner violence in healthcare settings: creating sustainable system-level programs. J Womens Health (Larchmt). 2015 Jan;24(1):86–91. doi: 10.1089/jwh.2014.4861. PMID: 25412012. Exclusion Code: X 1.25412012
122 Hammock A, Palermo T, Keogler R, . Evaluation of a short intervention on screening for intimate partner violence in an ED. Am J Emerg Med. 2017 Jan;35(1):171–3. doi: 10.1016/j.ajem.2016.09.055. PMID: 27789103. Exclusion Code: X 2.27789103
123 He S, Tsang S, Li C. A revision of the sexual coercion in intimate relationships scale for young adults in China. Violence Vict. 2013;28(3):483–95. PMID: 23862311. Exclusion Code: X 8.23862311
124 Hegarty K, Tarzia L, Murray E, . Protocol for a randomised controlled trial of a web-based healthy relationship tool and safety decision aid for women experiencing domestic violence (I-DECIDE). BMC Public Health. 2015;15:736. doi: 10.1186/s12889-015-2072-z. PMID: 26231225. Exclusion Code: X 6.26231225
125 Hegarty KL, Gunn JM, O’Doherty LJ, . Women’s evaluation of abuse and violence care in general practice: a cluster randomised controlled trial (weave). BMC Public Health. 2010;10:2. doi: 10.1186/1471-2458-10-2. PMID: 20044929. Exclusion Code: X 6.20044929
126 Hegarty KL, O’Doherty LO, Astbury J, . Identifying intimate partner violence when screening for health and lifestyle issues among women attending general practice. Aust J Prim Health. 2012;18(4):327–31. doi: 10.1071/PY11101. PMID: 22950858. Exclusion Code: X 7.22950858
127 Heinzer MM, Krimm JR. Barriers to screening for domestic violence in an emergency department. Holist Nurs Pract. 2002 Apr;16(3):24–33. PMID: 11913225. Exclusion Code: X 8.11913225
128 Heron SL, Thompson MP, Jackson E, . Do responses to an intimate partner violence screen predict scores on a comprehensive measure of intimate partner violence in low-income black women? Ann Emerg Med. 2003 Oct;42(4):483–91. doi: 10.1067/S0196064403007182. PMID: 14520319. Exclusion Code: X 8.14520319
129 Hirsch CH, Stratton S, Loewy R. The primary care of elder mistreatment. West J Med. 1999 Jun;170(6):353–8. PMID: 10443164. Exclusion Code: X 1.10443164
130 Hoff LA, Rosenbaum L. A victimization assessment tool: instrument development and clinical implications. J Adv Nurs. 1994 Oct;20(4):627–34. PMID: 7822596. Exclusion Code: X 7.7822596
131 Hollander JE, Schears RM, Shofer FS, . The effect of written informed consent on detection of violence in the home. Acad Emerg Med. 2001 Oct;8(10):974–9. PMID: 11581084. Exclusion Code: X 4.11581084
132 Hooker L, Taft A. Screening for intimate partner violence in health care settings is a contested arena. Aust Nurs Midwifery J. 2013 Nov;21(5):22. PMID: 24672965. Exclusion Code: X 1.24672965
133 Hoover RM, Polson M. Detecting elder abuse and neglect: assessment and intervention. Am Fam Physician. 2014 Mar 15;89(6):453–60. doi: [pii]. PMID: 24695564. Exclusion Code: X 1.24695564
134 Houry D, Feldhaus K, Peery B, . A positive domestic violence screen predicts future domestic violence. J Interpers Violence. 2004 Sep;19(9):955–66. doi: 10.1177/0886260504267999. PMID: 15296611. Exclusion Code: X 13.15296611
135 Houry D, Feldhaus K, Peery B, . A positive domestic violence screen predicts future domestic violence. J Interpers Violence. 2004 Sep;19(9):955–66. doi: 10.1177/0886260504267999. PMID: 15296611. Exclusion Code: X 13.15296611
136 Howard A, Riger S, Campbell R, . Counseling services for battered women: a comparison of outcomes for physical and sexual assault survivors. J Interpers Violence. 2003 Jul;18(7):717–34. doi: 10.1177/0886260503253230. PMID: 14675505. Exclusion Code: X 5.14675505
137 Howard LM, Trevillion K, Khalifeh H, . Domestic violence and severe psychiatric disorders: prevalence and interventions. Psychol Med. 2010 Jun;40(6):881–93. doi: 10.1017/S0033291709991589. PMID: 19891808. Exclusion Code: X 6.19891808
138 Howell KH, Miller LE, Lilly MM, . Strengthening positive parenting through intervention: evaluating the Moms’ Empowerment Program for women experiencing intimate partner violence. In Journal of interpersonal violence Exclusion Code: X 8.
139 Howell KH, Miller-Graff LE, Hasselle AJ, . The unique needs of pregnant, violence-exposed women: A systematic review of current interventions and directions for translational research. Aggression and Violent Behavior. 2017;34((Howell K.H., k.howell@memphis.edu) Department of Psychology, University of Memphis, Memphis, United States):128–38. doi: 10.1016/j.avb.2017.01.021. Exclusion Code: X 7.
140 Hughes K, Bellis MA, Hardcastle KA, . Global development and diffusion of outcome evaluation research for interpersonal and self-directed violence prevention from 2007 to 2013: A systematic review. Aggression and Violent Behavior. 2014;19(6):655–62. Exclusion Code: X 6.29725241
141 Humphreys J, Tsoh JY, Kohn MA, . Increasing discussions of intimate partner violence in prenatal care using Video Doctor plus Provider Cueing: a randomized, controlled trial. Womens Health Issues. 2011 Mar-Apr;21(2):136–44. doi: 10.1016/j.whi.2010.09.006. PMID: 21185737. Exclusion Code: X 6.21185737
142 Hussain N, Sprague S, Madden K, . A comparison of the types of screening tool administration methods used for the detection of intimate partner violence: a systematic review and meta-analysis. Trauma Violence Abuse. 2015 Jan;16(1):60–9. doi: 10.1177/1524838013515759. PMID: 24343478. Exclusion Code: X 5.24343478
143 Intimate partner violence. HRSA Careaction. 2009 Sep:1–12. PMID: 20050220. Exclusion Code: X 1.20050220
144 Iverson KM, Huang K, Wells SY, . Women veterans’ preferences for intimate partner violence screening and response procedures within the Veterans Health Administration. Res Nurs Health. 2014 Aug;37(4):302–11. doi: 10.1002/nur.21602. PMID: 24990824. Exclusion Code: X 7.24990824
145 Iverson KM. Routine screening for intimate partner violence in VHA: a timely opportunity. J Gen Intern Med. 2014 Feb;29(2):280. doi: 10.1007/s11606-013-2716-6. PMID: 24263799. Exclusion Code: X 1.24263799
146 Iyer SV, Dutton CR. Screening for intimate partner violence in an outpatient gynecology clinic setting. In Obstetrics and Gynecology. Conference: 63rd Annual Clinical and Scientific Meeting of the American College of Obstetricians and Gynecologists San Francisco, CA United States. Conference Start: 20150502 Conference End: 20150506. Conference Publication: (var.pagings) Exclusion Code: X 6.
147 Izmirli GO, Sonmez Y, Sezik M. Prediction of domestic violence against married women in southwestern Turkey. Int J Gynaecol Obstet. 2014 Dec;127(3):288–92. doi: 10.1016/j.ijgo.2014.06.011. PMID: 25113652. Exclusion Code: X 7.25113652
148 Jahanfar S, Howard LM, Medley N. Interventions for preventing or reducing domestic violence against pregnant women. Cochrane Database Syst Rev. 2014;11:CD009414. doi: 10.1002/14651858.CD009414.pub3. PMID: 25390767. Exclusion Code: X 7.25390767
149 Jahanfar S, Janssen PA, Howard LM, . Interventions for preventing or reducing domestic violence against pregnant women. Cochrane Database Syst Rev. 2013;2:CD009414. doi: 10.1002/14651858.CD009414.pub2. PMID: 23450603. Exclusion Code: X 7.23450603
150 Jervis LL, Fickenscher A, Beals J. Assessment of elder mistreatment in two American Indian samples: psychometric characteristics of the HS-EAST and the Native Elder Life-Financial Exploitation and -Neglect measures. J Appl Gerontol. 2014 Apr;33(3):336–56. doi: 10.1177/0733464812470748. PMID: 24652864. Exclusion Code: X 5.24652864
151 Jezierski MB, Eickholt T, McGee J. Disadvantages to mandatory reporting of domestic violence. J Emerg Nurs. 1999 Apr;25(2):79–80. doi: [pii]. PMID: 10097260. Exclusion Code: X 1.10097260
152 Johnson RM. Emergency department screening for domestic violence. Am J Public Health. 2001 Apr;91(4):651–2. PMID: 11291386. Exclusion Code: X 1.11291386
153 Johnson SM, Murphy MJ, Gidycz CA. Reliability and Validity of the Sexual Experiences Survey-Short Forms Victimization and Perpetration. Violence Vict. 2017;32(1):78–92. doi: 10.1891/0886-6708.vv-d-15-00110. Exclusion Code: X 2.28234199
154 Jones C, Bonner M. Screening for domestic violence in an antenatal clinic. Aust J Midwifery. 2002;15(1):14–20. PMID: 12017039. Exclusion Code: X 6.12017039
155 Jonker IE, Sijbrandij M, van Luijtelaar MJ, . The effectiveness of interventions during and after residence in women’s shelters: a meta-analysis. Eur J Public Health. 2015;25(1):15–9. Exclusion Code: X 8.
156 Karakurt G, Whiting K, van Esch C, . Couples Therapy for Intimate Partner Violence: A Systematic Review and Meta-Analysis. J Marital Fam Ther. 2016 Oct;42(4):567–83. doi: 10.1111/jmft.12178. PMID: 27377617. Exclusion Code: X 7.27377617
157 Karatzias T, Ferguson S, Gullone A, . Group psychotherapy for female adult survivors of interpersonal psychological trauma: a preliminary study in Scotland. J Ment Health. 2016 Dec;25(6):512–9. doi: 10.3109/09638237.2016.1139062. PMID: 26850453. Exclusion Code: X 2.26850453
158 Kearney JA, Cushing E. A multi-modal pilot intervention with violence-exposed mothers in a child psychiatric trauma-focused treatment program. Issues Ment Health Nurs. 2012 Aug;33(8):544–52. doi: 10.3109/01612840.2012.688254. PMID: 22849782. Exclusion Code: X 5.22849782
159 Kelly A, Garland EL. Trauma-Informed Mindfulness-Based Stress Reduction for Female Survivors of Interpersonal Violence: Results From a Stage I RCT. J Clin Psychol. 2016;72(4):311–28. doi: 10.1002/jclp.22273. Exclusion Code: X 8.27002222
160 Kerker BD, Horwitz SM, Leventhal JM, . Identification of violence in the home: pediatric and parental reports. Arch Pediatr Adolesc Med. 2000 May;154(5):457–62. PMID: 10807295. Exclusion Code: X 2.10807295
161 Kershner M, Anderson JE. Barriers to disclosure of abuse among rural women. Minn Med. 2002 Mar;85(3):32–7. PMID: 11915526. Exclusion Code: X 6.11915526
162 Kheder S, VandenBosch T. Intimate partner violence: a health system’s response. Continuum Soc Soc Work Leadersh Health Care. 2001 Jan-Feb;21(1):15–22. PMID: 11255844. Exclusion Code: X 7.11255844
163 Kiely M, Gantz MG, El-Khorazaty MN, . Sequential screening for psychosocial and behavioural risk during pregnancy in a population of urban African Americans. BJOG. 2013 Oct;120(11):1395–402. doi: 10.1111/1471-0528.12202. PMID: 23906260. Exclusion Code: X 6.23906260
164 Kim H, Cain R, Viner-Brown S. Intimate partner violence before or during pregnancy in Rhode Island. Med Health R I. 2010 Jan;93(1):29–31. PMID: 20481205. Exclusion Code: X 6.20481205
165 Kirst M, Zhang YJ, Young A, . Referral to health and social services for intimate partner violence in health care settings: a realist scoping review. Trauma Violence Abuse. 2012 Oct;13(4):198–208. doi: 10.1177/1524838012454942. PMID: 22899703. Exclusion Code: X 1.22899703
166 Kita S, Haruna M, Hikita N, . Development of the Japanese version of the Woman Abuse Screening Tool-Short. Nurs Health Sci. 2017 Mar;19(1):35–43. doi: 10.1111/nhs.12298. PMID: 27426035. Exclusion Code: X 13.27426035
167 Kita S, Haruna M, Hikita N, . Development of the Japanese version of the Woman Abuse Screening Tool-Short. Nurs Health Sci. 2017 Mar;19(1):35–43. doi: 10.1111/nhs.12298. PMID: 27426035. Exclusion Code: X 13.27426035
168 Klein SJ, Birkhead GS, Wright G. Domestic violence and HIV/AIDS. Am J Public Health. 2000 Oct;90(10):1648. PMID: 11030008. Exclusion Code: X 1.11030008
169 Klein SJ, Tesoriero JM, Leung SY, . Screening persons newly diagnosed with HIV/AIDS for risk of intimate partner violence: early progress in changing practice. J Public Health Manag Pract. 2008 Sep-Oct;14(5):420–8. doi: 10.1097/01.PHH.0000333875.32701.ca. PMID: 18708884. Exclusion Code: X 7.18708884
170 Kleinschmidt KC. Elder abuse: a review. Ann Emerg Med. 1997 Oct;30(4):463–72. doi: [pii]. PMID: 9326861. Exclusion Code: X 1.9326861
171 Klevens J, Sadowski L, Kee R, . Comparison of screening and referral strategies for exposure to partner violence. Womens Health Issues. 2012 Jan-Feb;22(1):e45–52. doi: 10.1016/j.whi.2011.06.008. PMID: 21798763. Exclusion Code: X 5.21798763
172 Koziol-Mclain J, Campbell JC. Universal screening and mandatory reporting: an update on two important issues for victims/survivors of intimate partner violence. J Emerg Nurs. 2001 Dec;27(6):602–6. doi: 10.1067/men.2001.117053. PMID: 11712019. Exclusion Code: X 1.11712019
173 Koziol-McLain J, Vandal AC, Nada-Raja S, . A web-based intervention for abused women: the New Zealand isafe randomised controlled trial protocol. BMC Public Health. 2015;15:56. Exclusion Code: X 6.25637195
174 Kramer A, Nosbusch JM, Rice J. Safe mom, safe baby: a collaborative model of care for pregnant women experiencing intimate partner violence. J Perinat Neonatal Nurs. 2012 Oct-Dec;26(4):307–16; quiz p 17-8. doi: 10.1097/JPN.0b013e31824356dd. PMID: 23111718. Exclusion Code: X 7.23111718
175 Krasnoff M, Moscati R. Domestic violence screening and referral can be effective. Ann Emerg Med. 2002 Nov;40(5):485–92. doi: [pii]. PMID: 12399791. Exclusion Code: X 5.12399791
176 Krimm J, Heinzer MM. Domestic violence screening in the emergency department of an urban hospital. J Natl Med Assoc. 2002;94(6):484–91. Exclusion Code: X 5.12078930
177 Kropp PR. Intimate partner violence risk assessment and management. Violence Vict. 2008;23(2):202–20. PMID: 18624090. Exclusion Code: X 1.18624090
178 Kureshi S, Bullock K. Qualitative benefits of screening for intimate partner violence. Am Fam Physician. 2012 May 15;85(10):2; author reply -3. PMID: 22774269. Exclusion Code: X 1.22774269
179 Lachs MS, Pillemer KA. Elder abuse. N Engl J Med. 2015 Nov 12;373(20):1947–56. doi: 10.1056/NEJMra1404688. PMID: 26559573. Exclusion Code: X 1.26559573
180 Laisser RM, Nystrom L, Lindmark G, . Screening of women for intimate partner violence: a pilot intervention at an outpatient department in Tanzania. Glob Health Action. 2011;4:7288. doi: 10.3402/gha.v4i0.7288. PMID: 22028679. Exclusion Code: X 5.22028679
181 Larkin GL, Hyman KB, Mathias SR, . Universal screening for intimate partner violence in the emergency department: importance of patient and provider factors. Ann Emerg Med. 1999 Jun;33(6):669–75. doi: [pii]. PMID: 10339682. Exclusion Code: X 7.10339682
182 Leung WC, Wong YY, Leung TW, . Pregnancy outcome following domestic violence in a Chinese community. Int J Gynaecol Obstet. 2001 Jan;72(1):79–80. doi: [pii]. PMID: 11146083. Exclusion Code: X 7.11146083
183 Lewin L, Graham G. Interpersonal violence: secondary analysis of the keep your children/yourself safe and secure (KySS) data. J Pediatr Health Care. 2012 Mar;26(2):102–8. doi: 10.1016/j.pedhc.2010.07.001. PMID: 22360929. Exclusion Code: X 3.22360929
184 Lincoln AK, Liebschutz JM, Chernoff M, . Brief screening for co-occurring disorders among women entering substance abuse treatment. Subst Abuse Treat Prev Policy. 2006;1:26. doi: 10.1186/1747-597X-1-26. PMID: 16959041. Exclusion Code: X 6.16959041
185 Lindenbach JM, Larocque S, Lavoie AM, . Older adult mistreatment risk screening: contribution to the validation of a screening tool in a domestic setting. Can J Aging. 2012 Jun;31(2):235–52. doi: 10.1017/S0714980812000153. PMID: 22647665. Exclusion Code: X 5.22647665
186 Lion JR. Pitfalls in the assessment and measurement of violence: a clinical view. J Neuropsychiatry Clin Neurosci. 1991 Spring;3(2):S40–3. PMID: 1821221. Exclusion Code: X 1.1821221
187 Liu W, Binbin Y, Ma Y. Educational and skills-based interventions for preventing relationship and dating violence in adolescents and young adults. Public Health Nurs. 2014 Sep-Oct;31(5):441–3. doi: 10.1111/phn.12115. PMID: 24628504. Exclusion Code: X 1.24628504
188 Livingston G, Barber J, Rapaport P, . A randomized controlled trial of the effect of the start (strategies for relatives) intervention: The effect on family caregiver’s potentially harmful behavior to people with dementia. Alzheimer’s and Dementia. 2015;11(7):P222. Exclusion Code: X 3.
189 Lo Vecchio F, Bhatia A, Sciallo D. Screening for domestic violence in the emergency department. Eur J Emerg Med. 1998 Dec;5(4):441–4. PMID: 9919449. Exclusion Code: X 5.9919449
190 Lutgendorf MA, Thagard A, Rockswold PD, . Domestic violence screening of obstetric triage patients in a military population. J Perinatol. 2012 Oct;32(10):763–9. doi: 10.1038/jp.2011.188. PMID: 22301524. Exclusion Code: X 5.22301524
191 Lutwak N. Screening for intimate partner violence at VA EDs: the time is now. J Gen Intern Med. 2014 Feb;29(2):279. doi: 10.1007/s11606-013-2717-5. PMID: 24254892. Exclusion Code: X 1.24254892
192 Mackay K. To screen or not to screen: identification of domestic violence in Canadian emergency departments. CJEM. 2008 Jul;10(4):329–32. doi: [pii]. PMID: 18652723. Exclusion Code: X 1.18652723
193 Macmillan HL, Feder G. Screening women for intimate partner violence. Ann Intern Med. 2012 Nov 6;157(9):676; author reply -7. doi: 10.7326/0003-4819-157-9-201211060-00019. PMID: 23128869. Exclusion Code: X 1.23128869
194 Madden K, Bhandari M. Cochrane in CORR ((R)): Screening Women for Intimate Partner Violence in Healthcare Settings (Review). Clin Orthop Relat Res. 2016 Sep;474(9):1897–903. doi: 10.1007/s11999-016-4957-2. PMID: 27385221. Exclusion Code: X 7.27385221
195 Malpass A, Sales K, Johnson M, . Women’s experiences of referral to a domestic violence advocate in UK primary care settings: a service-user collaborative study. Br J Gen Pract. 2014 Mar;64(620):e151-8. doi: 10.3399/bjgp14X677527. PMID: 24567654. Exclusion Code: X 3.
196 Mayer BW. Female domestic violence victims: perspectives on emergency care. Nurs Sci Q. 2000 Oct;13(4):340–6. PMID: 11847758. Exclusion Code: X 1.11847758
197 Mayor S. Brief intervention in emergency department does not reduce partner violence in women, US study shows. BMJ (Online). 2015;351((Mayor S.) London, United Kingdom). Exclusion Code: X 1.
198 McCall-Hosenfeld JS, Chuang CH, Weisman CS. Prospective association of intimate partner violence with receipt of clinical preventive services in women of reproductive age. Womens Health Issues. 2013 Mar-Apr;23(2):e109–16. doi: 10.1016/j.whi.2012.12.006. PMID: 23481691. Exclusion Code: X 7.23481691
199 McCauley HL, Silverman JG, Jones KA, . Psychometric properties and refinement of the Reproductive Coercion Scale. Contraception. 2017;95(3):292–8. doi: 10.1016/j.contraception.2016.09.010. Exclusion Code: X 6.27639927
200 McCloskey LA, Lichter E, Ganz ML, . Intimate partner violence and patient screening across medical specialties. Acad Emerg Med. 2005 Aug;12(8):712–22. doi: 10.1197/j.aem.2005.03.529. PMID: 16079424. Exclusion Code: X 5.16079424
201 McCollum EE, Stith SM. Couples treatment for interpersonal violence: a review of outcome research literature and current clinical practices. Violence Vict. 2008;23(2):187–201. PMID: 18624089. Exclusion Code: X 1.18624089
202 McFarlane J, Greenberg L, Weltge A, . Identification of abuse in emergency departments: effectiveness of a two-question screening tool. J Emerg Nurs. 1995 Oct;21(5):391–4. PMID: 7500563. Exclusion Code: X 2.7500563
203 McFarlane J, Hughes RB, Nosek MA, . Abuse assessment screen-disability (AAS-D): measuring frequency, type, and perpetrator of abuse toward women with physical disabilities. J Womens Health Gend Based Med. 2001 Nov;10(9):861–6. doi: 10.1089/152460901753285750. PMID: 11747680. Exclusion Code: X 5.11747680
204 McFarlane J, Soeken K, Reel S, . Resource use by abused women following an intervention program: associated severity of abuse and reports of abuse ending. Public Health Nurs. 1997 Aug;14(4):244–50. PMID: 9270289. Exclusion Code: X 7.9270289
205 McFarlane J, Soeken K, Wiist W. An evaluation of interventions to decrease intimate partner violence to pregnant women. Public Health Nurs. 2000 Nov-Dec;17(6):443–51. PMID: 11115142. Exclusion Code: X 13..11115142
206 McFarlane J, Soeken K, Wiist W. An evaluation of interventions to decrease intimate partner violence to pregnant women. Public Health Nurs. 2000 Nov-Dec;17(6):443–51. PMID: 11115142. Exclusion Code: X 13..11115142
207 McFarlane J, Wiist W. Preventing abuse to pregnant women: implementation of a “mentor mother” advocacy model. J Community Health Nurs. 1997;14(4):237–49. doi: 10.1207/s15327655jchn1404_3. PMID: 9409094. Exclusion Code: X 7.9409094
208 McFarlane J. Intimate partner violence and physical health consequences: commentary on Plichta. J Interpers Violence. 2004 Nov;19(11):1335–41. doi: 10.1177/0886260504269687. PMID: 15534335. Exclusion Code: X 1.15534335
209 McFarlane JM, Groff JY, O’Brien JA, . Behaviors of children following a randomized controlled treatment program for their abused mothers. Issues Compr Pediatr Nurs. 2005 Oct-Dec;28(4):195–211. doi: 10.1080/01460860500396708. PMID: 16356894. Exclusion Code: X 6.16356894
210 McFarlane JM, Groff JY, O’Brien JA, . Secondary prevention of intimate partner violence: a randomized controlled trial. Nurs Res. 2006 Jan-Feb;55(1):52–61. PMID: 16439929. Exclusion Code: X 13.16439929
211 McFarlane JM, Groff JY, O’Brien JA, . Secondary prevention of intimate partner violence: a randomized controlled trial. Nurs Res. 2006 Jan-Feb;55(1):52–61. PMID: 16439929. Exclusion Code: X 13.16439929
212 McGarry J. Older women and domestic violence. Nurs Older People. 2008 Jul;20(6):10–1. PMID: 18655491. Exclusion Code: X 1.18655491
213 McNutt LA, Carlson BE, Gagen D, . Reproductive violence screening in primary care: perspectives and experiences of patients and battered women. J Am Med Womens Assoc. 1999 Spring;54(2):85–90. PMID: 10319597. Exclusion Code: X 7.10319597
214 McNutt LA, Carlson BE, Rose IM, . Partner violence intervention in the busy primary care environment. Am J Prev Med. 2002 Feb;22(2):84–91. doi: [pii]. PMID: 11818176. Exclusion Code: X 13.11818176
215 McNutt LA, Carlson BE, Rose IM, . Partner violence intervention in the busy primary care environment. Am J Prev Med. 2002 Feb;22(2):84–91. doi: [pii]. PMID: 11818176. Exclusion Code: X 13.11818176
216 McNutt LA, van Ryn M, Clark C, . Partner violence and medical encounters: African-American women’s perspectives. Am J Prev Med. 2000 Nov;19(4):264–9. doi: [pii]. PMID: 11064230. Exclusion Code: X 6.11064230
217 McWhirter PT. Differential therapeutic outcomes of community-based group interventions for women and children exposed to intimate partner violence. J Interpers Violence. 2011 Aug;26(12):2457–82. doi: 10.1177/0886260510383026. PMID: 20889533. Exclusion Code: X 8.20889533
218 Mechem CC, Shofer FS, Reinhard SS, . History of domestic violence among male patients presenting to an urban emergency department. Acad Emerg Med. 1999 Aug;6(8):786–91. PMID: 10463549. Exclusion Code: X 5.10463549
219 Miller E, Goldstein S, McCauley HL, . A school health center intervention for abusive adolescent relationships: A cluster RCT. Pediatrics. 2015;135(1):76–85. Exclusion Code: X 8.25535265
220 Mitrani VB, McCabe BE, Gonzalez-Guarda RM, . Participation in SEPA, a sexual and relational health intervention for Hispanic women. West J Nurs Res. 2013;35(7):849–66. Exclusion Code: X 8.23493674
221 Nager AL, Pham PK, Grajower DN, . Mental Health Screening Among Adolescents and Young Adults in the Emergency Department. Pediatr Emerg Care. 2017 Jan;33(1):5–9. doi: 10.1097/PEC.0000000000000529. PMID: 26414635. Exclusion Code: X 2.26414635
222 Nelson HD, Bougatsos C, Blazina I. Screening women for intimate partner violence: a systematic review to update the U.S. Preventive Services Task Force recommendation. Ann Intern Med. 2012 Jun 5;156(11):796–808, W-279, W-80, W-81, W-82. doi: 10.7326/0003-4819-156-11-201206050-00447. PMID: 22565034. Exclusion Code: X 7.22565034
223 Nelson HD, Bougatsos C, Blazina I. Screening Women for Intimate Partner Violence and Elderly and Vulnerable Adults for Abuse: Systematic Review to Update the 2004 U.S. Preventive Services Task Force Recommendation. Rockville MD; 2012. Exclusion Code: X 7.
224 Nelson HD, Nygren P, McInerney Y, . Screening women and elderly adults for family and intimate partner violence: a review of the evidence for the U. S. Preventive Services Task Force. Ann Intern Med. 2004 Mar 2;140(5):387–96. PMID: 14996681. Exclusion Code: X 7.14996681
225 Nosek MA, Hughes RB, Taylor HB, . Disability, psychosocial, and demographic characteristics of abused women with physical disabilities. Violence Against Women. 2006 Sep;12(9):838–50. doi: 10.1177/1077801206292671. PMID: 16905676. Exclusion Code: X 5.16905676
226 O’Doherty L, Hegarty K, Ramsay J, . Screening women for intimate partner violence in healthcare settings. Cochrane Database Syst Rev. 2015;7:CD007007. doi: 10.1002/14651858.CD007007.pub3. PMID: 26200817. Exclusion Code: X 7.26200817
227 O’Doherty LJ, Taft A, Hegarty K, . Screening women for intimate partner violence in healthcare settings: abridged Cochrane systematic review and meta-analysis. BMJ. 2014;348:g2913. PMID: 24821132. Exclusion Code: X 7.24821132
228 Oriel KA, Fleming MF. Screening men for partner violence in a primary care setting. A new strategy for detecting domestic violence. J Fam Pract. 1998 Jun;46(6):493–8. PMID: 9638114. Exclusion Code: X 2.9638114
229 Pantalone DW, Rood BA, Morris BW, . A systematic review of the frequency and correlates of partner abuse in HIV-infected women and men who partner with men. J Assoc Nurses AIDS Care. 2014 Jan-Feb;25(1 Suppl):S15–35. doi: 10.1016/j.jana.2013.04.003. PMID: 24070646. Exclusion Code: X 7.24070646
230 Parker B, Chouaf K. Intimate partner violence following pregnancy. Arch Pediatr Adolesc Med. 2002 Apr;156(4):313–4. doi: [pii]. PMID: 11929361. Exclusion Code: X 1.11929361
231 Parker B, McFarlane J, Soeken K. Abuse during pregnancy: effects on maternal complications and birth weight in adult and teenage women. Obstet Gynecol. 1994 Sep;84(3):323–8. PMID: 8058224. Exclusion Code: X 5.8058224
232 Phelan MB. Screening for intimate partner violence in medical settings. Trauma Violence Abuse. 2007 Apr;8(2):199–213. doi: 10.1177/1524838007301221. PMID: 17545574. Exclusion Code: X 1.17545574
233 Plazaola-Castano J, Ruiz-Perez I, Escriba-Aguir V, . Validation of the Spanish version of the Index of Spouse Abuse. J Womens Health (Larchmt). 2009 Apr;18(4):499–506. doi: 10.1089/jwh.2008.0944. PMID: 19361317. Exclusion Code: X 3.19361317
234 Ploeg J, Fear J, Hutchison B, . A systematic review of interventions for elder abuse. J Elder Abuse Negl. 2009 Jul-Sep;21(3):187–210. doi: 10.1080/08946560902997181. PMID: 19827325. Exclusion Code: X 7.19827325
235 Potera C. Screening teens for dating violence in EDs. Am J Nurs. 2014 Oct;114(10):14. doi: 10.1097/01.NAJ.0000454834.82114.b7. PMID: 25251112. Exclusion Code: X 1.25251112
236 Prosman GJ, Lo Fo Wong SH, Lagro-Janssen AL. Support by trained mentor mothers for abused women: a promising intervention in primary care. Fam Pract. 2014 Feb;31(1):71–80. doi: 10.1093/fampra/cmt058. PMID: 24132592. Exclusion Code: X 7.24132592
237 Prosman GJ, Lo Fo Wong SH, van der Wouden JC, . Effectiveness of home visiting in reducing partner violence for families experiencing abuse: a systematic review. Fam Pract. 2015 Jun;32(3):247–56. doi: 10.1093/fampra/cmu091. PMID: 25947931. Exclusion Code: X 7.25947931
238 Rabin RF, Jennings JM, Campbell JC, . Intimate partner violence screening tools: a systematic review. Am J Prev Med. 2009 May;36(5):439–45 e4. doi: 10.1016/j.amepre.2009.01.024. PMID: 19362697. Exclusion Code: X 7.19362697
239 Raissi SE, Krentz HB, Siemieniuk RA, . Implementing an intimate partner violence (IPV) screening protocol in HIV care. AIDS Patient Care STDS. 2015 Mar;29(3):133–41. doi: 10.1089/apc.2014.0306. PMID: 25585198. Exclusion Code: X 6.25585198
240 Ramachandran DV, Covarrubias L, Watson C, . How you screen is as important as whether you screen: a qualitative analysis of violence screening practices in reproductive health clinics. J Community Health. 2013 Oct;38(5):856–63. doi: 10.1007/s10900-013-9690-0. PMID: 23645349. Exclusion Code: X 3.23645349
241 Ramsden C, Bonner M. A realistic view of domestic violence screening in an emergency department. Accid Emerg Nurs. 2002 Jan;10(1):31–9. PMID: 11998582. Exclusion Code: X 7.11998582
242 Reichenheim ME, Paixao CM, Jr., Moraes CL. Reassessing the construct validity of a Brazilian version of the instrument Caregiver Abuse Screen (CASE) used to identify risk of domestic violence against the elderly. J Epidemiol Community Health. 2009 Nov;63(11):878–83. doi: 10.1136/jech.2008.084095. PMID: 19622518. Exclusion Code: X 6.19622518
243 Reichenheim ME, Patricio TF, Moraes CL. Detecting intimate partner violence during pregnancy: awareness-raising indicators for use by primary healthcare professionals. Public Health. 2008 Jul;122(7):716–24. doi: 10.1016/j.puhe.2007.09.016. PMID: 18222507. Exclusion Code: X 3.18222507
244 Reis BY, Kohane IS, Mandl KD. Longitudinal histories as predictors of future diagnoses of domestic abuse: modelling study. BMJ. 2009;339:b3677. PMID: 19789406. Exclusion Code: X 7.19789406
245 Reis M, Nahmiash D. Validation of the indicators of abuse (IOA) screen. Gerontologist. 1998 Aug;38(4):471–80. PMID: 9726134. Exclusion Code: X 8.9726134
246 Reisenhofer S, Taft A. Women’s journey to safety - The Transtheoretical model in clinical practice when working with women experiencing Intimate Partner Violence: A scientific review and clinical guidance. Patient Educ Couns. 2013;93(3):536–48. Exclusion Code: X 1.24007763
247 Rhodes KV, Drum M, Anliker E, . Lowering the threshold for discussions of domestic violence: a randomized controlled trial of computer screening. Arch Intern Med. 2006 May 22;166(10):1107–14. doi: 10.1001/archinte.166.10.1107. PMID: 16717173. Exclusion Code: X 6.16717173
248 Rhodes KV, Frankel RM, Levinthal N, . “You’re not a victim of domestic violence, are you?” Provider patient communication about domestic violence. In Ann Intern Med Exclusion Code: X 6.
249 Rhodes KV, Grisso JA, Rodgers M, . The anatomy of a community health center system-level intervention for intimate partner violence. J Urban Health. 2014 Feb;91(1):107–21. doi: 10.1007/s11524-013-9816-9. PMID: 23917943. Exclusion Code: X 6.23917943
250 Rhodes KV, Lauderdale DS, He T, . “Between me and the computer”: increased detection of intimate partner violence using a computer questionnaire. Ann Emerg Med. 2002 Nov;40(5):476–84. doi: [pii]. PMID: 12399790. Exclusion Code: X 6.12399790
251 Rhodes KV, Rodgers M, Sommers M, . The Social Health Intervention Project (SHIP): protocol for a randomized controlled clinical trial assessing the effectiveness of a brief motivational intervention for problem drinking and intimate partner violence in an urban emergency department. BMC Emerg Med. 2014;14:10. doi: 10.1186/1471-227X-14-10. PMID: 24742322. Exclusion Code: X 6.24742322
252 Rhodes KV. Taking a fresh look at routine screening for intimate partner violence: what can we do about what we know? Mayo Clin Proc. 2012 May;87(5):419–23. doi: 10.1016/j.mayocp.2012.02.006. PMID: 22560520. Exclusion Code: X 1.22560520
253 Rivas C, Ramsay J, Sadowski L, . Advocacy interventions to reduce or eliminate violence and promote the physical and psychosocial well-being of women who experience intimate partner abuse. Cochrane Database Syst Rev. 2015;12:CD005043. doi: 10.1002/14651858.CD005043.pub3. Exclusion Code: X 7.
254 Robinson-Whelen S, Hughes RB, Gabrielli J, . A safety awareness program for women with diverse disabilities: a randomized controlled trial. Violence Against Women. 2014 Jul;20(7):846–68. doi: 10.1177/1077801214543387. PMID: 25031362. Exclusion Code: X 2.25031362
255 Roque AM, Weinberg J, Hohler AD. Evaluating exposure to abuse and violence in neurological patients. Neurologist. 2013 Jan;19(1):7–10. doi: 10.1097/NRL.0b013e31827c6c26. PMID: 23269099. Exclusion Code: X 6.23269099
256 Ross J, Walther V, Epstein I. Screening risks for intimate partner violence and primary care settings: implications for future abuse. Soc Work Health Care. 2004;38(4):1–23. doi: 10.1300/J010v38n04_01. PMID: 15149903. Exclusion Code: X 6.15149903
257 Rotheram-Borus MJ, Tomlinson M, Roux IL, . Alcohol use, partner violence, and depression: a cluster randomized controlled trial among urban South African mothers over 3 years. Am J Prev Med. 2015;49(5):715–25. Exclusion Code: X 9.26231855
258 Rudolph MN, Hughes DH. Emergency assessments of domestic violence, sexual dangerousness, and elder and child abuse. Psychiatr Serv. 2001 Mar;52(3):281–2, 306. doi: 10.1176/appi.ps.52.3.281. PMID: 11239094. Exclusion Code: X 1.11239094
259 Saggurti N, Nair S, Silverman JG, . Impact of the RHANI Wives intervention on marital conflict and sexual coercion. Int J Gynaecol Obstet. 2014 Jul;126(1):18–22. doi: 10.1016/j.ijgo.2014.01.015. PMID: 24795094. Exclusion Code: X 9.24795094
260 Sagrestano LM, Rodriguez AC, Carroll D, . A comparison of standardized measures of psychosocial variables with single-item screening measures used in an urban obstetric clinic. J Obstet Gynecol Neonatal Nurs. 2002 Mar-Apr;31(2):147–55. doi: [pii]. PMID: 11926397. Exclusion Code: X 6.11926397
261 Schrager JD, Smith LS, Heron SL, . Does stage of change predict improved intimate partner violence outcomes following an emergency department intervention? Acad Emerg Med. 2013 Feb;20(2):169–77. doi: 10.1111/acem.12081. PMID: 23406076. Exclusion Code: X 7.23406076
262 Schumm JA, O’Farrell TJ, Kahler CW, . A randomized clinical trial of behavioral couples therapy versus individually based treatment for women with alcohol dependence. J Consult Clin Psychol. 2014;82(6):993–1004. Exclusion Code: X 4.25045910
263 Schumm JA, O’Farrell TJ, Murphy CM, . Partner violence before and after couples-based alcoholism treatment for female alcoholic patients. J Consult Clin Psychol. 2009 Dec;77(6):1136–46. doi: 10.1037/a0017389. PMID: 19968389. Exclusion Code: X 4.19968389
264 Scribano PV, Stevens J, Marshall J, . Feasibility of computerized screening for intimate partner violence in a pediatric emergency department. Pediatr Emerg Care. 2011 Aug;27(8):710–6. doi: 10.1097/PEC.0b013e318226c871. PMID: 21811196. Exclusion Code: X 6.21811196
265 Sengstock MC, Hwalek M, Stahl C. Developing new models of service delivery to aged abuse victims: does it matter? Clinical Sociology Review. 1991 1991;9:142–61. PMID: 61299773; 93Z6312. Exclusion Code: X 5.
266 Shadigian EM, Bauer ST. Screening for partner violence during pregnancy. Int J Gynaecol Obstet. 2004 Mar;84(3):273–80. doi: 10.1016/j.ijgo.2003.07.001. PMID: 15001383. Exclusion Code: X 1.15001383
267 Shakil A, Bardwell J, Sherin K, . Development of Verbal HITS for intimate partner violence screening in family medicine. Fam Med. 2014 Mar;46(3):180–5. PMID: 24652635. Exclusion Code: X 5.24652635
268 Shakil A, Donald S, Sinacore JM, . Validation of the HITS domestic violence screening tool with males. Fam Med. 2005 Mar;37(3):193–8. PMID: 15739135. Exclusion Code: X 13..15739135
269 Shakil A, Donald S, Sinacore JM, . Validation of the HITS domestic violence screening tool with males. Fam Med. 2005 Mar;37(3):193–8. PMID: 15739135. Exclusion Code: X 13..15739135
270 Sharps P, Alhusen JL, Bullock L, . Engaging and retaining abused women in perinatal home visitation programs. Pediatrics. 2013 Nov;132: Suppl 2:S134–9. doi: 10.1542/peds.2013-1021L. PMID: 24187115. Exclusion Code: X 6.24187115
271 Shock LP. Responding to evidence of abuse in the elderly. JAAPA. 2000 Jun;13(6):73–6, 82, 5. PMID: 11503243. Exclusion Code: X 1.11503243
272 Shorey RC, Brasfield H, Febres J, . A comparison of three different scoring methods for self-report measures of psychological aggression in a sample of college females. Violence Vict. 2012;27(6):973–90. PMID: 23393957. Exclusion Code: X 8.23393957
273 Shorey RC, Cornelius TL, Bell KM. Reactions to participating in dating violence research: are our questions distressing participants? J Interpers Violence. 2011 Sep;26(14):2890–907. doi: 10.1177/0886260510390956. PMID: 21156687. Exclusion Code: X 8.21156687
274 Shugarman LR, Fries BE, Wolf RS, . Identifying older people at risk of abuse during routine screening practices. J Am Geriatr Soc. 2003 Jan;51(1):24–31. doi: [pii]. PMID: 12534841. Exclusion Code: X 6.12534841
275 Siegel RM, Hill TD, Henderson VA, . Screening for domestic violence in the community pediatric setting. Pediatrics. 1999 Oct;104(4 Pt 1):874–7. PMID: 10506228. Exclusion Code: X 6.10506228
276 Siemieniuk RA, Krentz HB, Gish JA, . Domestic violence screening: prevalence and outcomes in a Canadian HIV population. AIDS Patient Care STDS. 2010 Dec;24(12):763–70. doi: 10.1089/apc.2010.0235. PMID: 21138382. Exclusion Code: X 1.21138382
277 Sieving RE, McMorris BJ, Secor-Turner M, . Prime time: 18-month violence outcomes of a clinic-linked intervention. Prev Sci. 2014 Aug;15(4):460–72. doi: 10.1007/s11121-013-0387-5. PMID: 23543359. Exclusion Code: X 4.23543359
278 Simon W, Sliwka P. Effectiveness of group psychotherapy for adult outpatients traumatized by abuse, neglect, and/or pregnancy loss: a multiple-site, pre-post-follow-up, naturalistic study. Int J Group Psychother. 2012 Apr;62(2):283–308. doi: 10.1521/ijgp.2012.62.2.283. PMID: 22468575. Exclusion Code: X 2.22468575
279 Simpson LE, Atkins DC, Gattis KS, . Low-level relationship aggression and couple therapy outcomes. J Fam Psychol. 2008 Feb;22(1):102–11. doi: 10.1037/0893-3200.22.1.102. PMID: 18266537. Exclusion Code: X 7.18266537
280 Simpson Rowe L, Jouriles EN, McDonald R, . Enhancing women’s resistance to sexual coercion: a randomized controlled trial of the DATE program. J Am Coll Health. 2012;60(3):211–8. doi: 10.1080/07448481.2011.587068. PMID: 22420698. Exclusion Code: X 2.22420698
281 Sirey JA, Berman J, Salamone A, . Feasibility of integrating mental health screening and services into routine elder abuse practice to improve client outcomes. J Elder Abuse Negl. 2015;27(3):254–69. doi: 10.1080/08946566.2015.1008086. PMID: 25611116. Exclusion Code: X 3.25611116
282 Smith DB, Whiting JB, Karakurt G, . The Self Assessment of Future Events Scale (SAFE): assessing perceptions of risk for future violence in intimate partner relationships. J Marital Fam Ther. 2013 Jul;39(3):314–29. doi: 10.1111/j.1752-0606.2012.00319.x. PMID: 25059299. Exclusion Code: X 6.25059299
283 Smith R, Dobbins S, Evans A, . Hospital-based violence intervention: risk reduction resources that are essential for success. J Trauma Acute Care Surg. 2013 Apr;74(4):976–80; discussion 80-2. doi: 10.1097/TA.0b013e31828586c9. PMID: 23511134. Exclusion Code: X 2.23511134
284 Snider C, Logsetty S, Jiang D. Interim results of a pilot randomized control trial of an ED-based violence intervention program. Canadian Journal of Emergency Medicine. 2015;17((Snider C.; Logsetty S.; Jiang D.) Department of Emergency Medicine, University of Manitoba, Winnipeg, Canada):S82. doi: 10.1017/cem.2015.50. Exclusion Code: X 2.
285 Snider C, Webster D, O’Sullivan CS, . Intimate partner violence: development of a brief risk assessment for the emergency department. Acad Emerg Med. 2009 Nov;16(11):1208–16. doi: 10.1111/j.1553-2712.2009.00457.x. PMID: 20053241. Exclusion Code: X 3.20053241
286 Sohani Z, Shannon H, Busse JW, . Feasibility of screening for intimate partner violence at orthopedic trauma hospitals in India. J Interpers Violence. 2013 May;28(7):1455–75. doi: 10.1177/0886260512468244. PMID: 23262825. Exclusion Code: X 9.23262825
287 Sommerfeld DH, Henderson LB, Snider MA, . Multidimensional measurement within adult protective services: design and initial testing of the tool for risk, interventions, and outcomes. J Elder Abuse Negl. 2014;26(5):495–522. doi: 10.1080/08946566.2014.917598. PMID: 24848994. Exclusion Code: X 8.24848994
288 Spangaro J, Poulos RG, Zwi AB. Pandora doesn’t live here anymore: normalization of screening for intimate partner violence in Australian antenatal, mental health, and substance abuse services. Violence Vict. 2011;26(1):130–44. PMID: 21776834. Exclusion Code: X 2.21776834
289 Spangaro JM, Zwi AB, Poulos RG, . Who tells and what happens: disclosure and health service responses to screening for intimate partner violence. Health Soc Care Community. 2010 Nov;18(6):671–80. doi: 10.1111/j.1365-2524.2010.00943.x. PMID: 20637041. Exclusion Code: X 6.20637041
290 Spangaro JM. The NSW Health routine screening for domestic violence program. N S W Public Health Bull. 2007 May-Jun;18(5-6):86–9. doi: [pii]. PMID: 17651662. Exclusion Code: X 1.17651662
291 Spinola C, Stewart L, Fanslow J, . Developing and implementing an intervention. Evaluation of an emergency department pilot on partner abuse. Eval Health Prof. 1998 Mar;21(1):91–119. PMID: 10183341. Exclusion Code: X 6.10183341
292 Stark S. Elder abuse: screening, intervention, and prevention. Nursing. 2012 Oct;42(10):24–9; quiz 9-30. doi: 10.1097/01.NURSE.0000419426.05524.45 [doi]. PMID: 22955256. Exclusion Code: X 1.22955256
293 Stayton CD, Duncan MM. Mutable influences on intimate partner abuse screening in health care settings: a synthesis of the literature. Trauma Violence Abuse. 2005 Oct;6(4):271–85. doi: 10.1177/1524838005277439. PMID: 16217117. Exclusion Code: X 1.16217117
294 Stenson K, Heimer G, Lundh C, . The prevalence of violence investigated in a pregnant population in Sweden. J Psychosom Obstet Gynaecol. 2001 Dec;22(4):189–97. PMID: 11840572. Exclusion Code: X 6.11840572
295 Stevens J, Scribano PV, Marshall J, . A Trial of Telephone Support Services to Prevent Further Intimate Partner Violence. In Violence Against Women Exclusion Code: X 5.
296 Stith SM, Rosen KH, McCollum EE, . Treating intimate partner violence within intact couple relationships: outcomes of multi-couple versus individual couple therapy. J Marital Fam Ther. 2004 Jul;30(3):305–18. PMID: 15293649. Exclusion Code: X 5.15293649
297 Stith SM, Rosen KH, McCollum EE. Effectiveness of couples treatment for spouse abuse. J Marital Fam Ther. 2003 Jul;29(3):407–26. PMID: 12870412. Exclusion Code: X 1.12870412
298 Stockl H, Hertlein L, Himsl I, . Acceptance of routine or case-based inquiry for intimate partner violence: a mixed method study. BMC Pregnancy Childbirth. 2013;13:77. doi: 10.1186/1471-2393-13-77. PMID: 23531127. Exclusion Code: X 6.23531127
299 Stockl H. A move beyond screening is required to ensure adequate healthcare response for women who experience intimate partner violence. Evid Based Med. 2014 Dec;19(6):240. doi: 10.1136/ebmed-2014-110049. PMID: 25053640. Exclusion Code: X 1.25053640
300 Stonard G, Whapples E. Domestic violence in pregnancy: midwives and routine questioning. Pract Midwife. 2016 Jan;19(1):26–9. PMID: 26975130. Exclusion Code: X 1.26975130
301 Stuart GL, Ramsey SE, Moore TM, . Reductions in marital violence following treatment for alcohol dependence. J Interpers Violence. 2003 Oct;18(10):1113–31. PMID: 19771712. Exclusion Code: X 4.19771712
302 Subramanian S, Katz KS, Rodan M, . An integrated randomized intervention to reduce behavioral and psychosocial risks: pregnancy and neonatal outcomes. Matern Child Health J. 2012 Apr;16(3):545–54. doi: 10.1007/s10995-011-0875-9. PMID: 21931956. Exclusion Code: X 2.21931956
303 Sullivan CM, Bybee DI. Reducing violence using community-based advocacy for women with abusive partners. J Consult Clin Psychol. 1999 Feb;67(1):43–53. PMID: 10028208. Exclusion Code: X 2.10028208
304 Sullivan CM, Campbell R, Angelique H, . An advocacy intervention program for women with abusive partners: six-month follow-up. Am J Community Psychol. 1994 Feb;22(1):101–22. PMID: 7942642. Exclusion Code: X 2.7942642
305 Sullivan CM, Tan C, Basta J, . An advocacy intervention program for women with abusive partners: initial evaluation. Am J Community Psychol. 1992 Jun;20(3):309–32. PMID: 1415030. Exclusion Code: X 2.1415030
306 Sullivan CM. Using the ESID model to reduce intimate male violence against women. Am J Community Psychol. 2003 Dec;32(3-4):295–303. PMID: 14703265. Exclusion Code: X 2.14703265
307 Sweeney AC, Weitlauf JC, Manning EA, . Intimate partner violence: perspectives on universal screening for women in VHA primary care. Womens Health Issues. 2013 Mar-Apr;23(2):e73–6. doi: 10.1016/j.whi.2012.12.004. PMID: 23415320. Exclusion Code: X 1.23415320
308 Taft A, O’Doherty L, Hegarty K, . Screening women for intimate partner violence in healthcare settings. Cochrane Database Syst Rev. 2013;4:CD007007. doi: 10.1002/14651858.CD007007.pub2. PMID: 23633338. Exclusion Code: X 7.23633338
309 Taft AJ, Hooker L, Humphreys C, . Maternal and child health nurse screening and care for mothers experiencing domestic violence (MOVE): a cluster randomised trial. BMC Med. 2015;13:150. doi: 10.1186/s12916-015-0375-7. PMID: 26111528. Exclusion Code: X 5.26111528
310 Taft AJ, Small R, Hegarty KL, . Mothers’ AdvocateS In the Community (MOSAIC)-non-professional mentor support to reduce intimate partner violence and depression in mothers: a cluster randomised trial in primary care. BMC Public Health. 2011;11:178. doi: 10.1186/1471-2458-11-178. PMID: 21429226. Exclusion Code: X 2.21429226
311 Taft AJ, Small R, Humphreys C, . Enhanced maternal and child health nurse care for women experiencing intimate partner/family violence: protocol for MOVE, a cluster randomised trial of screening and referral in primary health care. BMC Public Health. 2012;12:811. doi: 10.1186/1471-2458-12-811. PMID: 22994910. Exclusion Code: X 6.22994910
312 Tancredi DJ, Silverman JG, Decker MR, . Cluster randomized controlled trial protocol: addressing reproductive coercion in health settings (ARCHES). BMC Womens Health. 2015;15:57. doi: 10.1186/s12905-015-0216-z. PMID: 26245752. Exclusion Code: X 6.26245752
313 Terebelo S. Practical approaches to screening for domestic violence. JAAPA. 2006 Sep;19(9):30–5. PMID: 16999285. Exclusion Code: X 1.16999285
314 The end of universal screening for intimate partner violence? BMJ. 2013;346:f2532. PMID: 23616169. Exclusion Code: X 1.23616169
315 Thompson RS, Rivara FP, Thompson DC, . Identification and management of domestic violence: a randomized trial. Am J Prev Med. 2000 Nov;19(4):253–63. doi: [pii]. PMID: 11064229. Exclusion Code: X 6.11064229
316 Thurston WE, Tutty LM, Eisener AE, . Domestic violence screening rates in a community health center urgent care clinic. Res Nurs Health. 2007 Dec;30(6):611–9. doi: 10.1002/nur.20221. PMID: 18022814. Exclusion Code: X 6.18022814
317 Tirado-Munoz J, Gilchrist G, Farre M, . The efficacy of cognitive behavioural therapy and advocacy interventions for women who have experienced intimate partner violence: a systematic review and meta-analysis. Ann Med. 2014 Dec;46(8):567–86. doi: 10.3109/07853890.2014.941918. PMID: 25211469. Exclusion Code: X 7.25211469
318 Tiwari A, Chan CL, Ho RT, . Effect of a qigong intervention program on telomerase activity and psychological stress in abused Chinese women: a randomized, wait-list controlled trial. BMC Complement Altern Med. 2014;14:300. doi: 10.1186/1472-6882-14-300. PMID: 25127878. Exclusion Code: X 6.25127878
319 Todahl J, Walters E. Universal screening for intimate partner violence: a systematic review. J Marital Fam Ther. 2011 Jul;37(3):355–69. doi: 10.1111/j.1752-0606.2009.00179.x. PMID: 21745237. Exclusion Code: X 7.21745237
320 Trautman DE, McCarthy ML, Miller N, . Intimate partner violence and emergency department screening: computerized screening versus usual care. Ann Emerg Med. 2007 Apr;49(4):526–34. doi: 10.1016/j.annemergmed.2006.11.022. PMID: 17276547. Exclusion Code: X 5.17276547
321 Van Parys AS, Verhamme A, Temmerman M, . Intimate partner violence and pregnancy: a systematic review of interventions. PLoS One. 2014;9(1). Exclusion Code: X 7.
322 Vogel J. Effective gender-based violence screening tools for use in primary health care settings in Afghanistan and Pakistan: a systematic review. East Mediterr Health J. 2013 Mar;19(3):219–26. PMID: 23879072. Exclusion Code: X 7.23879072
323 Waller AE, Hohenhaus SM, Shah PJ, . Development and validation of an emergency department screening and referral protocol for victims of domestic violence. Ann Emerg Med. 1996;27(6):754–60. Exclusion Code: X 2.8644964
324 Wang JJ, Tseng HF, Chen KM. Development and testing of screening indicators for psychological abuse of older people. Arch Psychiatr Nurs. 2007 Feb;21(1):40–7. doi: 10.1016/j.apnu.2006.09.004. PMID: 17258108. Exclusion Code: X 5.17258108
325 Wathen CN, MacMillan HL. Health care’s response to women exposed to partner violence: moving beyond universal screening. JAMA. 2012 Aug 15;308(7):712–3. doi: 10.1001/jama.2012.9913. PMID: 22893169. Exclusion Code: X 1.22893169
326 Wathen CN, MacMillan HL. Interventions for violence against women: scientific review. JAMA. 2003 Feb 5;289(5):589–600. doi: [pii]. PMID: 12578492. Exclusion Code: X 7.12578492
327 Weaver TL, Gilbert L, El-Bassel N, . Identifying and intervening with substance-using women exposed to intimate partner violence: phenomenology, comorbidities, and integrated approaches within primary care and other agency settings. J Womens Health (Larchmt). 2015 Jan;24(1):51–6. doi: 10.1089/jwh.2014.4866. PMID: 25554915. Exclusion Code: X 1.25554915
328 Weaver TL. Method variance and sensitivity of screening for traumatic stressors. J Trauma Stress. 1998 Jan;11(1):181–5. doi: 10.1023/A:1024477620628. PMID: 9479687. Exclusion Code: X 3.9479687
329 Webster J, Creedy DK. Domestic violence. Screening can be made acceptable to women. BMJ. 2002 Jul 6;325(7354):44. PMID: 12102079. Exclusion Code: X 1.12102079
330 Webster J, Holt V. Screening for partner violence: direct questioning or self-report? Obstet Gynecol. 2004 Feb;103(2):299–303. doi: 10.1097/01.AOG.0000110245.83404.3d. PMID: 14754699. Exclusion Code: X 5.14754699
331 Wetmore M, Fairbairn CD. A regional California program to screen adolescent patients for intimate partner violence. J Emerg Nurs. 2003 Aug;29(4):373–6. doi: [pii]. PMID: 12874565. Exclusion Code: X 5.12874565
332 Whitehouse WP. Study shows that more must be done to detect domestic violence. BMJ. 2014;348:g3946. PMID: 24942853. Exclusion Code: X 1.24942853
333 Wiglesworth A, Mosqueda L, Mulnard R, . Screening for abuse and neglect of people with dementia. J Am Geriatr Soc. 2010 Mar;58(3):493–500. doi: 10.1111/j.1532-5415.2010.02737.x. PMID: 20398118. Exclusion Code: X 6.20398118
334 Wilbur L, Noel N, Couri G. Is screening women for intimate partner violence in the emergency department effective? Ann Emerg Med. 2013 Dec;62(6):609–11. doi: 10.1016/j.annemergmed.2013.06.012. PMID: 23870859. Exclusion Code: X 1.23870859
335 Wilson IM, Graham K, Taft A. Alcohol interventions, alcohol policy and intimate partner violence: a systematic review. BMC Public Health. 2014;14:881. doi: 10.1186/1471-2458-14-881. PMID: 25160510. Exclusion Code: X 4.25160510
336 Wilson JS, Lane EM, Gillespie T. Identifying and responding to intimate partner violence in the health care setting. Okla Nurse. 2006 Jun-Aug;51(2):28–32; quiz 3. PMID: 16737118. Exclusion Code: X 1.16737118
337 Wong JY, Tiwari A, Fong DY, . Intimate partner violence, depressive symptoms, and immigration status: does existing advocacy intervention work on abused immigrant women in the Chinese community? J Interpers Violence. 2013 Jul;28(11):2181–202. doi: 10.1177/0886260512475311. PMID: 23400883. Exclusion Code: X 6.23400883
338 Woodin EM, Sotskova A, O’Leary KD. Do motivational interviewing behaviors predict reductions in partner aggression for men and women? Behav Res Ther. 2012 Jan;50(1):79–84. doi: 10.1016/j.brat.2011.11.001. PMID: 22119133. Exclusion Code: X 5.22119133
339 Wray AM, Hoyt T, Gerstle M. Preliminary examination of a mutual intimate partner violence intervention among treatment-mandated couples. J Fam Psychol. 2013 Aug;27(4):664–70. doi: 10.1037/a0032912. PMID: 23750516. Exclusion Code: X 8.23750516
340 Wright RJ. Identification of domestic violence in the community pediatric setting: need to protect mothers and children. Arch Pediatr Adolesc Med. 2000 May;154(5):431–3. PMID: 10807290. Exclusion Code: X 1.10807290
341 Wuest J, Merritt-Gray M, Dube N, . The process, outcomes, and challenges of feasibility studies conducted in partnership with stakeholders: a health intervention for women survivors of intimate partner violence. Res Nurs Health. 2015 Feb;38(1):82–96. doi: 10.1002/nur.21636. PMID: 25594917. Exclusion Code: X 5.25594917
342 Wyant AR, Collett D. Trauma in pregnancy: diagnosis and management of two patients in one. JAAPA. 2013 May;26(5):24–9. PMID: 23682452. Exclusion Code: X 1.23682452
343 Yaffe MJ, Tazkarji B. Understanding elder abuse in family practice. Can Fam Physician. 2012 Dec;58(12):1336–40, e695-8. doi: [pii]. PMID: 23242889. Exclusion Code: X 1.23242889
344 Yaffe MJ, Wolfson C, Lithwick M, . Development and validation of a tool to improve physician identification of elder abuse: the Elder Abuse Suspicion Index (EASI). J Elder Abuse Negl. 2008;20(3):276–300. doi: 10.1080/08946560801973168. PMID: 18928055. Exclusion Code: X 12.18928055
345 Zachary MJ, Mulvihill MN, Burton WB, . Domestic abuse in the emergency department: can a risk profile be defined? Acad Emerg Med. 2001 Aug;8(8):796–803. PMID: 11483454. Exclusion Code: X 3.11483454
346 Zakrison TL, Ruiz X, Gelbard R, . Universal screening for intimate partner and sexual violence in trauma patients: An EAST multicenter trial. J Trauma Acute Care Surg. 2017 Jul;83(1):105–10. doi: 10.1097/TA.0000000000001495. PMID: 28426560. Exclusion Code: X 6.28426560
347 Zhang H, Neelarambam K, Schwenke TJ, . Mediators of a culturally-sensitive intervention for suicidal African American women. J Clin Psychol Med Settings. 2013 Dec;20(4):401–14. doi: 10.1007/s10880-013-9373-0. PMID: 23864403. Exclusion Code: X 13.23864403
348 Zhang H, Neelarambam K, Schwenke TJ, . Mediators of a culturally-sensitive intervention for suicidal African American women. J Clin Psychol Med Settings. 2013 Dec;20(4):401–14. doi: 10.1007/s10880-013-9373-0. PMID: 23864403. Exclusion Code: X 13.23864403