# Appendix B Detailed Methods

## Original Search Strategies

### KQ 2

#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Intimate Partner Violence”[Mesh]) OR, “Elder Abuse”[Mesh]) OR, (“Spouse Abuse”[Mesh]) OR, “Battered Women”[Mesh] | 9879 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Domestic Violence”[Mesh]) NOT “Child Abuse”[Mesh] | 11929 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 OR, #2) | 13490 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Mass Screening”[Mesh]) OR, (“Risk”[Mesh] OR, “Risk Assessment”[Mesh])) | 1016867 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 AND #4) | 3716 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Surveys and Questionnaires”[Mesh]) OR, (“Diagnosis”[Mesh] OR, “diagnosis” [Subheading])) | 9346557 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #6) | 2106 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #6) Filters: Humans | 2106 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #6) Filters: Humans; English | 2034 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #6) Filters: Publication date from 2012/01/01; Humans; English | 490 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)

Cochrane

((partner OR, spouse) AND (abuse OR, violence)) AND ((harms OR, adverse) AND (studies))

- Reviews=3=2 New
- DARE=3=2 New
- Cochrane Controlled Clinical Trials Registry=7=3 New

Embase=69=57

((partner OR, spouse) AND (abuse OR, violence)) AND ((harms OR, adverse) AND (studies)) =12 New

Total KQ 2 Database=554

### KQ 3

#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Intimate Partner Violence”[Mesh]) OR, “Elder Abuse”[Mesh]) OR, (“Spouse Abuse”[Mesh]) OR, “Battered Women”[Mesh] | 9879 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Domestic Violence”[Mesh]) NOT “Child Abuse”[Mesh] | 11929 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 OR, #2) | 13490 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Mass Screening”[Mesh]) OR, (“Risk”[Mesh] OR, “Risk Assessment”[Mesh])) | 1016867 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 AND #4) | 3716 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Surveys and Questionnaires”[Mesh]) OR, (“Diagnosis”[Mesh] OR, “diagnosis” [Subheading])) | 9346557 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #6) | 2106 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #6) Filters: Humans | 2106 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #6) Filters: Humans; English | 2034 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #6) Filters: Publication date from 2012/01/01; Humans; English | 490 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#17 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Observational Study” [Publication Type] OR, “Prospective Studies”[Mesh] OR, “Cohort Studies” [Mesh] OR, “adverse effects” [Subheading] OR, harms[tw]Filters: Publication date from 2012/01/01; Humans; English | 514448 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#10 AND #17) Filters: Publication date from 2012/01/01; Humans; English | 120 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)

Cochrane

((partner OR, spouse) AND (abuse OR, violence)) AND ((harms OR, adverse) AND (studies))

- Reviews=0 New
- DARE=0 New
- Cochrane Controlled Clinical Trials Registry=1 New

Embase

((partner OR, spouse) AND (abuse OR, violence)) AND ((harms OR, adverse) AND (studies)) =12 New

Total Database KQ 3=133

### KQ 4

#1 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((“Intimate Partner Violence”[Mesh]) OR, “Elder Abuse”[Mesh]) OR, (“Spouse Abuse”[Mesh]) OR, “Battered Women”[Mesh] | 9879 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Domestic Violence”[Mesh]) NOT “Child Abuse”[Mesh] | 11929 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 OR, #2) | 13490 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#17 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Observational Study” [Publication Type] OR, “Prospective Studies”[Mesh] OR, “Cohort Studies” [Mesh] OR, “adverse effects” [Subheading] OR, harms[tw]Filters: Publication date from 2012/01/01; Humans; English | 514448 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#24 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((((((“prevention and control” [Subheading] OR, “Primary Prevention”[Mesh]) OR, “Preventive Health Services”[Mesh]) OR, “Counseling”[Mesh]) OR, “Outcome and Process Assessment (Health Care)”[Mesh]) OR, “Mental Health Services”[Mesh])) | 2214779 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=24)
#27 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #3 AND #24 | 4896 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=27)
#28 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Random Allocation”[Mesh] OR, “Randomized Controlled Trial” [Publication Type] OR, “Randomized Controlled Trials as Topic”[Mesh]) OR, (“Single-Blind Method”[Mesh] OR, “Double-Blind Method”[Mesh]) | 604087 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=28)
#29 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#27 AND #28) | 221 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=29)
#30 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#27 AND #28) Filters: Humans | 221 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=30)
#31 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#27 AND #28) Filters: Humans; English | 221 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=31)
#32 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#27 AND #28) Filters: Publication date from 2012/01/01; Humans; English | 98 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=32)
#39 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((“Patient Outcome Assessment”[Mesh] OR, “Outcome Assessment (Health Care)”[Mesh] OR, “Pragmatic Clinical Trial” [Publication Type]) OR, “Outcome and Process Assessment (Health Care)”[Mesh]) OR, “Epidemiologic Studies”[Mesh] | 2368187 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=39)
#40 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#27 AND #39) | 841 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=40)
#41 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#40 OR, #32) | 900 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=41)
#42 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#40 OR, #32) Filters: Humans | 900 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=42)
#43 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#40 OR, #32) Filters: Humans; English | 867 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=43)
#45 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#40 OR, #32) Filters: Publication date from 2012/01/01; Humans; English | [underlined: 253]

Cochrane

((partner OR, spouse OR, elder) AND (abuse OR, violence)) AND “controlled trials”

- Reviews=9=2 New
- DARE=3=2 New
- Cochrane Controlled Clinical Trials Registry=9=4 New

Embase

((partner OR, spouse OR, elder) AND (abuse OR, violence)) AND “controlled trials”

131=81 New

Total Database KQ 4=342

### KQ 5

#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Intimate Partner Violence”[Mesh]) OR, “Elder Abuse”[Mesh]) OR, (“Spouse Abuse”[Mesh]) OR, “Battered Women”[Mesh] | 9879 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Domestic Violence”[Mesh]) NOT “Child Abuse”[Mesh] | 11929 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 OR, #2) | 13490 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#17 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Observational Study” [Publication Type] OR, “Prospective Studies”[Mesh] OR, “Cohort Studies” [Mesh] OR, “adverse effects” [Subheading] OR, harms[tw]Filters: Publication date from 2012/01/01; Humans; English | 514448 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#24 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((((((“prevention and control” [Subheading] OR, “Primary Prevention”[Mesh]) OR, “Preventive Health Services”[Mesh]) OR, “Counseling”[Mesh]) OR, “Outcome and Process Assessment (Health Care)”[Mesh]) OR, “Mental Health Services”[Mesh])) | 2214779 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=24)
#27 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #3 AND #24 | 4896 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=27)
#28 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Random Allocation”[Mesh] OR, “Randomized Controlled Trial” [Publication Type] OR, “Randomized Controlled Trials as Topic”[Mesh]) OR, (“Single-Blind Method”[Mesh] OR, “Double-Blind Method”[Mesh]) | 604087 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=28)
#29 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#27 AND #28) | 221 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=29)
#30 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#27 AND #28) Filters: Humans | 221 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=30)
#31 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#27 AND #28) Filters: Humans; English | 221 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=31)
#32 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#27 AND #28) Filters: Publication date from 2012/01/01; Humans; English | 98 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=32)
#39 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Patient Outcome Assessment”[Mesh] OR, “Outcome Assessment (Health Care)”[Mesh] OR, “Pragmatic Clinical Trial” [Publication Type]) OR, “Outcome and Process Assessment (Health Care)”[Mesh]) OR, “Epidemiologic Studies”[Mesh] | 2368187 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=39)
#40 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#27 AND #39) | 841 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=40)
#41 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#40 OR, #32) | 900 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=41)
#42 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#40 OR, #32) Filters: Humans | 900 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=42)
#43 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#40 OR, #32) Filters: Humans; English | 867 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=43)
#45 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#40 OR, #32) Filters: Publication date from 2012/01/01; Humans; English | 255 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=45)
#46 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#17 AND #45) Filters: Publication date from 2012/01/01; Humans; English | 88 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=46)

Cochrane

((partner OR, spouse OR, elder) AND (abuse OR, violence)) AND (“controlled trials” AND outcome)

- Reviews=1=New=1
- DARE =0
- Cochrane Controlled Clinical Trials Registry=0

Embase

((partner OR, spouse OR, elder) AND (abuse OR, violence)) AND (“controlled trials” AND outcome)

New=19

Total Database KQ 5=108

## Update Searches

### PubMed

#1 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Intimate Partner Violence”[Mesh]) OR “Elder Abuse”[Mesh]) OR (“Spouse Abuse”[Mesh]) OR “Battered Women”[Mesh] | 10798 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Domestic Violence”[Mesh]) NOT “Child Abuse”[Mesh] | 12581 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 OR #2) | 14630 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Mass Screening”[Mesh]) OR (“Risk”[Mesh] OR “Risk Assessment”[Mesh])) | 1106268 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 AND #4) | 4079 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Surveys and Questionnaires”[Mesh]) OR (“Diagnosis”[Mesh] OR “diagnosis” [Subheading])) | 8845051 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #6) | 2285 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #6) Filters: Humans | 2285 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #6) Filters: Humans; English | 2209 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #6) Filters: Publication date from 2016/02/01; Humans; English | 122 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Observational Study” [Publication Type] OR “Prospective Studies”[Mesh] OR “Cohort Studies” [Mesh] OR “adverse effects” [Subheading] OR harms[tw]) Filters: Publication date from 2016/02/01; Humans; English | 143929 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#10 AND #11) Filters: Publication date from 2016/02/01; Humans; English | 28 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((((((“prevention and control” [Subheading] OR “Primary Prevention”[Mesh]) OR “Preventive Health Services”[Mesh]) OR “Counseling”[Mesh]) OR “Outcome and Process Assessment (Health Care)”[Mesh]) OR “Mental Health Services”[Mesh]))) Filters: Publication date from 2016/02/01; Humans; English | 97080 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 AND #13) Filters: Publication date from 2016/02/01; Humans; English | 203 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Random Allocation”[Mesh] OR “Randomized Controlled Trial” [Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh]) OR (“Single-Blind Method”[Mesh] OR “Double-Blind Method”[Mesh] Filters: Publication date from 2016/02/01; Humans; English | 28511 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#14 AND #15) Filters: Publication date from 2016/02/01; Humans; English | 30 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((“Patient Outcome Assessment”[Mesh] OR “Outcome Assessment (Health Care)”[Mesh] OR “Pragmatic Clinical Trial” [Publication Type]) OR “Outcome and Process Assessment (Health Care)”[Mesh]) OR “Epidemiologic Studies”[Mesh]) Filters: Publication date from 2016/02/01; Humans; English | 157528 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#14 AND #17) Filters: Publication date from 2016/02/01; Humans; English | 49 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#16 OR #18) Filters: Publication date from 2016/02/01; Humans; English | 65 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#20 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#19 OR #12 OR #10) Filters: Publication date from 2016/02/01; Humans; English | 168 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)

PubMed = 168 = 166 New

Cochrane

- Reviews=1=1 New
- DARE=0 New
- Cochrane Controlled Clinical Trials Registry=33=15 New

Embase=55=45

Total Update Database=227

Gray Lit

ClinicalTrials.gov=7=3 New

HSRProj=4

WHO ICTRP=12=0 New

Total=7

NIH Reporter=33

## Key Question Searches in PubMed

### KQ 2

#1 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Intimate Partner Violence”[Mesh]) OR “Elder Abuse”[Mesh]) OR (“Spouse Abuse”[Mesh]) OR “Battered Women”[Mesh] | 10798 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Domestic Violence”[Mesh]) NOT “Child Abuse”[Mesh] | 12581 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 OR #2) | 14630 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Mass Screening”[Mesh]) OR (“Risk”[Mesh] OR “Risk Assessment”[Mesh])) | 1106268 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 AND #4) | 4079 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Surveys and Questionnaires”[Mesh]) OR (“Diagnosis”[Mesh] OR “diagnosis” [Subheading])) | 8845051 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #6) | 2285 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #6) Filters: Humans | 2285 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #6) Filters: Humans; English | 2209 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #6) Filters: Publication date from 2016/02/01; Humans; English | 122 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)

### KQ 3

#1 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Intimate Partner Violence”[Mesh]) OR “Elder Abuse”[Mesh]) OR (“Spouse Abuse”[Mesh]) OR “Battered Women”[Mesh] | 10798 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Domestic Violence”[Mesh]) NOT “Child Abuse”[Mesh] | 12581 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 OR #2) | 14630 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Mass Screening”[Mesh]) OR (“Risk”[Mesh] OR “Risk Assessment”[Mesh])) | 1106268 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 AND #4) | 4079 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Surveys and Questionnaires”[Mesh]) OR (“Diagnosis”[Mesh] OR “diagnosis” [Subheading])) | 8845051 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #6) | 2285 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #6) Filters: Humans | 2285 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #6) Filters: Humans; English | 2209 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #6) Filters: Publication date from 2016/02/01; Humans; English | 122 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Observational Study” [Publication Type] OR “Prospective Studies”[Mesh] OR “Cohort Studies” [Mesh] OR “adverse effects” [Subheading] OR harms[tw]) Filters: Publication date from 2016/02/01; Humans; English | 143929 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#10 AND #11) Filters: Publication date from 2016/02/01; Humans; English | 28 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)

### KQ 4 & KQ 5

#1 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Intimate Partner Violence”[Mesh]) OR “Elder Abuse”[Mesh]) OR (“Spouse Abuse”[Mesh]) OR “Battered Women”[Mesh] | 10798 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Domestic Violence”[Mesh]) NOT “Child Abuse”[Mesh] | 12581 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 OR #2) | 14630 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Mass Screening”[Mesh]) OR (“Risk”[Mesh] OR “Risk Assessment”[Mesh])) | 1106268 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 AND #4) | 4079 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Surveys and Questionnaires”[Mesh]) OR (“Diagnosis”[Mesh] OR “diagnosis” [Subheading])) | 8845051 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #6) | 2285 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #6) Filters: Humans | 2285 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #6) Filters: Humans; English | 2209 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #6) Filters: Publication date from 2016/02/01; Humans; English | 122 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Observational Study” [Publication Type] OR “Prospective Studies”[Mesh] OR “Cohort Studies” [Mesh] OR “adverse effects” [Subheading] OR harms[tw]) Filters: Publication date from 2016/02/01; Humans; English | 143929 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#10 AND #11) Filters: Publication date from 2016/02/01; Humans; English | 28 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((((((“prevention and control” [Subheading] OR “Primary Prevention”[Mesh]) OR “Preventive Health Services”[Mesh]) OR “Counseling”[Mesh]) OR “Outcome and Process Assessment (Health Care)”[Mesh]) OR “Mental Health Services”[Mesh]))) Filters: Publication date from 2016/02/01; Humans; English | 97080 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 AND #13) Filters: Publication date from 2016/02/01; Humans; English | 203 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Random Allocation”[Mesh] OR “Randomized Controlled Trial” [Publication Type] OR “Randomized Controlled Trials as Topic”[Mesh]) OR (“Single-Blind Method”[Mesh] OR “Double-Blind Method”[Mesh] Filters: Publication date from 2016/02/01; Humans; English | 28511 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#14 AND #15) Filters: Publication date from 2016/02/01; Humans; English | 30 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((“Patient Outcome Assessment”[Mesh] OR “Outcome Assessment (Health Care)”[Mesh] OR “Pragmatic Clinical Trial” [Publication Type]) OR “Outcome and Process Assessment (Health Care)”[Mesh]) OR “Epidemiologic Studies”[Mesh]) Filters: Publication date from 2016/02/01; Humans; English | 157528 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#14 AND #17) Filters: Publication date from 2016/02/01; Humans; English | 49 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#16 OR #18) Filters: Publication date from 2016/02/01; Humans; English | 65 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)

### Additional Harms Search

#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Intimate Partner Violence”[Mesh]) OR, “Elder Abuse”[Mesh]) OR, (“Spouse Abuse”[Mesh]) OR, “Battered Women”[Mesh] | 9879 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Domestic Violence”[Mesh]) NOT “Child Abuse”[Mesh] | 11929 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 OR, #2) | 13490 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((((((“prevention and control” [Subheading] OR, “Primary Prevention”[Mesh]) OR, “Preventive Health Services”[Mesh]) OR, “Counseling”[Mesh]) OR, “Outcome and Process Assessment (Health Care)”[Mesh]) OR, “Mental Health Services”[Mesh])) | 2214779 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=24)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 AND #4) | 1683 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (harm OR, harms OR, adverse effect* OR, adverse event OR, complication* OR, death OR, stroke OR, mortality OR, “Long Term Adverse Effects”[Mesh]) | 4929732 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #6) | 1206 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #6) Filters: Humans | 1206 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #6) Filters: Humans; English | 890 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #6) Filters: Publication date from 2012/01/01; Humans; English | 360 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)

### Total Database IPV=1,001

Adding “Violence/prevention and control” as a Major Term

#1 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((((“Intimate Partner Violence”[Mesh]) OR, “Elder Abuse”[Mesh]) OR, (“Spouse Abuse”[Mesh]) OR, “Battered Women”[Mesh])) OR, ((“Domestic Violence”[Mesh]) NOT “Child Abuse”[Mesh]) | 13536 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#4 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Violence/prevention and control”[Majr] | 10525 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#4 NOT #1) | 7925 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#4 NOT #1) Filters: Humans | 7556 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#4 NOT #1) Filters: Humans; English | 6912 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#4 NOT #1) Filters: Publication date from 2012/01/01; Humans; English | 1265 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#10 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Mass Screening”[Mesh]) OR, (“Risk”[Mesh] OR, “Risk Assessment”[Mesh])) | 1021253 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Surveys and Questionnaires”[Mesh]) OR, (“Diagnosis”[Mesh] OR, “diagnosis” [Subheading])) | 9372880 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#8 AND #10 AND #11) | 77 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((((((“prevention and control” [Subheading] OR, “Primary Prevention”[Mesh]) OR, “Preventive Health Services”[Mesh]) OR, “Counseling”[Mesh]) OR, “Outcome and Process Assessment (Health Care)”[Mesh]) OR, “Mental Health Services”[Mesh])) | 2222452 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#15 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Random Allocation”[Mesh] OR, “Randomized Controlled Trial” [Publication Type] OR, “Randomized Controlled Trials as Topic”[Mesh]) OR, (“Single-Blind Method”[Mesh] OR, “Double-Blind Method”[Mesh]) | 606371 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#17 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (harm OR, harms OR, adverse effect* OR, adverse event OR, complication* OR, death OR, stroke OR, mortality OR, “Long Term Adverse Effects”[Mesh]) | 4905204 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#8 AND #13) | 1265 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#18 AND #15) | 74 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#20 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#18 AND #17) | 138 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)
#21 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#12 OR, #19 OR, #20) | 260 (https://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)

## Total Database IPV=1,259

### Focused Men 1995–2012

#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Intimate Partner Violence”[Mesh]) OR, “Elder Abuse”[Mesh]) OR, (“Spouse Abuse”[Mesh]) OR, “Battered Women”[Mesh] | 9879 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Domestic Violence”[Mesh]) NOT “Child Abuse”[Mesh] | 11929 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 OR, #2) | 13490 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Mass Screening”[Mesh]) OR, (“Risk”[Mesh] OR, “Risk Assessment”[Mesh])) | 1016867 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 AND #4) | 3716 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Surveys and Questionnaires”[Mesh]) OR, (“Diagnosis”[Mesh] OR, “diagnosis” [Subheading])) | 9346557 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #6) | 2106 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#17 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (harm OR, harms OR, adverse effect* OR, adverse event OR, complication* OR, death OR, stroke OR, mortality OR, “Long Term Adverse Effects”[Mesh]) | 4929732 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#24 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((((((“prevention and control” [Subheading] OR, “Primary Prevention”[Mesh]) OR, “Preventive Health Services”[Mesh]) OR, “Counseling”[Mesh]) OR, “Outcome and Process Assessment (Health Care)”[Mesh]) OR, “Mental Health Services”[Mesh])) | 2214779 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=24)
#27 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #3 AND #24 | 4896 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=27)
#28 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Random Allocation”[Mesh] OR, “Randomized Controlled Trial” [Publication Type] OR, “Randomized Controlled Trials as Topic”[Mesh]) OR, (“Single-Blind Method”[Mesh] OR, “Double-Blind Method”[Mesh]) | 604087 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=28)
#29 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#27 AND #28) | 221 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=29)
#30 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#27 AND #17) | 4901
#39 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((“Patient Outcome Assessment”[Mesh] OR, “Outcome Assessment (Health Care)”[Mesh] OR, “Pragmatic Clinical Trial” [Publication Type]) OR, “Outcome and Process Assessment (Health Care)”[Mesh]) OR, “Epidemiologic Studies”[Mesh] | 2368187 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=39)
#40 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#27 AND #39) | 841 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=40)
#41 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#7 OR, #29 OR, #30 OR, #40) | 3028 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=41)
#42 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#7 OR, #29 OR, #30 OR, #40)) Filters: Humans | 3028 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=42)
#43 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#7 OR, #29 OR, #30 OR, #40) Filters: Humans; English | 2923 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=43)
#44 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Men”[Mesh]) OR, “Male”[Mesh] | 7171428 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=41)
#45 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#43 AND #44) | 2150 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=43)
#46 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#43 AND #44) Filters: Publication date from 1995/01/01 to 2011/12/31; Humans; English; Male | 1017

Cochrane

- Reviews=0
- DARE=0
- Cochrane Controlled Clinical Trials Registry 13=4=New

Embase=87=65 New

Total Men Database=1,086

### Focused Adolescents

#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Intimate Partner Violence”[Mesh]) OR, “Elder Abuse”[Mesh]) OR, (“Spouse Abuse”[Mesh]) OR, “Battered Women”[Mesh] | 9879 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Domestic Violence”[Mesh]) NOT “Child Abuse”[Mesh] | 11929 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 OR, #2) | 13490 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Mass Screening”[Mesh]) OR, (“Risk”[Mesh] OR, “Risk Assessment”[Mesh])) | 1016867 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 AND #4) | 3716 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Surveys and Questionnaires”[Mesh]) OR, (“Diagnosis”[Mesh] OR, “diagnosis” [Subheading])) | 9346557 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #6) | 2106 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#17 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (harm OR, harms OR, adverse effect* OR, adverse event OR, complication* OR, death OR, stroke OR, mortality OR, “Long Term Adverse Effects”[Mesh]) | 4929732 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#24 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((((((“prevention and control” [Subheading] OR, “Primary Prevention”[Mesh]) OR, “Preventive Health Services”[Mesh]) OR, “Counseling”[Mesh]) OR, “Outcome and Process Assessment (Health Care)”[Mesh]) OR, “Mental Health Services”[Mesh])) | 2214779 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=24)
#27 (http://www.ncbi.nlm.nih.gov/pubmed) | Search #3 AND #24 | 4896 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=27)
#28 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Random Allocation”[Mesh] OR, “Randomized Controlled Trial” [Publication Type] OR, “Randomized Controlled Trials as Topic”[Mesh]) OR, (“Single-Blind Method”[Mesh] OR, “Double-Blind Method”[Mesh]) | 604087 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=28)
#29 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#27 AND #28) | 221 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=29)
#30 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#27 AND #17) | 4901
#39 (http://www.ncbi.nlm.nih.gov/pubmed) | Search ((“Patient Outcome Assessment”[Mesh] OR, “Outcome Assessment (Health Care)”[Mesh] OR, “Pragmatic Clinical Trial” [Publication Type]) OR, “Outcome and Process Assessment (Health Care)”[Mesh]) OR, “Epidemiologic Studies”[Mesh] | 2368187 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=39)
#40 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#27 AND #39) | 841 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=40)
#41 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#7 OR, #29 OR, #30 OR, #40) | 3028 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=41)
#42 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#7 OR, #29 OR, #30 OR, #40)) Filters: Humans | 3028 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=42)
#43 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#7 OR, #29 OR, #30 OR, #40) Filters: Humans; English | 2923 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=43)
#44 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Adolescent”[Mesh]) OR, “Pregnancy in Adolescence”[Mesh] | 1719223 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=41)
#45 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#43 AND #44) | 666 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=42)
#46 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#40 OR, #32) Filters: Publication date to 2011/12/31; Humans; English; Adolescent | 666

Cochrane

- Reviews=4=1 New
- DARE=1=0 New
- Cochrane Controlled Clinical Trials Registry=42=22 New

Embase=265=148 New

Total Adolescent Database=837

Appendix B Table 1 Eligibility Criteria: Intimate Partner Violence

| Include | Exclude
Populations | Studies enrolling adolescents^a^ and adults (male and female, including older and vulnerable adults) presenting for primary care services without recognized signs or symptoms of IPV or abuse^b^ For each KQ, we will search for evidence on subgroups defined by age, sex, race/ethnicity, pregnancy status, LGBTQ identification, type of abuse (e.g., physical abuse, sexual abuse), history of IPV, or presence of comorbid conditions | Studies restricted to populations seeking care for IPV or for obvious signs or symptoms of abuse
Screening | KQs 1–3: Screening tests designed to detect current or past IPV victimization or risk status for IPV victimization, including self-administered, computer-enabled, or patient self-report instruments, as well as clinician-administered screening methods; instruments must be feasible for use for screening in U.S. primary care settings (i.e., brief, easy to interpret, acceptable to patients and clinicians) | KQs 1–3: Screening tests designed to identify perpetrators of IPV
Interventions | KQs 4, 5: Services that could be offered in or referred to by primary care, including counseling, case management, home visitation, mentor or peer support, safety planning, and referral to community services | KQs 4, 5: Public awareness campaigns without specific interventions linked to screening; studies of other interventions that do not include a health service component (e.g., effectiveness of women’s shelters, unless referred by a clinician)
Comparisons | KQs 1, 3: Screened vs. nonscreened groups KQ 2: Eligible instruments must be compared with an acceptable reference standard (verified or self-reported abuse or validated screening instrument for abuse) KQs 4, 5: No treatment, usual care, attention control, or waitlist control | KQs 4, 5: Head-to-head comparisons of two active interventions
Outcomes | KQs 1, 4: Reduced exposure to IPV as measured by a validated instrument (e.g., Community Composite Scale), self-report frequency of abuse (e.g., number of physical assaults), or discontinuation of an unsafe relationship; physical morbidity caused by IPV, including acute physical trauma (e.g., fractures, dislocations), chronic medical conditions (e.g., chronic pain, brain injury), and sexual trauma; mental health morbidity caused by IPV, including acute mental morbidity (e.g., stress, nightmares) and chronic mental health conditions (e.g., posttraumatic stress disorder, anxiety, depression); sexual trauma, unintended pregnancy, and sexually transmitted infections; adverse perinatal outcomes (e.g., preterm birth, low birth weight, decreased mean gestational age); health care utilization attributed to physical or mental effects of IPV (e.g., rates of emergency department visits); quality of life and social isolation; and mortality KQ 2: Sensitivity, specificity, positive and negative predictive values, positive and negative likelihood ratios, diagnostic odds ratios, and relative risks for future abuse KQ 3: Psychosocial harms, including labeling and stigma; false-positive and false-negative results; increased abuse or other forms of retaliation; and other reported harms of screening or identification KQ 5: Any harms that result from interventions, such as increased abuse or other forms of retaliation, and emotional distress | All KQs: Screening or referral rates, attitudes about screening, plans or intentions related to screening, and other intermediate outcomes KQ 2: Theory or survey development and validation without correlation to abuse outcomes, studies that focus only on particular risk factors, or assessment of provider or participant attitudes toward the instrument
Study Designs | All KQs: Randomized, controlled trials KQ 2: Cross-sectional and cohort studies of diagnostic accuracy are also eligible KQs 3, 5: Cohort studies with a concurrent control group are also eligible | All other study designs, including case series, case-control studies, and systematic reviews^c^
Quality | Studies rated good or fair quality | Studies rated poor quality
Settings | All KQs: Primary care clinics or other settings where primary care services are offered, such as student health centers and emergency departments^d^ KQs 4, 5: Settings referable from primary care are also eligible | Nonclinically based settings or nonapplicable settings (e.g., prisons)
Country | Research conducted in the United States or in populations similar to U.S. populations with services and interventions applicable to U.S. practice (i.e., countries categorized as “Very High” on the United Nations Human Development Index, as defined by the United Nations Development Programme) | Research not relevant to the United States (i.e., countries not categorized as “Very High” on the Human Development Index)
Language | Full text published in English | Languages other than English

a Studies enrolling adolescents at any age will be included as long as the focus is on abuse from an intimate partner and not a parent or other caregiver.

b Adults and adolescents with problems directly related to abuse (e.g., physical injuries) will have evaluations outside the scope of screening.

c Relevant systematic reviews will be identified in database searches and used for hand searches to ensure the databases have captured all relevant studies.

d Results will be stratified by study setting to assess whether results for IPV screening accuracy and intervention studies differ based on whether populations were enrolled from primary care or emergency department settings.

Abbreviations: IPV=intimate partner violence; KQ=key question; LGBTQ=lesbian, gay, bisexual, transgender, and questioning; U.S.=United States; vs.=versus.

Appendix B Table 2 Eligibility Criteria: Elder Abuse and Abuse of Vulnerable Adults

| Include | Exclude
Populations | Studies enrolling older adult (age ≥60 years) and vulnerable^a^ adult (age ≥18 years) populations presenting for primary care services without recognized signs or symptoms of abuse or neglect For each KQ, we will search for evidence on subgroups defined by age, sex, race/ethnicity, pregnancy status, LGBTQ identification, type of abuse (e.g., physical abuse, sexual abuse), history of abuse, or presence of comorbid conditions | Studies restricted to populations seeking care for abuse or presenting with obvious signs or symptoms of abuse
Screening | KQs 1–3: Screening tests designed to detect current or past abuse or neglect or risk of being abused, including self-administered, computer-enabled, or patient self-report instruments, as well as clinician-administered screening methods; screening may involve input from caregivers, and instruments must be feasible for use in U.S. primary care settings (i.e., brief, easy to interpret, acceptable to patients and clinicians) | KQs 1–3: Screening to detect behavioral problems in older and vulnerable adults with specific conditions (e.g., Alzheimer’s, dementia)
Interventions | KQs 4, 5: Services that could be offered in or referred to by primary care, including counseling, case management, home visitation, and referral to community services (e.g., adult protective services) | KQs 4, 5: Public awareness campaigns without specific interventions linked to screening; studies of other interventions that do not include a health service component (e.g., effectiveness of nursing facility policies and procedures to reduce violence)
Comparisons | KQs 1, 3: Screened vs. nonscreened groups KQ 2: Eligible instruments must be compared with an acceptable reference standard (verified or self-reported abuse or validated screening instrument for abuse) KQs 4, 5: No treatment, usual care, attention control, or waitlist control | KQs 4, 5: Head-to-head comparisons of two active interventions
Outcomes | KQs 1, 4: Reduced exposure to abuse or neglect (e.g., reduced episodes of physical violence); physical morbidity associated with abuse or neglect, including physical trauma (e.g., fractures, dislocations) and chronic conditions (e.g., brain injury, physical disability); mental morbidity associated with abuse or neglect (e.g., anxiety, nightmares) and chronic mental health conditions (e.g., posttraumatic stress disorder, anxiety, depression); sexual trauma, unintended pregnancy,^b^ and sexually transmitted infections; adverse perinatal outcomes^b^ (e.g., preterm birth, low birth weight, decreased mean gestational age); health care utilization attributed to physical or mental effects of abuse (e.g., rates of emergency department visits); social isolation and quality of life; and mortality KQ 2: Sensitivity, specificity, positive and negative predictive values, positive and negative likelihood ratios, diagnostic odds ratios, and relative risks for future abuse KQ 3: Psychosocial harms, including labeling and stigma; false-positive and false-negative results; increased abuse or other forms of retaliation; and other reported harms of screening or identification KQ 5: Any harms that result from interventions, such as increased abuse or emotional distress | KQs 1, 4: Screening or referral rates, attitudes about screening, plans or intentions related to screening, and other intermediate outcomes KQ 2: Theory or survey development and validation without correlation to abuse outcomes, studies that focus only on particular risk factors, or assessment of provider or participant attitudes toward the instrument
Study Designs | All KQs: Randomized, controlled trials KQ 2: Cross-sectional and cohort studies of diagnostic accuracy are also eligible KQs 3, 5: Cohort studies with a concurrent control group are also eligible | All other study designs, including case series, case-control studies, and systematic reviews^c^
Quality | Studies rated good or fair quality | Studies rated poor quality
Settings | Primary care clinics, emergency departments,^d^ or other settings where primary care services are offered^e^ | Nonclinically based or nonapplicable settings (e.g., prisons), populations or services/interventions not applicable to U.S. practice
Country | Research conducted in the United States or in populations similar to U.S. populations with services and interventions applicable to U.S. practice (i.e., countries categorized as “Very High” on the United Nations Human Development Index, as defined by the United Nations Development Programme) | Research not relevant to the United States (i.e., countries not categorized as “Very High” on the Human Development Index)
Language | Full text published in English | Languages other than English

a “Vulnerable adult” is a person age 18 years or older whose ability to provide his or her own care or protection is impaired.

b Outcomes that are specific to pregnancy apply to vulnerable adult women of childbearing age.

c Relevant systematic reviews will be identified in database searches and used in hand searches to ensure the databases have captured all relevant studies.

d Results will be stratified by study setting to assess whether results for older/vulnerable adult abuse screening accuracy or intervention studies differ based on whether populations were enrolled from primary care or emergency department settings.

e This includes community-dwelling, assisted living settings where primary care services are delivered, and where patients/residents are able to live independently and receive care similar to a traditional primary care setting.

Abbreviation: KQ=key question; LGBTQ=lesbian, gay, bisexual, transgender, and questioning; U.S.=United States.

Appendix B Table 3 U.S. Preventive Services Task Force Quality Rating Criteria

Randomized, Controlled Trials and Cohort Studies

- Initial assembly of comparable groups
- Randomized, controlled trials (RCTs)—adequate randomization, including concealment and whether potential confounders were distributed equally among groups; cohort studies—consideration of potential confounders with either restriction or measurement for adjustment in the analysis; consideration of inception cohorts
- Maintenance of comparable groups (includes attrition, crossovers, adherence, and contamination)
- Important differential loss to followup or overall high loss to followup
- Measurements: Equal, reliable, and valid (includes masking of outcome assessment)
- Clear definition of interventions
- Important outcomes considered
- Analysis: Adjustment for potential confounders for cohort studies or intention-to-treat analysis for RCTs; for cluster RCTs, correction for correlation coefficient

Definition of Ratings Based on Above Criteria

Good: | Meets all criteria: Comparable groups are assembled initially and maintained throughout the study (followup ≥80%); reliable and valid measurement instruments are used and applied equally to the groups; interventions are spelled out clearly; important outcomes are considered; and appropriate attention is given to confounders in analysis. In addition, intention-to-treat analysis is used for RCTs.
Fair: | Studies will be graded “fair” if any or all of the following problems occur, without the important limitations noted in the “poor” category below: Generally comparable groups are assembled initially, but some question remains on whether some (although not major) differences occurred in followup; measurement instruments are acceptable (although not the best) and generally applied equally; some but not all important outcomes are considered; and some but not all potential confounders are accounted for. Intention-to-treat analysis is lacking for RCTs.
Poor: | Studies will be graded “poor” if any of the following major limitations exist: Groups assembled initially are not close to being comparable or maintained throughout the study; unreliable or invalid measurement instruments are used or not applied equally among groups (including not masking outcome assessment); and key confounders are given little or no attention. Intention-to-treat analysis is lacking for RCTs.

Diagnostic Accuracy Studies

- Screening test relevant, available for primary care, and adequately described
- Credible reference standard, performed regardless of test results
- Reference standard interpreted independently of screening test
- Indeterminate results handled in a reasonable manner
- Spectrum of patients included in study
- Sample size
- Reliable screening test

Definition of ratings based on above criteria

Good: | Evaluates relevant available screening test; uses a credible reference standard; interprets reference standard independently of screening test; assesses reliability of test; has few or handles indeterminate results in a reasonable manner; includes large number (>100) of broad-spectrum patients with and without disease
Fair: | Evaluates relevant available screening test; uses reasonable although not best standard; interprets reference standard independent of screening test; has moderate sample size (50 to 100 subjects) and a “medium” spectrum of patients.
Poor: | Has a fatal flaw, such as using inappropriate reference standard, improperly administering screening test, using biased ascertainment of reference standard; has very small sample size or very narrow selected spectrum of patients

Sources: U.S. Preventive Services Task Force, Procedure Manual, Appendix VI

https://www.uspreventiveservicestaskforce.org/Page/Name/methods-and-processes

Harris et al, 200153