# Appendix A Additional Background, Summary of Guidelines From Other Groups, and Contextual Questions

Appendix A Table 1 Categories of Intimate Partner Violence

Category^*^ | Definition
Physical violence | Intentional use of physical force with the potential for causing death, disability, injury, or harm. Includes but is not limited to scratching, pushing, shoving, throwing, grabbing, biting, choking, shaking, hair pulling, slapping, punching, hitting, burning, use of a weapon (gun, knife, or other object), and use of restraints or one’s body, size, or strength against another person. Physical violence also includes coercing other people to commit any of the above acts.
Sexual violence | Any sexual act committed or attempted by another person without freely given consent of the victim or against someone who is unable to consent or refuse, including forced or alcohol-/drug-facilitated penetration (completed or attempted) of a victim, forced or alcohol‑/drug-facilitated incidents in which the victim was made to penetrate a perpetrator or someone else, nonphysically pressured unwanted penetration, intentional sexual touching, or noncontact acts of a sexual nature. Sexual violence can also occur when a perpetrator forces or coerces a victim to engage in sexual acts with a third party.
Psychological aggression | Use of verbal and nonverbal communication with the intent to a) harm another person mentally or emotionally and/or b) exert control over another person. Includes but is not limited to making threats of physical or sexual violence, involving the use of words, gestures, or weapons to communicate the intent to cause death, disability, injury, or physical harm; humiliating, degrading, or intentionally embarrassing or diminishing the victim; using coercive control of what the victim can and cannot do; withholding information from the victim; isolating the victim from friends and family; controlling the victim’s reproductive or sexual health; and denying the victim access to money or other basic resources.
Stalking | Repeated, unwanted attention and contact that causes the victim fear or concern for her/his own safety or the safety of someone else, such as a family member or close friend.

* Categories and definitions of Intimate Partner Violence shown here are based on CDC guidance.^3^

Appendix A Table 2 Categories of Elder Abuse

Category^*^ | Definition
Physical abuse | Intentional use of physical force that results in acute or chronic illness, bodily injury, physical pain, functional impairment, distress, or death. May include but is not limited to such acts of violence as striking (with or without an object or weapon), hitting, beating, scratching, biting, choking, suffocation, pushing, shoving, shaking, slapping, kicking, stomping, pinching, and burning. In addition, inappropriate use of medications and physical restraints, pinning in place, arm twisting, hair pulling, force feeding, and physical punishment of any kind also are examples of physical abuse.
Sexual abuse or abusive sexual contact | Forced and/or unwanted sexual interaction (touching and nontouching acts) of any kind with an older adult. May include but is not limited to forced and/or unwanted completed or attempted contact between the penis and the vulva or the penis and the anus involving penetration, however slight; forced and/or unwanted contact between the mouth and the penis, vulva, or anus; forced and/or unwanted penetration of the anal or genital opening of another person by a hand, finger, or other object; forced and/or unwanted intentional touching, either directly or through the clothing, of the genitalia, anus, groin, breast, inner thigh, or buttocks; unwarranted, intrusive, and/or painful procedures in caring for genitals or rectal area; or forced and/or unwanted noncontact acts of a sexual nature. Also any of the above committed against an incapacitated person who is not competent to give informed approval, indicating a freely given agreement to have sexual intercourse or sexual contact.
Emotional or psychological abuse | Verbal or nonverbal behavior resulting in the infliction of anguish, mental pain, fear, or distress, perpetrated by a caregiver or other person who stands in a trust relationship to the elder. May have immediate effects or delayed effects that are short or long term in nature that may or may not be readily apparent to or acknowledged by the victim. May include any of the following and vary according to cultural norms: humiliation/disrespect, threats, harassment, or isolation/coercive control.
Neglect | Failure by a caregiver or other person in a trust relationship to protect an elder from harm or the failure to meet needs for essential medical care, nutrition, hydration, hygiene, clothing, or basic activities of daily living or shelter, which results in a serious risk of compromised health and/or safety, relative to age, health status, and cultural norms.
Financial abuse or exploitation | The illegal, unauthorized, or improper use of an older individual’s resources by a caregiver or other person in a trusting relationship, for the benefit of someone other than the older individual. Includes but is not limited to depriving an older individual of rightful access to information about or use of personal benefits, resources, belongings, or assets.

* Categories and definitions of Intimate Elder abuse shown here are based on CDC guidance.^3^

Appendix A Table 3 Current Recommendations From Other Organizations

Organization, Year | IPV Screening Recommendation
AAFP, 2016^102^ | Clinicians should screen all women of childbearing age for IPV, and women who screen positive for IPV should receive intervention services.
AAN, 2012^103^ | Physicians should routinely screen all patients for past and ongoing violence, fully integrating the questions into the medical history.
AAP, 2010^104^ (reaffirmed in 2014)^105^ | Pediatricians should remain alert to the signs and symptoms of exposure to IPV in caregivers and children and should consider attempts to identify evidence of IPV either by targeted screening of high-risk families or universal screening.
ACOG, 2012^106,^ ^107^ | Pregnant women: Physicians should screen all women for IPV at periodic intervals, including during obstetric care (at the first prenatal visit, at least once per trimester, and at the postpartum checkup), offer ongoing support, and review available prevention and referral options. Adolescents: All adolescents should be asked annually about a history of experiencing or witnessing abuse, including emotional, physical, and sexual abuse and assault by family members, peers, romantic partners, and others. Practitioners should be aware of State law reporting requirements and clearly disclose those laws to the patient prior to asking questions. Screening may take place through either direct interviewing or written questionnaire.
AWHONN, 2015^108^ | Opposes laws and policies that require nurses to report the results of screening for IPV to law enforcement or other regulatory agencies without the consent of the woman who experiences IPV. Women should be universally screened for IPV in private, safe settings where health care is provided.
IOM Committee on Preventive Services for Women, 2011^109^ | Recommends for consideration as a preventive service for women: screening and counseling for interpersonal and domestic violence. Screening and counseling involve elicitation of information from women and adolescents about current and past violence and abuse in a culturally sensitive and supportive manner to address current health concerns about safety and other current or future health problems.
CTFPHC, 2013^110^ | Available evidence does not justify routinely screening Canadian residents for IPV.
WHO, 2013^111^ | “Universal screening” or “routine enquiry” (i.e., asking women in all health care encounters) should not be implemented.

Abbreviations: AAN=American Academy of Neurology; AAFP=American Academy of Family Physicians; ACOG=American Congress of Obstetricians and Gynecologists; AAP=American Academy of Pediatrics; AWHONN=Association of Women’s Health, Obstetric and Neonatal Nurses; CTFPHC=Canadian Task Force on Preventive Health Care; IOM=Institute of Medicine; IPV=intimate partner violence; WHO=World Health Organization.

Appendix A Table 4 Current Recommendations from Other Organizations: Elderly and Vulnerable Adults

Organization, Year | Screening Recommendation
AAFP, 2014^112^ | Routine screening of older and vulnerable adults is not explicitly recommended by the AAFP. However, the AAFP states that validated screening instruments are available, and preventative health visits may function as a reasonable occasion for screening at the discretion of family physicians.
AAN, 2012^103^ | Physicians should routinely screen all patients for past and ongoing violence, fully integrating the questions into the medical history.
ACOG, 2013^113^ | Recommends screening all patients older than 60 years for signs and symptoms of elder abuse; advocates for a safe environment for all aging women to receive high-quality care from health care providers; recommends following individual State guidelines for reporting elder abuse to APS; providing education regarding elder abuse to patients, family, caregivers, and health care providers; and encourages research in elder abuse and mistreatment.
CTFPHC, 2013^110^ | Available evidence does not justify routine screening of Canadian residents for abuse of elderly and vulnerable persons.
HIGN, 2012^114^ | Recommends screening for elder abuse and neglect.
AARP, 2009^115^ | Recommends screening home care workers to protect elders and vulnerable adults from harm.

Abbreviations: AAFP=American Academy of Family Physicians; AAN=American Academy of Neurology; AARP=American Association of Retired Persons; ACOG=American Congress of Obstetricians and Gynecologists; APS=Adult Protective Services; CTFPHC=Canadian Task Force on Preventive Health Care; HIGN=Hartford Institute for Geriatric Nursing.

## Contextual Questions

### CQ 1 What factors limit the applicability of IPV screening and treatment studies conducted in emergency department settings to primary care settings (e.g., differences in patient populations or characteristics of the clinical settings)?

To address this question, we first assessed the applicability of IPV studies that met inclusion criteria for our review. Overall, nine included studies were set in an emergency department (one KQ 1 study, six KQ 2 studies, and one KQ 4 study). We also looked for studies that did not meet our inclusion criteria (e.g., wrong outcome or no comparison group) but that commented on factors that limited the applicability of IPV screening and treatment studies conducted in emergency departments. Our assessment of applicability focused on differences in populations, interventions offered, and care delivery likely to be different across outpatient primary care and emergency department settings.

Across the nine included studies conducted in an emergency department, the prevalence of IPV ranged from 14 to 40 percent; prevalence was lowest in a KQ 1 trial of screening (18%) and highest in KQ 2 studies enrolling participants from emergency departments (34 to 40%).

Twenty additional studies were identified that commented on factors that may limit the applicability of IPV screening and treatment studies conducted in emergency department settings to primary care. Most are cross-sectional or cohort studies focused on assessing IPV prevalence or acceptability of screening to patients and emergency department staff. Sixteen of these described clinical and demographic characteristics of patients presenting to the emergency department who were identified as having IPV. Patients who seek treatment in an emergency department may have higher IPV prevalence and more severe injury patterns than patients who present to primary care, although IPV prevalence varied between studies (from 0.4 to 38.9%).^1–15^ Studies with the lowest reports of IPV prevalence were conducted outside of the United States. The majority of emergency department–based studies (10 studies) reported IPV prevalence greater than 10 percent, and five studies described IPV prevalence greater than 20 percent. In addition, unselected patients presenting to the emergency department may exhibit more overt signs and symptoms of IPV compared with patients presenting to primary care settings. For example, one cohort study (N=528) assessing an emergency department IPV screening program reported that 74 percent of patients who screened positive for IPV had a chief complaint of assault or trauma, while only 20 percent of IPV-positive patients presented with a medical chief complaint.^3^ Additional studies set in an emergency department describe the presence of blunt injury in 70 percent of IPV-positive patients, including injury to the head or face, presence of multiple injuries, and presence of contusions.^2,6,9^

Beyond clinical presentation, patients treated in the emergency room may have decreased access to traditional health care services. Emergency department–based IPV screening studies report 33.3 to 43.1 percent of IPV-positive patients receive Medicaid, while 18.6 to 37.0 percent are uninsured.^3,5,13,15^ One cross-sectional study (N=2,465) compared demographic characteristics of patients who screened positive for IPV in an emergency department versus primary care setting. A greater percentage of emergency department patients were unemployed, uneducated (less than high school education), African American, Hispanic, young (<29 years), and unmarried compared with IPV-positive patients screened in primary care.^7^ Data from the 2002 National Survey on Drug Use and Health (N=536) supports this finding of greater emergency department utilization among Hispanics experiencing IPV compared with non-Hispanic whites experiencing IPV.^16^ Emergency department–treated patients also have high percentages of coexisting mental health conditions including depression, anxiety, and drug or alcohol use.^2,6,12,15^

Thirteen studies reported differences in emergency department and primary care clinical settings that may pose unique challenges to IPV screening in the emergency department. Most described poor engagement in emergency department screening programs by staff; prevalence of IPV screening ranged from 8.8 to 34.0 percent.^3–5,10,11,17^ One narrative review examined 38 studies and categorized barriers to IPV screening in emergency departments as patient, provider, or systems issues.^1^ Patient-driven factors include acute complaint or injury, severe pain, decreased level of consciousness, psychiatric presentation, and intoxication.^5,7,13,18^ Provider-based factors include lack of time, lack of knowledge and training, lack of motivation, feelings of discomfort, feelings of inability to effect change, and provider beliefs about the emergency room’s purpose and the provider’s role in screening.^1,4,10,17,19–21^ Systems barriers include lack of privacy for screening, unclear or inconsistent procedures for referral, inability to screen during night shift due to staff shortages and absence of social workers, patient arrival by ambulance, and patient absence from the emergency department for tests or imaging.^1,4,5,10,13,17,19,21^

### CQ 2 What factors limit the applicability of older/vulnerable adult abuse and neglect screening and treatment studies conducted in emergency room settings to primary care settings (e.g., differences in patient populations or characteristics of the clinical settings)?

We found only one study addressing elder abuse that met inclusion criteria (and no studies enrolling vulnerable adults). The study assessed the accuracy of the Hwalek–Sengstock elder abuse screening test among older adults presenting for routine care at an academic dental clinic.^98^ We found no studies comparing primary care with emergency department settings, nor any study set solely in the emergency department.

We did find observational studies that suggest differences between primary care and the emergency departments in the prevalence of abuse, the types of abuse, the types of older adults who are abused, and the types of abusers. Though likely underreported in all settings, the prevalence of abuse in primary care could be as high as 5 to 9 percent,^14,^ ^15^ while rates in emergency departments appear to be lower, ranging from 0.013 percent to 0.3 percent.^116,^ ^117^ The type of abuse detected in the emergency department may reflect higher rates of trauma than primary care, where emotional abuse may be more prevalent.^14,^ ^15,^ ^40,^ ^118^ The types of abuse and potential perpetrators may also differ. Victims of elder abuse in the emergency department may be more likely to suffer from dementia and be less able to access primary care.^119^ Patients in the primary care setting may be more likely to be “young old” adults.^14,^ ^41^ Perpetrators of elder abuse and neglect are often family members in both settings. Approximately 11 percent of the substantiated reports of abuse of community-dwelling older adults with a known perpetrator involved a spouse or intimate partner.^16^ The most common perpetrators of elder abuse are adult children (33% of cases) and other family members (20% of cases).^16^ Elder abuse in emergency departments appears to be commonly associated with family,^116^ though other types of caregivers may be more prevalent than in the community, due to the rates of institutional care among older adults seen in emergency departments.