# References

1 World Health Organization. Obesity: preventing and managing the global epidemic. Report of a WHO consultation. World Health Organization technical report series. 2000;894:i–xii, 1–253. PMID: 11234459.11234459
2 Clinical Guidelines on the Identification, Evaluation, and Treatment of Overweight and Obesity in Adults-The Evidence Report. National Institutes of Health. Obes Res. 1998;6: Suppl 2:51S–209S. PMID: 9813653. 10.1002/j.1550-8528.1998.tb00690.x 9813653
3 Jensen MD, Ryan DH, Apovian CM, . 2013 AHA/ACC/TOS guideline for the management of overweight and obesity in adults: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines and The Obesity Society. Circulation. 2014;129(25 Suppl 2):S102–38. PMID: 24222017. 10.1161/01.cir.0000437739.71477.ee 24222017
4 Heymsfield SB, Peterson CM, Thomas DM, . Why are there race/ethnic differences in adult body mass index-adiposity relationships? A quantitative critical review. Obes Rev. 2016;17(3):262–75. PMID: 26663309. 10.1111/obr.12358 26663309
5 Deurenberg P, Yap M, van Staveren WA. Body mass index and percent body fat: a meta analysis among different ethnic groups. Int J Obes Relat Metab Disord. 1998;22(12):1164–71. PMID: 9877251.9877251
6 Abell JE, Egan BM, Wilson PW, . Age and race impact the association between BMI and CVD mortality in women. Public health reports. 2007;122(4):507–12. PMID: 17639654. 10.1177/003335490712200412 17639654
7 Abell JE, Egan BM, Wilson PW, . Differences in cardiovascular disease mortality associated with body mass between Black and White persons. Am J Public Health. 2008;98(1):63–6. PMID: 18048799. 10.2105/AJPH.2006.093781 18048799
8 Chen Y, Henson S, Jackson AB, . Obesity intervention in persons with spinal cord injury. Spinal Cord. 2006;44(2):82–91. PMID: 16103891. 10.1038/sj.sc.3101818 16103891
9 Low S, Chin MC, Ma S, . Rationale for redefining obesity in Asians. Annals of the Academy of Medicine, Singapore. 2009;38(1):66–9. PMID: 19221673.19221673
10 Maskarinec G, Grandinetti A, Matsuura G, . Diabetes prevalence and body mass index differ by ethnicity: the Multiethnic Cohort. Ethn Dis. 2009;19(1):49–55. PMID: 19341163.19341163
11 Ni Mhurchu C, Rodgers A, Pan WH, . Body mass index and cardiovascular disease in the Asia-Pacific Region: an overview of 33 cohorts involving 310 000 participants. Int J Epidemiol. 2004;33(4):751–8. PMID: 15105409. 10.1093/ije/dyh163 15105409
12 Obesity in Asia Collaboration, Huxley R, Barzi F, . Waist circumference thresholds provide an accurate and widely applicable method for the discrimination of diabetes. Diabetes Care. 2007;30(12):3116–8. PMID: 17804678. 10.2337/dc07-1455 17804678
13 Razak F, Anand S, Vuksan V, . Ethnic differences in the relationships between obesity and glucose-metabolic abnormalities: a cross-sectional population-based study. Int J Obes (Lond). 2005;29(6):656–67. PMID: 15782225. 10.1038/sj.ijo.0802937 15782225
14 Razak F, Anand SS, Shannon H, . Defining obesity cut points in a multiethnic population. Circulation. 2007;115(16):2111–8. PMID: 17420343. 10.1161/CIRCULATIONAHA.106.635011 17420343
15 Sanchez-Castillo CP, Velazquez-Monroy O, Berber A, . Anthropometric cutoff points for predicting chronic diseases in the Mexican National Health Survey 2000. Obes Res. 2003;11(3):442–51. PMID: 12634443. 10.1038/oby.2003.60 12634443
16 Stevens J, Juhaeri, Cai J, . The effect of decision rules on the choice of a body mass index cutoff for obesity: examples from African American and white women. Am J Clin Nutr. 2002;75(6):986–92. PMID: 12036803.12036803
17 Stommel M, Schoenborn CA. Variations in BMI and prevalence of health risks in diverse racial and ethnic populations. Obesity. 2010;18(9):1821–6. PMID: 20075855. 10.1038/oby.2009.472 20075855
18 WHO Expert Consultation. Appropriate body-mass index for Asian populations and its implications for policy and intervention strategies. Lancet. 2004;363(9403):157–63. PMID: 14726171. 10.1016/S0140-6736(03)15268-3 14726171
19 Wen CP, David Cheng TY, Tsai SP, . Are Asians at greater mortality risks for being overweight than Caucasians? Redefining obesity for Asians. Public Health Nutr. 2009;12(4):497–506. PMID: 18547457. 10.1017/S1368980008002802 18547457
20 Jackson CL, Wang NY, Yeh HC, . Body-mass index and mortality risk in U.S. blacks compared to whites. Obesity (Silver Spring). 2014;22(3):842–51. PMID: 23554375. 10.1002/oby.20471 23554375
21 Chiu M, Austin PC, Manuel DG, . Deriving ethnic-specific BMI cutoff points for assessing diabetes risk. Diabetes Care. 2011;34(8):1741–8. PMID: 21680722. 10.2337/dc10-2300 21680722
22 Hsu WC, Araneta MR, Kanaya AM, . BMI cut points to identify at-risk Asian Americans for type 2 diabetes screening. Diabetes Care. 2015;38(1):150–8. PMID: 25538311. 10.2337/dc14-2391 25538311
23 National Institute for Health and Care Excellence. Assessing body mass index and waist circumference thresholds for intervening to prevent ill health and premature death among adults from black, Asian and other minority ethnic groups in the UK. 2013. PMID: none.
24 Gu D, He J, Duan X, . Body weight and mortality among men and women in China. JAMA. 2006;295(7):776–83. PMID: 16478900. 10.1001/jama.295.7.776 16478900
25 Jee SH, Sull JW, Park J, . Body-mass index and mortality in Korean men and women. N Engl J Med. 2006;355(8):779–87. PMID: 16926276. 10.1056/NEJMoa054017 16926276
26 Matsuo T, Sairenchi T, Iso H, . Age- and gender-specific BMI in terms of the lowest mortality in Japanese general population. Obesity (Silver Spring). 2008;16(10):2348–55. PMID: 18719651. 10.1038/oby.2008.342 18719651
27 Tsugane S, Sasaki S, Tsubono Y. Under- and overweight impact on mortality among middle-aged Japanese men and women: a 10-y follow-up of JPHC study cohort I. Int J Obes Relat Metab Disord. 2002;26(4):529–37. PMID: 12075580.12075580
28 Katzmarzyk PT, Mire E, Bray GA, . Anthropometric markers of obesity and mortality in white and African American adults: the pennington center longitudinal study. Obesity. 2013;21(5):1070–5. PMID: 23784912. 10.1002/oby.20151 23784912
29 Calle EE, Thun MJ, Petrelli JM, . Body-mass index and mortality in a prospective cohort of U.S. adults. N Engl J Med. 1999;341(15):1097–105. PMID: 10511607. 10.1056/NEJM199910073411501 10511607
30 Stevens J. Obesity and mortality in African-Americans. Nutr Rev. 2000;58(11):346–53. PMID: 11140906.11140906
31 Rillamas-Sun E, LaCroix AZ, Waring ME, . Obesity and late-age survival without major disease or disability in older women. JAMA Intern Med. 2014;174(1):98–106. PMID: 24217806 10.1001/jamainternmed.2013.12051 24217806
32 Ogden CL, Carroll MD, Fryar CD, . Prevalence of Obesity Among Adults and Youth: United States, 2011-2014. NCHS data brief. 2015(219):1–8. PMID: 26633046.26633046
33 Ogden CL, Carroll MD, Kit BK, . Prevalence of childhood and adult obesity in the United States, 2011-2012. JAMA. 2014;311(8):806–14. PMID: 24570244. 10.1001/jama.2014.732 24570244
34 Ford ES, Maynard LM, Li C. Trends in mean waist circumference and abdominal obesity among US adults, 1999-2012. JAMA. 2014;312(11):1151–3. PMID: 25226482. 10.1001/jama.2014.8362 25226482
35 Flegal KM, Kruszon-Moran D, Carroll MD, . Trends in Obesity Among Adults in the United States, 2005 to 2014. JAMA. 2016;315(21):2284–91. PMID: 27272580. 10.1001/jama.2016.6458 27272580
36 National Center for Health Statistics. Health United States Report 2016: With Chartbook on Long-term Trends in Health. https://www.cdc.gov/nchs/data/hus/hus16.pdf. Accessed May 23, 2017.
37 Echeverria SE, Mustafa M, Pentakota SR, . Social and clinically-relevant cardiovascular risk factors in Asian Americans adults: NHANES 2011-2014. Prev Med. 2017;99:222–7. PMID: 28219784. 10.1016/j.ypmed.2017.02.016 28219784
38 Bogers RP, Bemelmans WJ, Hoogenveen RT, . Association of overweight with increased risk of coronary heart disease partly independent of blood pressure and cholesterol levels: a meta-analysis of 21 cohort studies including more than 300 000 persons. Arch Intern Med. 2007;167(16):1720–8. PMID: 17846390. 10.1001/archinte.167.16.1720 17846390
39 Colditz GA, Willett WC, Rotnitzky A, . Weight gain as a risk factor for clinical diabetes mellitus in women. Ann Intern Med. 1995;122(7):481–6. PMID: 7872581. 10.7326/0003-4819-122-7-199504010-00001 7872581
40 Willett WC, Manson JE, Stampfer MJ, . Weight, weight change, and coronary heart disease in women. Risk within the ‘normal’ weight range. JAMA. 1995;273(6):461–5. PMID: 7654270. 10.1001/jama.1995.03520300035033 7654270
41 Kenchaiah S, Evans JC, Levy D, . Obesity and the risk of heart failure. N Engl J Med. 2002;347(5):305–13. PMID: 12151467. 10.1056/NEJMoa020245 12151467
42 Guh DP, Zhang W, Bansback N, . The incidence of co-morbidities related to obesity and overweight: a systematic review and meta-analysis. BMC Public Health. 2009;9:88. PMID: 19320986. 10.1186/1471-2458-9-88 19320986
43 Dai Z, Xu YC, Niu L. Obesity and colorectal cancer risk: a meta-analysis of cohort studies. World J Gastroenterol. 2007;13(31):4199–206. PMID: 17696248. 10.3748/wjg.v13.i31.4199 17696248
44 Harriss DJ, Atkinson G, George K, . Lifestyle factors and colorectal cancer risk (1): systematic review and meta-analysis of associations with body mass index. Colorectal Dis. 2009;11(6):547–63. PMID: 19207714. 10.1111/j.1463-1318.2009.01766.x 19207714
45 Renehan AG, Tyson M, Egger M, . Body-mass index and incidence of cancer: a systematic review and meta-analysis of prospective observational studies. Lancet. 2008;371(9612):569–78. PMID: 18280327. 10.1016/S0140-6736(08)60269-X 18280327
46 Bhaskaran K, Douglas I, Forbes H, . Body-mass index and risk of 22 specific cancers: a population-based cohort study of 5.24 million UK adults. Lancet. 2014;384(9945):755–65. PMID: 25129328. 10.1016/S0140-6736(14)60892-8 25129328
47 Kyrgiou M, Kalliala I, Markozannes G, . Adiposity and cancer at major anatomical sites: umbrella review of the literature. BMJ. 2017;356(j477). PMID: 28246088. 10.1136/bmj.j477 28246088
48 Strazzullo P, D’Elia L, Cairella G, . Excess body weight and incidence of stroke: meta-analysis of prospective studies with 2 million participants. Stroke; a journal of cerebral circulation. 2010;41(5):e418–26. PMID: 20299666. 10.1161/STROKEAHA.109.576967 20299666
49 Zhou M, Offer A, Yang G, . Body mass index, blood pressure, and mortality from stroke: a nationally representative prospective study of 212,000 Chinese men. Stroke; a journal of cerebral circulation. 2008;39(3):753–9. PMID: 18239175. 10.1161/STROKEAHA.107.495374 18239175
50 Frost L, Hune LJ, Vestergaard P. Overweight and obesity as risk factors for atrial fibrillation or flutter: the Danish Diet, Cancer, and Health Study. Am J Med. 2005;118(5):489–95. PMID: 15866251. 10.1016/j.amjmed.2005.01.031 15866251
51 Wang TJ, Parise H, Levy D, . Obesity and the risk of new-onset atrial fibrillation. JAMA. 2004;292(20):2471–7. PMID: 15562125. 10.1001/jama.292.20.2471 15562125
52 Ageno W, Becattini C, Brighton T, . Cardiovascular risk factors and venous thromboembolism: a meta-analysis. Circulation. 2008;117(1):93–102. PMID: 18086925. 10.1161/CIRCULATIONAHA.107.709204 18086925
53 Stampfer MJ, Maclure KM, Colditz GA, . Risk of symptomatic gallstones in women with severe obesity. Am J Clin Nutr. 1992;55(3):652–8. PMID: 1550039.1550039
54 Willett WC, Dietz WH, Colditz GA. Guidelines for healthy weight. N Engl J Med. 1999;341(6):427–34. PMID: 10432328. 10.1056/NEJM199908053410607 10432328
55 Park M, Song DY, Je Y, . Body mass index and biliary tract disease: a systematic review and meta-analysis of prospective studies. Prev Med. 2014;65:13–22. PMID: 24721739. 10.1016/j.ypmed.2014.03.027 24721739
56 Pandolfino JE, El-Serag HB, Zhang Q, . Obesity: a challenge to esophagogastric junction integrity. Gastroenterology. 2006;130(3):639–49. PMID: 16530504. 10.1053/j.gastro.2005.12.016 16530504
57 Ferris M, Hogan SL, Chin H, . Obesity, albuminuria, and urinalysis findings in US young adults from the Add Health Wave III study. Clinical journal of the American Society of Nephrology: CJASN. 2007;2(6):1207–14. PMID: 17942783. 10.2215/CJN.00540107 17942783
58 Hsu CY, McCulloch CE, Iribarren C, . Body mass index and risk for end-stage renal disease. Ann Intern Med. 2006;144(1):21–8. PMID: 16389251. 10.7326/0003-4819-144-1-200601030-00006 16389251
59 Young T, Skatrud J, Peppard PE. Risk factors for obstructive sleep apnea in adults. JAMA. 2004;291(16):2013–6. PMID: 15113821. 10.1001/jama.291.16.2013 15113821
60 Hassing LB, Dahl AK, Thorvaldsson V, . Overweight in midlife and risk of dementia: a 40-year follow-up study. Int J Obes (Lond). 2009;33(8):893–8. PMID: 19506566. 10.1038/ijo.2009.104 19506566
61 Loef M, Walach H. Midlife obesity and dementia: meta-analysis and adjusted forecast of dementia prevalence in the United States and China. Obesity (Silver Spring). 2013;21(1):E51–5. PMID: 23401370. 10.1002/oby.20037 23401370
62 Hart DJ, Spector TD. The relationship of obesity, fat distribution and osteoarthritis in women in the general population: the Chingford Study. The Journal of rheumatology. 1993;20(2):331–5. PMID: 8474072.8474072
63 Cicuttini FM, Baker JR, Spector TD. The association of obesity with osteoarthritis of the hand and knee in women: a twin study. The Journal of rheumatology. 1996;23(7):1221–6. PMID: 8823696.8823696
64 Chen H, Guo X. Obesity and functional disability in elderly Americans. J Am Geriatr Soc. 2008;56(4):689–94. PMID: 18266843. 10.1111/j.1532-5415.2007.01624.x 18266843
65 Jia H, Lubetkin EI. The impact of obesity on health-related quality-of-life in the general adult US population. J Public Health (Oxf). 2005;27(2):156–64. PMID: 15820993. 10.1093/pubmed/fdi025 15820993
66 Fine JT, Colditz GA, Coakley EH, . A prospective study of weight change and health-related quality of life in women. JAMA. 1999;282(22):2136–42. PMID: 10591335. 10.1001/jama.282.22.2136 10591335
67 Luppino FS, de Wit LM, Bouvy PF, . Overweight, obesity, and depression: a systematic review and meta-analysis of longitudinal studies. Archives of general psychiatry. 2010;67(3):220–9. PMID: 20194822. 10.1001/archgenpsychiatry.2010.2 20194822
68 Bertakis KD, Azari R. Obesity and the use of health care services. Obes Res. 2005;13(2):372–9. PMID: 15800296. 10.1038/oby.2005.49 15800296
69 Quesenberry CP, Jr., Caan B, Jacobson A. Obesity, health services use, and health care costs among members of a health maintenance organization. Arch Intern Med. 1998;158(5):466–72. PMID: 9508224. 10.1001/archinte.158.5.466 9508224
70 Flegal K, Kit B, Orpana H, . Association of all-cause mortality with overweight and obesity using standard body mass index categories: a systematic review and meta-analysis. JAMA. 2013;309(1):71–82. PMID: 23280227 10.1001/jama.2012.113905 23280227
71 Borrell LN, Samuel L. Body mass index categories and mortality risk in US adults: the effect of overweight and obesity on advancing death. Am J Public Health. 2014;104(3):512–9. PMID: 24432921. 10.2105/AJPH.2013.301597 24432921
72 Dobbins M, Decorby K, Choi BC. The Association between Obesity and Cancer Risk: A Meta-Analysis of Observational Studies from 1985 to 2011. ISRN Preventive Med. 2013;2013:680536. PMID: 24977095. 10.5402/2013/680536 24977095
73 Prospective Studies Collaboration, Whitlock G, Lewington S, . Body-mass index and cause-specific mortality in 900 000 adults: collaborative analyses of 57 prospective studies. Lancet. 2009;373(9669):1083–96. PMID: 19299006. 10.1016/S0140-6736(09)60318-4 19299006
74 Flegal KM, Ioannidis JPA. A meta-analysis but not a systematic review: an evaluation of the Global BMI Mortality Collaboration. J Clin Epidemiol. 2017. PMID: 28435099. 10.1016/j.jclinepi.2017.04.007 28435099
75 Adams KF, Schatzkin A, Harris TB, . Overweight, obesity, and mortality in a large prospective cohort of persons 50 to 71 years old. N Engl J Med. 2006;355(8):763–78. PMID: 16926275. 10.1056/NEJMoa055643 16926275
76 Danaei G, Ding EL, Mozaffarian D, . The preventable causes of death in the United States: comparative risk assessment of dietary, lifestyle, and metabolic risk factors. PLoS medicine. 2009;6(4):e1000058. PMID: 19399161. 10.1371/journal.pmed.1000058 19399161
77 Peeters A, Barendregt JJ, Willekens F, . Obesity in adulthood and its consequences for life expectancy: a life-table analysis. Ann Intern Med. 2003;138(1):24–32. PMID: 12513041. 10.7326/0003-4819-138-1-200301070-00008 12513041
78 Berrington de Gonzalez A, Hartge P, Cerhan JR, . Body-mass index and mortality among 1.46 million white adults. N Engl J Med. 2010;363(23):2211–9. PMID: 21121834. 10.1056/NEJMoa1000367 21121834
79 Global BMI Mortality Collaboration. Body-mass index and all-cause mortality: individual-participant-data meta-analysis of 239 prospective studies in four continents. Lancet. 2016;388(10046):776–86. PMID: 27423262. 10.1016/S0140-6736(16)30175-1 27423262
80 Yu E, Levy SH, Manson JE, . Weight History and All-Cause and Cause-Specific Mortality in Three Prospective Cohort Studies. Ann Intern Med. 2017. PMID: None. 10.7326/M16-1390
81 Flegal KM, Williamson DF, Pamuk ER, . Estimating deaths attributable to obesity in the United States. Am J Public Health. 2004;94(9):1486–9. PMID: 15333299.15333299
82 Lenz M, Richter T, Muhlhauser I. The morbidity and mortality associated with overweight and obesity in adulthood: a systematic review. Dtsch Arztebl Int. 2009;106(40):641–8. PMID: 19890430. 10.3238/arztebl.2009.0641 19890430
83 Flanders WD, Augestad LB. Adjusting for reverse causality in the relationship between obesity and mortality. Int J Obes (Lond). 2008;32: Suppl 3:S42–6. PMID: 18695652. 10.1038/ijo.2008.84 18695652
84 Lawlor DA, Hart CL, Hole DJ, . Reverse causality and confounding and the associations of overweight and obesity with mortality. Obesity (Silver Spring). 2006;14(12):2294–304. PMID: 17189558. 10.1038/oby.2006.269 17189558
85 Chang SH, Beason TS, Hunleth JM, . A systematic review of body fat distribution and mortality in older people. Maturitas. 2012;72(3):175–91. PMID: 22595204. 10.1016/j.maturitas.2012.04.004 22595204
86 Donini LM, Savina C, Gennaro E, . A systematic review of the literature concerning the relationship between obesity and mortality in the elderly. J Nutr Health Aging. 2012;16(1):89–98. PMID: 22238007.22238007
87 Janssen I, Mark AE. Elevated body mass index and mortality risk in the elderly. Obes Rev. 2007;8(1):41–59. PMID: 17212795. 10.1111/j.1467-789X.2006.00248.x 17212795
88 Oreopoulos A, Kalantar-Zadeh K, Sharma AM, . The obesity paradox in the elderly: potential mechanisms and clinical implications. Clinics in geriatric medicine. 2009;25(4):643–59, viii. PMID: 19944265. 10.1016/j.cger.2009.07.005 19944265
89 Winter JE, MacInnis RJ, Wattanapenpaiboon N, . BMI and all-cause mortality in older adults: a meta-analysis. Am J Clin Nutr. 2014;99(4):875–90. PMID: 24452240. 10.3945/ajcn.113.068122 24452240
90 Al Snih S, Ottenbacher KJ, Markides KS, . The effect of obesity on disability vs mortality in older Americans. Arch Intern Med. 2007;167(8):774–80. PMID: 17452539. 10.1001/archinte.167.8.774 17452539
91 Jensen GL, Friedmann JM. Obesity is associated with functional decline in community-dwelling rural older persons. J Am Geriatr Soc. 2002;50(5):918–23. PMID: 12028181. 10.1046/j.1532-5415.2002.50220.x 12028181
92 Zoico E, Di Francesco V, Guralnik JM, . Physical disability and muscular strength in relation to obesity and different body composition indexes in a sample of healthy elderly women. Int J Obes Relat Metab Disord. 2004;28(2):234–41. PMID: 14708033. 10.1038/sj.ijo.0802552 14708033
93 Kramer C, Zinman B, Retnakaran R. Are metabolically healthy overweight and obesity benign conditions?: A systematic review and meta-analysis. Ann Intern Med. 2013;159(11):758–69. PMID: 24297192 10.7326/0003-4819-159-11-201312030-00008 24297192
94 Barry V, Baruth M, Beets M, . Fitness vs. fatness on all-cause mortality: a meta-analysis. Proj Cardiovasc Dis. 2014;56(4):382–90. PMID: 24438729. 10.1016/j.pcad.2013.09.002 24438729
95 Stevens J, Cai J, Evenson K, . Fitness and fatness as predictors of mortality from all causes and from cardiovascular disease in men and women in the lipid research clinics study. Am J Epidemiol. 2002;156(9):832–41. PMID: 12397001.12397001
96 Hu F, Willett W, Li T, . Adiposity as compared with physical activity in predicting mortality among women. N Engl J Med. 2004;351(26):2694–703. PMID: 15616204. 10.1056/NEJMoa042135 15616204
97 Arem H, Moore SC, Patel A, . Leisure time physical activity and mortality: a detailed pooled analysis of the dose-response relationship. JAMA Intern Med. 2015;175(6):959–67. PMID: 25844730. 10.1001/jamainternmed.2015.0533 25844730
98 Puhl RM, Quinn DM, Weisz BM, . The Role of Stigma in Weight Loss Maintenance Among U.S. Adults. Ann Behav Med. 2017. 10.1007/s12160-017-9898-9
99 Kruseman M, Schmutz N, Carrard I. Long-Term Weight Maintenance Strategies Are Experienced as a Burden by Persons Who Have Lost Weight Compared to Persons with a lifetime Normal, Stable Weight. Obes Facts. 2017;10(4):373–85. PMID: 28810238. 10.1159/000478096 28810238
100 Vieira PN, Silva MN, Mata J, . Correlates of health-related quality of life, psychological well-being, and eating self-regulation after successful weight loss maintenance. J Behav Med. 2013;36(6):601–10. PMID: 23015283. 10.1007/s10865-012-9454-9 23015283
101 Feller S, Muller A, Mayr A, . What distinguishes weight loss maintainers of the German Weight Control Registry from the general population? Obesity (Silver Spring). 2015;23(5):1112–8. PMID: 25864871. 10.1002/oby.21054 25864871
102 Qi L, Cho YA. Gene-environment interaction and obesity. Nutr Rev. 2008;66(12):684–94. PMID: 19019037. 10.1111/j.1753-4887.2008.00128.x 19019037
103 Bouchard C, Tremblay A, Despres JP, . The response to long-term overfeeding in identical twins. N Engl J Med. 1990;322(21):1477–82. PMID: 2336074. 10.1056/NEJM199005243222101 2336074
104 Mozaffarian D, Hao T, Rimm EB, . Changes in diet and lifestyle and long-term weight gain in women and men. New England Journal of Medicine. 2011;364(25):2392–404. PMID: 21696306. 10.1056/NEJMoa1014296 21696306
105 Swinburn BA, Sacks G, Hall KD, . The global obesity pandemic: shaped by global drivers and local environments. Lancet. 2011;378(9793):804–14. PMID: 21872749. 10.1016/S0140-6736(11)60813-1 21872749
106 Malik VS, Pan A, Willett WC, . Sugar-sweetened beverages and weight gain in children and adults: a systematic review and meta-analysis. Am J Clin Nutr. 2013;98(4):1084–102. PMID: 23966427. 10.3945/ajcn.113.058362 23966427
107 Williamson DF, Madans J, Anda RF, . Recreational physical activity and ten-year weight change in a US national cohort. Int J Obes Relat Metab Disord. 1993;17(5):279–86. PMID: 8389337.8389337
108 Hu FB, Li TY, Colditz GA, . Television watching and other sedentary behaviors in relation to risk of obesity and type 2 diabetes mellitus in women. JAMA. 2003;289(14):1785–91. PMID: 12684356. 10.1001/jama.289.14.1785 12684356
109 Pereira MA, Kartashov AI, Ebbeling CB, . Fast-food habits, weight gain, and insulin resistance (the CARDIA study): 15-year prospective analysis. Lancet. 2005;365(9453):36–42. PMID: 15639678. 10.1016/S0140-6736(04)17663-0 15639678
110 Vorona RD, Winn MP, Babineau TW, . Overweight and obese patients in a primary care population report less sleep than patients with a normal body mass index. Arch Intern Med. 2005;165(1):25–30. PMID: 15642870. 10.1001/archinte.165.1.25 15642870
111 Komaroff AL. The Microbiome and Risk for Obesity and Diabetes. JAMA. 2017;317(4):355–6. 10.1001/jama.2016.20099 28006047
112 Huang TT, Cawley JH, Ashe M, . Mobilisation of public support for policy actions to prevent obesity. Lancet. 2015;385(9985):2422–31. 10.1016/S0140-6736(14)61743-8 25703113
113 Hawkes C, Smith TG, Jewell J, . Smart food policies for obesity prevention. Lancet. 2015;385(9985):2410–21. 10.1016/S0140-6736(14)61745-1 25703109
114 Roberto CA, Swinburn B, Hawkes C, . Patchy progress on obesity prevention: emerging examples, entrenched barriers, and new thinking. Lancet. 2015;385(9985):2400–9. 10.1016/S0140-6736(14)61744-X 25703111
115 Loos RJ. Genetic determinants of common obesity and their value in prediction. Best Pract Res Clin Endocrinol Metab. 2012;26(2):211–26. 10.1016/j.beem.2011.11.003 22498250
116 Bray G. Clinical Classification and Natural History of Overweight. In: Contemporary Diagnosis and Management of Obesity and The Metabolic Syndrome. Newton, Pennsylvania: Handbooks in Health Care Co.; 2003. p. 111–43. PMID: none.
117 Howard BV, Manson JE, Stefanick ML, . Low-fat dietary pattern and weight change over 7 years: the Women’s Health Initiative Dietary Modification Trial. JAMA. 2006;295(1):39–49. PMID: 16391215. 10.1001/jama.295.1.39 16391215
118 Ozanne SE. Epigenetic signatures of obesity. N Engl J Med. 2015;372(10):973–4. PMID: 25738675. 10.1056/NEJMcibr1414707 25738675
119 Sen S, Carpenter AH, Hochstadt J, . Nutrition, weight gain and eating behavior in pregnancy: a review of experimental evidence for long-term effects on the risk of obesity in offspring. Physiol Behav. 2012;107(1):138–45. PMID: 22546810. 10.1016/j.physbeh.2012.04.014 22546810
120 Catalano PM, Farrell K, Thomas A, . Perinatal risk factors for childhood obesity and metabolic dysregulation. Am J Clin Nutr. 2009;90(5):1303–13. PMID: 19759171. 10.3945/ajcn.2008.27416 19759171
121 Power C, Jefferis BJ. Fetal environment and subsequent obesity: a study of maternal smoking. Int J Epidemiol. 2002;31(2):413–9. PMID: 11980805.11980805
122 Dabelea D, Hanson RL, Lindsay RS, . Intrauterine exposure to diabetes conveys risks for type 2 diabetes and obesity: a study of discordant sibships. Diabetes. 2000;49(12):2208–11. PMID: 11118027. 10.2337/diabetes.49.12.2208 11118027
123 Harder T, Bergmann R, Kallischnigg G, . Duration of breastfeeding and risk of overweight: a meta-analysis. Am J Epidemiol. 2005;162(5):397–403. PMID: 16076830. 10.1093/aje/kwi222 16076830
124 Freedman DS, Khan LK, Serdula MK, . The relation of childhood BMI to adult adiposity: the Bogalusa Heart Study. Pediatrics. 2005;115(1):22–7. PMID: 15629977. 10.1542/peds.2004-0220 15629977
125 Guo SS, Roche AF, Chumlea WC, . The predictive value of childhood body mass index values for overweight at age 35 y. Am J Clin Nutr. 1994;59(4):810–9. PMID: 8147324.8147324
126 McTigue KM, Garrett JM, Popkin BM. The natural history of the development of obesity in a cohort of young U.S. adults between 1981 and 1998. Ann Intern Med. 2002;136(12):857–64. PMID: 12069559. 10.7326/0003-4819-136-12-200206180-00006 12069559
127 Stein CJ, Colditz GA. The epidemic of obesity. J Clin Endocrinol Metab. 2004;89(6):2522–5. PMID: 15181019. 10.1210/jc.2004-0288 15181019
128 McTigue K, Harris R, Hemphill B, . Screening and interventions for obesity in adults: summary of the evidence for the U.S. Preventive Services Task Force. Ann Intern Med. 2003;139(11):933–49. PMID: 14644897. 10.7326/0003-4819-139-11-200312020-00013 14644897
129 Janssen I, Katzmarzyk PT, Ross R. Waist circumference and not body mass index explains obesity-related health risk. Am J Clin Nutr. 2004;79(3):379–84. PMID: 14985210.14985210
130 Simpson JA, MacInnis RJ, Peeters A, . A comparison of adiposity measures as predictors of all-cause mortality: the Melbourne Collaborative Cohort Study. Obesity (Silver Spring). 2007;15(4):994–1003. PMID: 17426335. 10.1038/oby.2007.622 17426335
131 Koster A, Leitzmann MF, Schatzkin A, . Waist circumference and mortality. Am J Epidemiol. 2008;167(12):1465–75. PMID: 18417494. 10.1093/aje/kwn079 18417494
132 Tsai AG, Wadden TA. In the clinic: obesity. Ann Intern Med. 2013;159(5):ITC3-1–ITC3-15; quiz ITC3-6. PMID: 24026335. 10.7326/0003-4819-159-5-201309030-01003 24026335
133 Jacobs EJ, Newton CC, Wang Y, . Waist circumference and all-cause mortality in a large US cohort. Arch Intern Med. 2010;170(15):1293–301. PMID: 20696950. 10.1001/archinternmed.2010.201 20696950
134 Hamer M, O’Donovan G, Stensel D, . Normal-Weight Central Obesity and Risk for Mortality. Ann Intern Med. 2017:1–2. PMID: 28437799. 10.7326/l17-0022 28437799
135 Czernichow S, Kengne AP, Huxley RR, . Comparison of waist-to-hip ratio and other obesity indices as predictors of cardiovascular disease risk in people with type-2 diabetes: a prospective cohort study from ADVANCE. European journal of cardiovascular prevention and rehabilitation: official journal of the European Society of Cardiology, Working Groups on Epidemiology & Prevention and Cardiac Rehabilitation and Exercise Physiology. 2011;18(2):312–9. PMID: 20628304. 10.1097/HJR.0b013e32833c1aa3 20628304
136 Ashwell M, Gunn P, Gibson S. Waist-to-height ratio is a better screening tool than waist circumference and BMI for adult cardiometabolic risk factors: systematic review and meta-analysis. Obes Rev. 2012;13(3):275–86. PMID: 22106927. 10.1111/j.1467-789X.2011.00952.x 22106927
137 Ashwell M, Mayhew L, Richardson J, . Waist-to-height ratio is more predictive of years of life lost than body mass index. PLoS One. 2014;9(9):e103483. PMID: 25198730. 10.1371/journal.pone.0103483 25198730
138 Krakauer NY, Krakauer JC. Expansion of waist circumference in medical literature: potential clinical application of a body shape index. Journal of Obesity & Weight Loss Therapy. 2014;2014. PMID: None. 10.4172/2165-7904.1000216
139 Krakauer NY, Krakauer JC. Dynamic association of mortality hazard with body shape. PLoS One. 2014;9(2):e88793. PMID: 24586394. 10.1371/journal.pone.0088793 24586394
140 Krakauer NY, Krakauer JC. A new body shape index predicts mortality hazard independently of body mass index. PLoS One. 2012;7(7):e39504. PMID: 22815707. 10.1371/journal.pone.0039504 22815707
141 Krakauer NY, Krakauer JC. An Anthropometric Risk Index Based on Combining Height, Weight, Waist, and Hip Measurements. J Obes. 2016;2016:8094275. PMID: 27830087. 10.1155/2016/8094275 27830087
142 Jortberg B, Myers E, Gigliotti L, . Academy of Nutrition and Dietetics: standards of practice and standards of professional performance for registered dietitian nutritionists (competent, proficient, and expert) in adult weight management. J Acad Nutr Diet. 2015;115(4):609–18e40. PMID: 25819519. 10.1016/j.jand.2014.12.018 25819519
143 Garvey W, Garber A, Mechanick J, . American association of clinical endocrinologists and american college of endocrinology position statement on the 2014 advanced framework for a new diagnosis of obesity as a chronic disease. Endocr Pract. 2014;20(9):977–89. PMID: 25253227.25253227
144 Stegenga H, Haines A, Jones K, . Identification, assessment, and management of overweight and obesity: summary of updated NICE guidance. BMJ. 2014;349:g6608. PMID: 25430558. 10.1136/bmj.g6608 25430558
145 Cerhan JR, Moore SC, Jacobs EJ, . A pooled analysis of waist circumference and mortality in 650,000 adults. Mayo Clin Proc. 2014;89(3):335–45. PMID: 24582192. 10.1016/j.mayocp.2013.11.011 24582192
146 Carmienke S, Freitag MH, Pischon T, . General and abdominal obesity parameters and their combination in relation to mortality: a systematic review and meta-regression analysis. Eur J Clin Nutr. 2013;67(6):573–85. PMID: 23511854. 10.1038/ejcn.2013.61 23511854
147 National Institutes of Health. NHLBI obesity education initiative expert panel on the identification, evaluation, and treatment of overweight and obesity in adults. The Evidence Report NIH. 1998:98–4083. PMID: None.
148 World Health Organization. Waist circumference and waist-hip ratio. Report of a WHO Expert Consultation. Geneva: World Health Organization, 8–11. Geneva 2008. PMID: None.
149 Alberti KG, Zimmet P, Shaw J. Metabolic syndrome-a new world-wide definition. A Consensus Statement from the International Diabetes Federation. Diabet Med. 2006;23(5):469–80. PMID: 16681555. 10.1111/j.1464-5491.2006.01858.x 16681555
150 Alberti KG, Zimmet P, Shaw J. International Diabetes Federation: a consensus on Type 2 diabetes prevention. Diabet Med. 2007;24(5):451–63. PMID: 17470191. 10.1111/j.1464-5491.2007.02157.x 17470191
151 de Hollander EL, Bemelmans WJ, Boshuizen HC, . The association between waist circumference and risk of mortality considering body mass index in 65- to 74-year-olds: a meta-analysis of 29 cohorts involving more than 58 000 elderly persons. Int J Epidemiol. 2012;41(3):805–17. PMID: 22467292. 10.1093/ije/dys008 22467292
152 Lear SA, James PT, Ko GT, . Appropriateness of waist circumference and waist-to-hip ratio cutoffs for different ethnic groups. Eur J Clin Nutr. 2010;64(1):42–61. PMID: 19672278. 10.1038/ejcn.2009.70 19672278
153 Stevens J, Keil JE, Rust PF, . Body mass index and body girths as predictors of mortality in black and white men. Am J Epidemiol. 1992;135(10):1137–46. PMID: 1632424.1632424
154 Reis JP, Araneta MR, Wingard DL, . Overall obesity and abdominal adiposity as predictors of mortality in u.s. White and black adults. Ann Epidemiol. 2009;19(2):134–42. PMID: 19185808. 10.1016/j.annepidem.2008.10.008 19185808
155 Lakoski SG, Le AH, Muntner P, . Adiposity, inflammation, and risk for death in black and white men and women in the United States: the Reasons for Geographic and Racial Differences in Stroke (REGARDS) study. J Clin Endocrinol Metab. 2011;96(6):1805–14. PMID: 21430022. 10.1210/jc.2010-3055 21430022
156 Jensen MD, Ryan DH, Apovian CM, . 2013 AHA/ACC/TOS guideline for the management of overweight and obesity in adults: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines and The Obesity Society. [Erratum appears in J Am Coll Cardiol. 2014 Jul 1;63(25 Pt B):3029–3030]. J Am Coll Cardiol. 2014;63(25 Pt B):2985–3023. PMID: 24239920. 10.1016/j.jacc.2013.11.004 24239920
157 Guidance for Industry Developing Products for Weight Management: Draft Guidance. https://www.fda.gov/downloads/Drugs/Guidances/ucm071612.pdf: Food and Drug Administration 2007. PMID: None.
158 Apovian CM, Aronne LJ, Bessesen DH, . Pharmacological management of obesity: an endocrine Society clinical practice guideline. J Clin Endocrinol Metab. 2015;100(2):342–62. PMID: 25590212. 10.1210/jc.2014-3415 25590212
159 U.S. Food and Drug Administration, Center for Drug Evaluation and Research (CDER). Xenical Approval Letter (NDA:020766). https://www.accessdata.fda.gov/drugsatfda_docs/appletter/1999/20766ltr.pdf. Accessed May 8, 2017.
160 Davidson MH, Hauptman J, DiGirolamo M, . Weight control and risk factor reduction in obese subjects treated for 2 years with orlistat: a randomized controlled trial. JAMA. 1999;281(3):235–42. PMID: 9918478. 10.1001/jama.281.3.235 9918478
161 Torgerson JS, Hauptman J, Boldrin MN, . XENical in the prevention of diabetes in obese subjects (XENDOS) study: a randomized study of orlistat as an adjunct to lifestyle changes for the prevention of type 2 diabetes in obese patients. Diabetes Care. 2004;27(1):155–61. PMID: 14693982. 10.2337/diacare.27.1.155 14693982
162 U.S. Food and Drug Administration, Center for Drug Evaluation and Research (CDER). Alli Approval Letter (NDA:21-887). https://www.accessdata.fda.gov/drugsatfda_docs/appletter/2007/021887s000ltr.pdf. Accessed May 8, 2017.
163 Kim GW, Lin JE, Blomain ES, . Antiobesity pharmacotherapy: new drugs and emerging targets. Clinical pharmacology and therapeutics. 2014;95(1):53–66. PMID: 24105257. 10.1038/clpt.2013.204 24105257
164 U.S. Food and Drug Administration, Center for Drug Evaluation and Research (CDER). Qsymia Approval Letter (NDA:022580). https://www.accessdata.fda.gov/drugsatfda_docs/appletter/2012/022580Origs000ltr.pdf. Accessed May 8, 2017.
165 Bray GA, Hollander P, Klein S, . A 6-month randomized, placebo-controlled, dose-ranging trial of topiramate for weight loss in obesity. Obes Res. 2003;11(6):722–33. PMID: 12805393. 10.1038/oby.2003.102 12805393
166 Wilding J, Van Gaal L, Rissanen A, . A randomized double-blind placebo-controlled study of the long-term efficacy and safety of topiramate in the treatment of obese subjects. Int J Obes Relat Metab Disord. 2004;28(11):1399–410. PMID: 15486569. 10.1038/sj.ijo.0802783 15486569
167 Astrup A, Caterson I, Zelissen P, . Topiramate: long-term maintenance of weight loss induced by a low-calorie diet in obese subjects. Obes Res. 2004;12(10):1658–69. PMID: 15536230. 10.1038/oby.2004.206 15536230
168 Aronne LJ, Wadden TA, Peterson C, . Evaluation of phentermine and topiramate versus phentermine/topiramate extended-release in obese adults. Obesity. 2013;21(11):2163–71. PMID: 24136928. 10.1002/oby.20584 24136928
169 Yanovski SZ, Yanovski JA. Long-term drug treatment for obesity: a systematic and clinical review. JAMA. 2014;311(1):74–86. PMID: 24231879. 10.1001/jama.2013.281361 24231879
170 U.S. Food and Drug Administration, Center for Drug Evaluation and Research (CDER). Belviq Approval Letter (NDA:022529). https://www.accessdata.fda.gov/drugsatfda_docs/appletter/2012/022529Orig1s000ltr.pdf. Accessed May 8, 2017.
171 Smith SR, Prosser WA, Donahue DJ, . Lorcaserin (APD356), a selective 5-HT(2C) agonist, reduces body weight in obese men and women. Obesity (Silver Spring). 2009;17(3):494–503. PMID: 19057523. 10.1038/oby.2008.537 19057523
172 Smith SR, Weissman NJ, Anderson CM, . Multicenter, placebo-controlled trial of lorcaserin for weight management. N Engl J Med. 2010;363(3):245–56. PMID: 20647200. 10.1056/NEJMoa0909809 20647200
173 Fidler MC, Sanchez M, Raether B, . A one-year randomized trial of lorcaserin for weight loss in obese and overweight adults: the BLOSSOM trial. J Clin Endocrinol Metab. 2011;96(10):3067–77. PMID: 21795446. 10.1210/jc.2011-1256 21795446
174 O’Neil PM, Smith SR, Weissman NJ, . Randomized placebo-controlled clinical trial of lorcaserin for weight loss in type 2 diabetes mellitus: the BLOOM-DM study. Obesity (Silver Spring). 2012;20(7):1426–36. PMID: 22421927. 10.1038/oby.2012.66 22421927
175 Carroll FI, Blough BE, Mascarella SW, . Bupropion and bupropion analogs as treatments for CNS disorders. Advances in pharmacology. 2014;69:177–216. PMID: 24484978. 10.1016/B978-0-12-420118-7.00005-6 24484978
176 Gadde KM, Parker CB, Maner LG, . Bupropion for weight loss: an investigation of efficacy and tolerability in overweight and obese women. Obes Res. 2001;9(9):544–51. PMID: 11557835. 10.1038/oby.2001.71 11557835
177 U.S. Food and Drug Administration, Center for Drug Evaluation and Research (CDER). Saxenda Approval Letter (NDA:206321). https://www.accessdata.fda.gov/drugsatfda_docs/appletter/2014/206321Orig1s000ltr.pdf. Accessed May 8, 2017.
178 Morton GJ, Cummings DE, Baskin DG, . Central nervous system control of food intake and body weight. Nature. 2006;443(7109):289–95. PMID: 16988703. 10.1038/nature05026 16988703
179 Arterburn D, Fisher D. The Current State of the Evidence for Bariatric Surgery. JAMA. 2014;312(9):898–9. PMID: 25182097 10.1001/jama.2014.10940 25182097
180 Buchwald H, Oien DM. Metabolic/bariatric surgery worldwide 2011. Obes Surg. 2013;23(4):427–36. PMID: 23338049. 10.1007/s11695-012-0864-0 23338049
181 Dixon JB, Lambert EA, Lambert GW. Neuroendocrine adaptations to bariatric surgery. Mol Cell Endocrinol. 2015. PMID: 26044866. 10.1016/j.mce.2015.05.033 26044866
182 Brauer P, Connor Gorber S, Shaw E, . Recommendations for prevention of weight gain and use of behavioural and pharmacologic interventions to manage overweight and obesity in adults in primary care. CMAJ: Canadian Medical Association journal = journal de l’Association medicale canadienne. 2015;187(3):184–95. PMID: 25623643. 10.1503/cmaj.140887 25623643
183 Smith AW, Borowski LA, Liu B, . U.S. primary care physicians’ diet-, physical activity-, and weight-related care of adult patients. Am J Prev Med. 2011;41(1):33–42. PMID: 21665061. 10.1016/j.amepre.2011.03.017 21665061
184 Steeves JA, Liu B, Willis G, . Physicians’ personal beliefs about weight-related care and their associations with care delivery: The U.S. National Survey of Energy Balance Related Care among Primary Care Physicians. Obes Res Clin Pract. 2015;9(3):243–55. PMID: 25175671. 10.1016/j.orcp.2014.08.002 25175671
185 Glauser TA, Roepke N, Stevenin B, . Physician knowledge about and perceptions of obesity management. Obes Res Clin Pract. 2015. PMID: 25791741. 10.1016/j.orcp.2015.02.011 25791741
186 World Health Organization Western Pacific Region. The Asia-Pacific perspective: Redefining obesity and its treatment. Melbourne: 2000. PMID: none.
187 Gallagher C. OCC Health Policy Memo: Summary of State Benchmark Plan Coverage of Obesity Treatment Services 2012 [cited Workplan.
188 Kraschnewski JL, Sciamanna CN, Stuckey HL, . A silent response to the obesity epidemic: decline in US physician weight counseling. Med Care. 2013;51(2):186–92. PMID: 23047128. 10.1097/MLR.0b013e3182726c33 23047128
189 Ma J, Xiao L, Yank V. Variations between obese Latinos and whites in weight-related counseling during preventive clinical visits in the United States. Obesity (Silver Spring). 2013;21(8):1734–41. PMID: 23696497. 10.1002/oby.20285 23696497
190 Ma J, Xiao L, Stafford RS. Underdiagnosis of obesity in adults in US outpatient settings. Arch Intern Med. 2009;169(3):313–4. PMID: 19204224. 10.1001/archinternmed.2008.582 19204224
191 Simkin-Silverman LR, Gleason KA, King WC, . Predictors of weight control advice in primary care practices: patient health and psychosocial characteristics. Prev Med. 2005;40(1):71–82. PMID: 15530583. 10.1016/j.ypmed.2004.05.012 15530583
192 Stafford RS, Farhat JH, Misra B, . National patterns of physician activities related to obesity management. Arch Fam Med. 2000;9(7):631–8. PMID: 10910311.10910311
193 Bleich SN, Bandara S, Bennett W, . Enhancing the role of nutrition professionals in weight management: A cross-sectional survey. Obesity (Silver Spring). 2015;23(2):454–60. PMID: 25445319. 10.1002/oby.20945 25445319
194 Dahlin A, Beermann B. Incorrect use of orlistat and sibutramine in clinical practice. Eur J Clin Pharmacol. 2007;63(2):205–9. PMID: 17205321. 10.1007/s00228-006-0226-8 17205321
195 Thomas CE, Mauer EA, Shukla AP, . Low adoption of weight loss medications: A comparison of prescribing patterns of antiobesity pharmacotherapies and SGLT2s. Obesity (Silver Spring). 2016;24(9):1955–61. PMID: 27569120. 10.1002/oby.21533 27569120
196 Moyer VA, Force USPST. Screening for and management of obesity in adults: U.S. Preventive Services Task Force recommendation statement. [Summary for patients in Ann Intern Med. 2012 Sep 4;157(5):I–32; PMID: 22733111]. Ann Intern Med. 2012;157(5):373-8. PMID: 22733087. 10.7326/0003-4819-157-5-201209040-00475 22733111
197 LeBlanc E, O’Connor E, Whitlock EP, . U.S. Preventive Services Task Force Evidence Syntheses, formerly Systematic Evidence Reviews. Rockville (MD): Agency for Healthcare Research and Quality (US); 2011. PMID: 2204956922049569.
198 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD: U.S. Preventive Services Task Force; 2015. PMID: None.
199 U.S. Preventive Services Task Force. Screening for Obesity in Children and Adolescents US Preventive Services Task Force Recommendation Statement. JAMA. 2017;317(23):2417–26. PMID: None. 10.1001/jama.2017.6803 28632874
200 List of OECD Member countries - Ratification of the Convention on the OECD. http://www.oecd.org/about/membersandpartners/list-oecd-member-countries.htm. Accessed 3/28/2017, 2017.
201 Elobeid MA, Padilla MA, McVie T, . Missing data in randomized clinical trials for weight loss: scope of the problem, state of the field, and performance of statistical methods. PLoS One. 2009;4(8):e6624. PMID: 19675667. 10.1371/journal.pone.0006624 19675667
202 Pritchard DA, Hyndman J, Taba F. Nutritional counselling in general practice: a cost effective analysis. J Epidemiol Community Health. 1999;53(5):311–6. PMID: 10396539. 10.1136/jech.53.5.311 10396539
203 Davis BR, Oberman A, Blaufox MD, . Effect of antihypertensive therapy on weight loss. The Trial of Antihypertensive Interventions and Management Research Group. Hypertension. 1992;19(4):393–9. PMID: 1555871. 10.1161/01.HYP.19.4.393 1555871
204 DerSimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7(3):177–88. PMID: 3802833. 10.1016/0197-2456(86)90046-2 3802833
205 Knowler WC, Barrett-Connor E, Fowler SE, . Reduction in the incidence of type 2 diabetes with lifestyle intervention or metformin. N Engl J Med. 2002;346(6):393–403. PMID: 11832527. 10.1056/NEJMoa012512 11832527
206 Wadden T, Volger S, Sarwer D, . A two-year randomized trial of obesity treatment in primary care practice. N Engl J Med. 2011;365(21):1969–79. PMID: 22082239 10.1056/NEJMoa1109220 22082239
207 Higgins JP, Thompson SG. Quantifying heterogeneity in a meta-analysis. Stat Med. 2002;21(11):1539–58. PMID: 12111919. 10.1002/sim.1186 12111919
208 The Cochrane Collaboration. Cochrane Handbook for Systematic Reviews of Interventions. Version 5.1.0. Higgins J, Green S, editors. The Cochrane Collaboration. 2011. PMID: None.
209 Egger M, Davey Smith G, Schneider M, . Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315(7109):629–34. PMID: 9310563. 10.1136/bmj.315.7109.629 9310563
210 Peters JL, Sutton AJ, Jones DR, . Comparison of two methods to detect publication bias in meta-analysis. JAMA. 2006;295(6):676–80. PMID: 16467236. 10.1001/jama.295.6.676 16467236
211 Berkman N, Lohr K, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD: Agency for Healthcare Research and Quality; 2014. p. 314–49. PMID: None.
212 Atkins D, Eccles M, Flottorp S, . Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. 2004;4(1):38. PMID: 15615589. 10.1186/1472-6963-4-38 15615589
213 Acharya NV, Wilton LV, Shakir SA. Safety profile of orlistat: results of a prescription-event monitoring study. Int J Obes (Lond). 2006;30(11):1645–52. PMID: 16552401. 10.1038/sj.ijo.0803323 16552401
214 Ackermann RT, Finch E, Brizendine E, . Translating the Diabetes Prevention Program into the community. The DEPLOY Pilot Study. Am J Prev Med. 2008;35(4):357–63. PMID: 18779029. 10.1016/j.amepre.2008.06.035 18779029
215 Ackermann RT, Liss DT, Finch EA, . A Randomized Comparative Effectiveness Trial for Preventing Type 2 Diabetes. Am J Public Health. 2015;105(11):2328–34. PMID: 26378828. 10.2105/AJPH.2015.302641 26378828
216 Allison DB, Gadde KM, Garvey WT, . Controlled-release phentermine/topiramate in severely obese adults: a randomized controlled trial (EQUIP). Obesity. 2012;20(2):330–42. PMID: 22051941. 10.1038/oby.2011.330 22051941
217 Anderson AS, Craigie AM, Caswell S, . The impact of a bodyweight and physical activity intervention (BeWEL) initiated through a national colorectal cancer screening programme: randomised controlled trial. BMJ. 2014;348:g1823. PMID: 24609919. 10.1136/bmj.g1823 24609919
218 Apovian CM, Aronne L, Rubino D, . A randomized, phase 3 trial of naltrexone SR/bupropion SR on weight and obesity-related risk factors (COR-II). Obesity. 2013;21(5):935–43. PMID: 23408728. 10.1002/oby.20309 23408728
219 Appel L, Clark J, Yeh H, . Comparative effectiveness of weight-loss interventions in clinical practice. N Engl J Med. 2011;365(21):1959–68. PMID: 22085317 10.1056/NEJMoa1108660 22085317
220 Astrup A, Carraro R, Finer N, . Safety, tolerability and sustained weight loss over 2 years with the once-daily human GLP-1 analog, liraglutide. Int J Obes (Lond). 2012;36(6):vill843–54. PMID: 21844879. 10.1038/ijo.2011.158 21844879
221 Aveyard P, Lewis A, Tearne S, . Screening and brief intervention for obesity in primary care: a parallel, two-arm, randomised trial. Lancet. 2016. PMID: 27789061. 10.1016/S0140-6736(16)31893-1 27789061
222 Bakris G, Calhoun D, Egan B, . Orlistat improves blood pressure control in obese subjects with treated but inadequately controlled hypertension. J Hypertens. 2002;20(11):2257–67. PMID: 12409965.12409965
223 Befort CA, Klemp JR, Sullivan DK, . Weight loss maintenance strategies among rural breast cancer survivors: The rural women connecting for better health trial. Obesity. 2016;24(10):2070–7. PMID: 27581328. 10.1002/oby.21625 27581328
224 Bennett GG, Warner ET, Glasgow RE, . Obesity treatment for socioeconomically disadvantaged patients in primary care practice. Arch Intern Med. 2012;172(7):565–74. PMID: 22412073. 10.1001/archinternmed.2012.1 22412073
225 Bhopal RS, Douglas A, Wallia S, . Effect of a lifestyle intervention on weight change in south Asian individuals in the UK at high risk of type 2 diabetes: a family-cluster randomised controlled trial. Lancet Diabetes Endocrinol. 2014;2(3):218–27. PMID: 24622752. 10.1016/S2213-8587(13)70204-3 24622752
226 Broom I, Hughes E, Dodson P, . The role of orlistat in the treatment of obese patients with mild to moderate hypercholesterolaemia: consequences for coronary risk. Br J Cardiol. 2002;9(8):460–8. PMID: None.
227 Broom I, Wilding J, Stott P, . Randomised trial of the effect of orlistat on body weight and cardiovascular disease risk profile in obese patients: UK Multimorbidity Study. Int J Clin Pract. 2002;56(7):494–9. PMID: 1229661012296610
228 Burke V, Beilin LJ, Cutt HE, . Effects of a lifestyle programme on ambulatory blood pressure and drug dosage in treated hypertensive patients: a randomized controlled trial. J Hypertens. 2005;23(6):1241–9. PMID: 15894901. 10.1097/01.hjh.0000170388.61579.4f 15894901
229 Cadmus-Bertram L, Nelson SH, Hartman S, . Randomized trial of a phone- and web-based weight loss program for women at elevated breast cancer risk: the HELP study. J Behav Med. 2016;39(4):551–9. PMID: 27012848. 10.1007/s10865-016-9735-9 27012848
230 Chirinos DA, Goldberg RB, Llabre MM, . Lifestyle modification and weight reduction among low-income patients with the metabolic syndrome: the CHARMS randomized controlled trial. J Behav Med. 2016;39(3):483–92. PMID: 26846133. 10.1007/s10865-016-9721-2 26846133
231 Christian JG, Byers TE, Christian KK, . A computer support program that helps clinicians provide patients with metabolic syndrome tailored counseling to promote weight loss. J Am Diet Assoc. 2011;111(1):75–83. PMID: 21185968. 10.1016/j.jada.2010.10.006 21185968
232 Cohen MD, D’Amico FJ, Merenstein JH. Weight reduction in obese hypertensive patients. Fam Med. 1991;23(1):25–8. PMID: 2001777.2001777
233 Cussler EC, Teixeira PJ, Going SB, . Maintenance of weight loss in overweight middle-aged women through the Internet. Obesity (Silver Spring). 2008;16(5):1052–60. PMID: 18309301 10.1038/oby.2008.19 18309301
234 de Vos BC, Runhaar J, Bierma-Zeinstra SM. Effectiveness of a tailor-made weight loss intervention in primary care. Eur J Nutr. 2014;53(1):95–104. PMID: 23429925. 10.1007/s00394-013-0505-y 23429925
235 Demark-Wahnefried W, Jones LW, Snyder DC, . Daughters and Mothers Against Breast Cancer (DAMES): main outcomes of a randomized controlled trial of weight loss in overweight mothers with breast cancer and their overweight daughters. Cancer. 2014;120(16):2522–34. PMID: 24804802. 10.1002/cncr.28761 24804802
236 Derosa G, Mugellini A, Ciccarelli L, . Randomized, double-blind, placebo-controlled comparison of the action of orlistat, fluvastatin, or both an anthropometric measurements, blood pressure, and lipid profile in obese patients with hypercholesterolemia prescribed a standardized diet. Clin Ther. 2003;25(4):1107–22. PMID: 12809960. 10.1016/S0149-2918(03)80070-X 12809960
237 Eaton CB, Hartman SJ, Perzanowski E, . A Randomized Clinical Trial of a Tailored Lifestyle Intervention for Obese, Sedentary, Primary Care Patients. Ann Fam Med. 2016;14(4):311–9. PMID: 27401418. 10.1370/afm.1952 27401418
238 Farr OM, Upadhyay J, Gavrieli A, . Lorcaserin Administration Decreases Activation of Brain Centers in Response to Food Cues and These Emotion- and Salience-Related Changes Correlate With Weight Loss Effects: A 4-Week-Long Randomized, Placebo-Controlled, Double-Blind Clinical Trial. Diabetes. 2016;65(10):2943–53. PMID: 27385157. 10.2337/db16-0635 27385157
239 Finer N, James WP, Kopelman PG, . One-year treatment of obesity: a randomized, double-blind, placebo-controlled, multicentre study of orlistat, a gastrointestinal lipase inhibitor. Int J Obes Relat Metab Disord. 2000;24(3):306–13. PMID: 10757623. 10.1038/sj.ijo.0801128 10757623
240 Fitzgibbon ML, Stolley MR, Schiffer L, . Obesity Reduction Black Intervention Trial (ORBIT): 18-Month Results. Obesity (Silver Spring). 2010;18(12):2317–25. PMID: 20300081. 10.1038/oby.2010.47 20300081
241 Gadde KM, Allison DB, Ryan DH, . Effects of low-dose, controlled-release, phentermine plus topiramate combination on weight and associated comorbidities in overweight and obese adults (CONQUER): a randomised, placebo-controlled, phase 3 trial.[Erratum appears in Lancet. 2011 Apr 30;377(9776):1494]. Lancet. 2011;377(9774):1341–52. PMID: 21481449. 10.1016/S0140-6736(11)60205-5 21481449
242 Godino JG, Merchant G, Norman GJ, . Using social and mobile tools for weight loss in overweight and obese young adults (Project SMART): a 2 year, parallel-group, randomised, controlled trial. Lancet Diabetes Endocrinol. 2016;4(9):747–55. PMID: 27426247. 10.1016/S2213-8587(16)30105-X 27426247
243 Greaves C, Gillison F, Stathi A, . Waste the waist: a pilot randomised controlled trial of a primary care based intervention to support lifestyle change in people with high cardiovascular risk. Int. 2015;12:1. PMID: 25592201. 10.1186/s12966-014-0159-z 25592201
244 Greenway FL, Fujioka K, Plodkowski RA, . Effect of naltrexone plus bupropion on weight loss in overweight and obese adults (COR-I): a multicentre, randomised, double-blind, placebo-controlled, phase 3 trial.[Erratum appears in Lancet. 2010 Oct 23;376(9750):1392], [Erratum appears in Lancet. 2010 Aug 21;376(9741):594]. Lancet. 2010;376(9741):595–605. PMID: 20673995. 10.1016/S0140-6736(10)60888-4 20673995
245 Haapala I, Barengo NC, Biggs S, . Weight loss by mobile phone: a 1-year effectiveness study. Public Health Nutr. 2009;12(12):2382–91. PMID: 19323865. 10.1017/S1368980009005230 19323865
246 Hauptman J, Lucas C, Boldrin MN, . Orlistat in the long-term treatment of obesity in primary care settings. Arch Fam Med. 2000;9(2):160–7. PMID: 10693734.10693734
247 Hill JO, Hauptman J, Anderson JW, . Orlistat, a lipase inhibitor, for weight maintenance after conventional dieting: a 1-y study. Am J Clin Nutr. 1999;69(6):1108–16. PMID: 10357727.10357727
248 Hong JL, Meier CR, Sandler RS, . Risk of colorectal cancer after initiation of orlistat: matched cohort study. BMJ. 2013;347:f5039. PMID: 23982291. 10.1136/bmj.f5039 23982291
249 Hunt K, Wyke S, Gray CM, . A gender-sensitised weight loss and healthy living programme for overweight and obese men delivered by Scottish Premier League football clubs (FFIT): a pragmatic randomised controlled trial. Lancet. 2014;383(9924):1211–21. PMID: 24457205. 10.1016/S0140-6736(13)62420-4 24457205
250 Huseinovic E, Bertz F, Leu Agelii M, . Effectiveness of a weight loss intervention in postpartum women: results from a randomized controlled trial in primary health care. Am J Clin Nutr. 2016;104(2):362–70. PMID: 27413127. 10.3945/ajcn.116.135673 27413127
251 Jakicic JM, Otto AD, Lang W, . The effect of physical activity on 18-month weight change in overweight adults. Obesity. 2011;19(1):100–9. PMID: 20539299. 10.1038/oby.2010.122 20539299
252 Jansson SP, Engfeldt P, Magnuson A, . Interventions for lifestyle changes to promote weight reduction, a randomized controlled trial in primary health care. BMC Res Notes. 2013;6:213. PMID: 23711165. 10.1186/1756-0500-6-213 23711165
253 Jebb SA, Ahern AL, Olson AD, . Primary care referral to a commercial provider for weight loss treatment versus standard care: a randomised controlled trial. Lancet. 2011;378(9801):1485–92. PMID: 21906798. 10.1016/S0140-6736(11)61344-5 21906798
254 Jeffery RW, Wing RR, Thorson C, . Strengthening behavioral interventions for weight loss: a randomized trial of food provision and monetary incentives. J Consult Clin Psychol. 1993;61(6):1038–45. PMID: 8113481. 10.1037/0022-006X.61.6.1038 8113481
255 Jolly K, Lewis A, Beach J, . Comparison of range of commercial or primary care led weight reduction programmes with minimal intervention control for weight loss in obesity: lighten Up randomised controlled trial. BMJ. 2011;343:d6500. PMID: 22053315. 10.1136/bmj.d6500 22053315
256 Jones DW, Miller ME, Wofford MR, . The effect of weight loss intervention on antihypertensive medication requirements in the hypertension Optimal Treatment (HOT) study. Am J Hypertens. 1999;12(12 Pt 1-2):1175–80. PMID: 10619579.10619579
257 Kanke S, Kawai T, Takasawa N, . Interventions for body weight reduction in obese patients during short consultations: an open-label randomized controlled trial in the Japanese primary care setting. Asia Pac Fam Med. 2015;14(1):5. PMID: 26015773. 10.1186/s12930-015-0022-7 26015773
258 Katula JA, Vitolins MZ, Rosenberger EL, . One-year results of a community-based translation of the Diabetes Prevention Program: Healthy-Living Partnerships to Prevent Diabetes (HELP PD) Project.[Erratum appears in Diabetes Care. 2012 Feb;35(2):455]. Diabetes Care. 2011;34(7):1451–7. PMID: 21593290. 10.2337/dc10-2115 21593290
259 Kim SH, Abbasi F, Lamendola C, . Benefits of liraglutide treatment in overweight and obese older individuals with prediabetes. Diabetes Care. 2013;36(10):3276–82. PMID: 23835684. 10.2337/dc13-0354 23835684
260 Krempf M, Louvet JP, Allanic H, . Weight reduction and long-term maintenance after 18 months treatment with orlistat for obesity. Int J Obes Relat Metab Disord. 2003;27(5):591–7. PMID: 12704403. 10.1038/sj.ijo.0802281 12704403
261 Kuller LH, Pettee Gabriel KK, Kinzel LS, . The Women on the Move Through Activity and Nutrition (WOMAN) study: final 48-month results. Obesity. 2012;20(3):636–43. PMID: 21494228. 10.1038/oby.2011.80 21494228
262 Kulzer B, Hermanns N, Gorges D, . Prevention of diabetes self-management program (PREDIAS): effects on weight, metabolic risk factors, and behavioral outcomes. Diabetes Care. 2009;32(7):1143–6. PMID: 19509014 10.2337/dc08-2141 19509014
263 Lindgarde F. The effect of orlistat on body weight and coronary heart disease risk profile in obese patients: the Swedish Multimorbidity Study. J Intern Med. 2000;248(3):245–54. PMID: 10971792. 10.1046/j.1365-2796.2000.00720.x 10971792
264 Little P, Stuart B, Hobbs FR, . An internet-based intervention with brief nurse support to manage obesity in primary care (POWeR+): a pragmatic, parallel-group, randomised controlled trial. Lancet Diabetes Endocrinol. 2016;4(10):821–8. PMID: 27474214. 10.1016/S2213-8587(16)30099-7 27474214
265 Luley C, Blaik A, Gotz A, . Weight loss by telemonitoring of nutrition and physical activity in patients with metabolic syndrome for 1 year. J Am Coll Nutr. 2014;33(5):363–74. PMID: 25105874. 10.1080/07315724.2013.875437 25105874
266 Ma J, Yank V, Xiao L, . Translating the Diabetes Prevention Program lifestyle intervention for weight loss into primary care: a randomized trial. JAMA Internal Medicine. 2013;173(2):113–21. PMID: 23229846. 10.1001/2013.jamainternmed.987 23229846
267 Marrero DG, Palmer KN, Phillips EO, . Comparison of Commercial and Self-Initiated Weight Loss Programs in People With Prediabetes: A Randomized Control Trial. Am J Public Health. 2016;106(5):949–56. PMID: 26890171. 10.2105/AJPH.2015.303035 26890171
268 Martin CK, Redman LM, Zhang J, . Lorcaserin, a 5-HT(2C) receptor agonist, reduces body weight by decreasing energy intake without influencing energy expenditure. J Clin Endocrinol Metab. 2011;96(3):837–45. PMID: 21190985. 10.1210/jc.2010-1848 21190985
269 Martin PD, Dutton GR, Rhode PC, . Weight loss maintenance following a primary care intervention for low-income minority women. Obesity. 2008;16(11):2462–7. PMID: 18787526. 10.1038/oby.2008.399 18787526
270 Mitsui T, Shimaoka K, Tsuzuku S, . Gentle exercise of 40 minutes with dietary counseling is effective in treating metabolic syndrome. Tohoku J Exp Med. 2008;215(4):355–61. PMID: 18679010 10.1620/tjem.215.355 18679010
271 Moore H, Summerbell CD, Greenwood DC, . Improving management of obesity in primary care: cluster randomised trial. BMJ. 2003;327(7423):1085. PMID: 14604931. 10.1136/bmj.327.7423.1085 14604931
272 Morgan PJ, Lubans DR, Collins CE, . 12-month outcomes and process evaluation of the SHED-IT RCT: an internet-based weight loss program targeting men. Obesity. 2011;19(1):142–51. PMID: 20523304. 10.1038/oby.2010.119 20523304
273 Muls E, Kolanowski J, Scheen A, . The effects of orlistat on weight and on serum lipids in obese patients with hypercholesterolemia: a randomized, double-blind, placebo-controlled, multicentre study. Int J Obes Relat Metab Disord. 2001;25(11):1713–21. PMID: 11753595. 10.1038/sj.ijo.0801814 11753595
274 Nakade M, Aiba N, Suda N, . Behavioral change during weight loss program and one-year follow-up: Saku Control Obesity Program (SCOP) in Japan. Asia Pac J Clin Nutr. 2012;21(1):22–34. PMID: 22374557.22374557
275 Nanchahal K, Power T, Holdsworth E, . A pragmatic randomised controlled trial in primary care of the Camden Weight Loss (CAMWEL) programme. BMJ Open. 2012;2(3). PMID: 22561352. 10.1136/bmjopen-2011-000793 22561352
276 Narayan KM, Hoskin M, Kozak D, . Randomized clinical trial of lifestyle interventions in Pima Indians: a pilot study. Diabet Med. 1998;15(1):66–72. PMID: 9472866. 10.1002/(SICI)1096-9136(199801)15:1<66::AID-DIA515>3.0.CO;2-A 9472866
277 Nicklas JM, Zera CA, England LJ, . A web-based lifestyle intervention for women with recent gestational diabetes mellitus: a randomized controlled trial. Obstet Gynecol. 2014;124(3):563–70. PMID: 25162257. 10.1097/AOG.0000000000000420 25162257
278 Ockene IS, Tellez TL, Rosal MC, . Outcomes of a Latino community-based intervention for the prevention of diabetes: the Lawrence Latino Diabetes Prevention Project. Am J Public Health. 2012;102(2):336–42. PMID: 22390448. 10.2105/AJPH.2011.300357 22390448
279 Pacanowski CR, Levitsky DA. Frequent Self-Weighing and Visual Feedback for Weight Loss in Overweight Adults. J Obes. 2015;2015:763680. PMID: 26064677. 10.1155/2015/763680 26064677
280 Parikh P, Simon EP, Fei K, . Results of a pilot diabetes prevention intervention in East Harlem, New York City: Project HEED. Am J Public Health. 2010;100: Suppl 1:S232–S9. PMID: 20147680 10.2105/AJPH.2009.170910 20147680
281 Patrick K, Calfas KJ, Norman GJ, . Outcomes of a 12-month web-based intervention for overweight and obese men. Ann Behav Med. 2011;42(3):391–401. PMID: 21822750. 10.1007/s12160-011-9296-7 21822750
282 Pekkarinen T, Kaukua J, Mustajoki P. Long-term weight maintenance after a 17-week weight loss intervention with or without a one-year maintenance program: a randomized controlled trial. J Obes. 2015;2015:651460. PMID: 25918644. 10.1155/2015/651460 25918644
283 Penn L, White M, Oldroyd J, . Prevention of type 2 diabetes in adults with impaired glucose tolerance: the European Diabetes Prevention RCT in Newcastle upon Tyne, UK. BMC Public Health. 2009;9:342. PMID: 19758428. 10.1186/1471-2458-9-342 19758428
284 Perri MG, McAllister DA, Gange JJ, . Effects of four maintenance programs on the long-term management of obesity. J Consult Clin Psychol. 1988;56(4):529–34. PMID: 2848874. 10.1037/0022-006X.56.4.529 2848874
285 Pi-Sunyer X, Astrup A, Fujioka K, . A Randomized, Controlled Trial of 3.0 mg of Liraglutide in Weight Management. N Engl J Med. 2015;373(1):11–22. PMID: 26132939. 10.1056/NEJMoa1411892 26132939
286 Puhkala J, Kukkonen-Harjula K, Mansikkamaki K, . Lifestyle counseling to reduce body weight and cardiometabolic risk factors among truck and bus drivers-a randomized controlled trial. Scand J Work Environ Health. 2015;41(1):54–64. PMID: 25310464. 10.5271/sjweh.3463 25310464
287 Richelsen B, Tonstad S, Rossner S, . Effect of orlistat on weight regain and cardiovascular risk factors following a very-low-energy diet in abdominally obese patients: a 3-year randomized, placebo-controlled study. Diabetes Care. 2007;30(1):27–32. PMID: 17192328. 10.2337/dc06-0210 17192328
288 Rock CL, Flatt SW, Byers TE, . Results of the Exercise and Nutrition to Enhance Recovery and Good Health for You (ENERGY) Trial: A Behavioral Weight Loss Intervention in Overweight or Obese Breast Cancer Survivors. J Clin Oncol. 2015;33(28):3169–76. PMID: 26282657. 10.1200/JCO.2015.61.1095 26282657
289 Rock CL, Pakiz B, Flatt SW, . Randomized trial of a multifaceted commercial weight loss program. Obesity. 2007;15(4):939–49. PMID: 17426329. 10.1038/oby.2007.614 17426329
290 Rosas LG, Thiyagarajan S, Goldstein BA, . The effectiveness of two community-based weight loss strategies among obese, low-income US Latinos. J Acad Nutr Diet. 2015;115(4):537–50.e2. PMID: 25578925. 10.1016/j.jand.2014.10.020 25578925
291 Ross R, Lam M, Blair SN, . Trial of prevention and reduction of obesity through active living in clinical settings: a randomized controlled trial. Arch Intern Med. 2012;172(5):414–24. PMID: 22371872. 10.1001/archinternmed.2011.1972 22371872
292 Rossner S, Sjostrom L, Noack R, . Weight loss, weight maintenance, and improved cardiovascular risk factors after 2 years treatment with orlistat for obesity. European Orlistat Obesity Study Group. Obes Res. 2000;8(1):49–61. PMID: 10678259. 10.1038/oby.2000.8 10678259
293 Shapiro JR, Koro T, Doran N, . Text4Diet: a randomized controlled study using text messaging for weight loss behaviors. Prev Med. 2012;55(5):412–7. PMID: 22944150. 10.1016/j.ypmed.2012.08.011 22944150
294 Sherwood NE, Crain AL, Martinson BC, . Enhancing long-term weight loss maintenance: 2 year results from the Keep It Off randomized controlled trial. Prev Med. 2013;56(3-4):171–7. PMID: 23276775. 10.1016/j.ypmed.2012.12.014 23276775
295 Silva MN, Vieira PN, Coutinho SR, . Using self-determination theory to promote physical activity and weight control: a randomized controlled trial in women. J Behav Med. 2009. PMID: 20012179. 10.1007/s10865-009-9239-y 20012179
296 Simpson SA, McNamara R, Shaw C, . A feasibility randomised controlled trial of a motivational interviewing-based intervention for weight loss maintenance in adults. Health Technol Assess. 2015;19(50):v–vi, xix–xxv, 1–378. PMID: 26168409. 10.3310/hta19500 26168409
297 Sjostrom L, Rissanen A, Andersen T, . Randomised placebo-controlled trial of orlistat for weight loss and prevention of weight regain in obese patients. European Multicentre Orlistat Study Group. Lancet. 1998;352(9123):167–72. PMID: 9683204. 10.1016/S0140-6736(97)11509-4 9683204
298 Smith SR, Stenlof KS, Greenway FL, . Orlistat 60 mg reduces visceral adipose tissue: a 24-week randomized, placebo-controlled, multicenter trial. Obesity. 2011;19(9):1796–803. PMID: 21720429. 10.1038/oby.2011.143 21720429
299 Smith TJ, Crombie A, Sanders LF, . Efficacy of orlistat 60 mg on weight loss and body fat mass in US Army soldiers. J Acad Nutr Diet. 2012;112(4):533–40. PMID: 22717217. 10.1016/j.jada.2011.10.006 22717217
300 Stevens VJ, Corrigan SA, Obarzanek E, . Weight loss intervention in phase 1 of the Trials of Hypertension Prevention. The TOHP Collaborative Research Group. Arch Intern Med. 1993;153(7):849–58. PMID: 8466377. 10.1001/archinte.1993.00410070039006 8466377
301 Stevens VJ, Obarzanek E, Cook NR, . Long-term weight loss and changes in blood pressure: results of the Trials of Hypertension Prevention, phase II. Ann Intern Med. 2001;134(1):1–11. PMID: 11187414. 10.7326/0003-4819-134-1-200101020-00007 11187414
302 Svetkey LP, Batch BC, Lin PH, . Cell phone intervention for you (CITY): A randomized, controlled trial of behavioral weight loss intervention for young adults using mobile technology. [Erratum appears in Obesity (Silver Spring). 2016 Feb;24(2):536; PMID: 26813533]. Obesity. 2015;23(11):2133–41. PMID: 26530929. 10.1002/oby.21226 26530929
303 Svetkey LP, Stevens VJ, Brantley PJ, . Comparison of strategies for sustaining weight loss: the weight loss maintenance randomized controlled trial. JAMA. 2008;299(10):1139–48. PMID: 18334689. 10.1001/jama.299.10.1139 18334689
304 Swinburn BA, Carey D, Hills AP, . Effect of orlistat on cardiovascular disease risk in obese adults. Diabetes Obes Metab. 2005;7(3):254–62. PMID: 15811142. 10.1111/j.1463-1326.2004.00467.x 15811142
305 Tsai AG, Wadden TA, Rogers MA, . A primary care intervention for weight loss: results of a randomized controlled pilot study. Obesity. 2010;18(8):1614–8. PMID: 20019680. 10.1038/oby.2009.457 20019680
306 Tuomilehto J, Lindstrom J, Eriksson JG, . Prevention of type 2 diabetes mellitus by changes in lifestyle among subjects with impaired glucose tolerance. N Engl J Med. 2001;344(18):1343–50. PMID: 11333990. 10.1056/NEJM200105033441801 11333990
307 Van Gaal LF, Broom JI, Enzi G, . Efficacy and tolerability of orlistat in the treatment of obesity: a 6-month dose-ranging study. Orlistat Dose-Ranging Study Group. Eur J Clin Pharmacol. 1998;54(2):125–32. PMID: 9626916. 10.1007/s002280050433 9626916
308 van Wier MF, Dekkers JC, Hendriksen IJ, . Effectiveness of phone and e-mail lifestyle counseling for long term weight control among overweight employees. J Occup Environ Med. 2011;53(6):680–6. PMID: 21654441. 10.1097/JOM.0b013e31821f2bbb 21654441
309 Voils C, Olsen M, Gierisch J, . Maintenance of Weight Loss After Initiation of Nutrition Training: A Randomized Trial. Annals Intern Med. 2017;166(7):463–71. PMID: 28241185. 10.7326/M16-2160 28241185
310 von Gruenigen V, Frasure H, Kavanagh MB, . Survivors of uterine cancer empowered by exercise and healthy diet (SUCCEED): a randomized controlled trial. Gynecol Oncol. 2012;125(3):699–704. PMID: 22465522. 10.1016/j.ygyno.2012.03.042 22465522
311 Wadden TA, Foreyt JP, Foster GD, . Weight loss with naltrexone SR/bupropion SR combination therapy as an adjunct to behavior modification: the COR-BMOD trial. Obesity. 2011;19(1):110–20. PMID: 20559296. 10.1038/oby.2010.147 20559296
312 Wadden TA, Hollander P, Klein S, . Weight maintenance and additional weight loss with liraglutide after low-calorie-diet-induced weight loss: the SCALE Maintenance randomized study. [Erratum appears in Int J Obes (Lond). 2015 Jan;39(1):187], [Erratum appears in Int J Obes (Lond). 2013 Nov;37(11):1514], [Erratum appears in Int J Obes (Lond). 2015 Jan;39(1):187; PMID: 25311036]. Int J Obes (Lond). 2013;37(11):1443–51. PMID: 23812094. 10.1038/ijo.2013.120 23812094
313 Wing RR, Tate DF, Gorin AA, . A self-regulation program for maintenance of weight loss. N Engl J Med. 2006;355(15):1563–71. PMID: 17035649. 10.1056/NEJMoa061883 17035649
314 Wing RR, Venditti E, Jakicic JM, . Lifestyle intervention in overweight individuals with a family history of diabetes. Diabetes Care. 1998;21(3):350–9. PMID: 9540015.9540015
315 Wylie-Rosett J, Swencionis C, Ginsberg M, . Computerized weight loss intervention optimizes staff time: the clinical and cost results of a controlled clinical trial conducted in a managed care setting. J Am Diet Assoc. 2001;101(10):1155–62. PMID: 11678486.11678486
316 Yeh MC, Heo M, Suchday S, . Translation of the Diabetes Prevention Program for diabetes risk reduction in Chinese immigrants in New York City. Diabet Med. 2016;33(4):547–51. PMID: 26179569. 10.1111/dme.12848 26179569
317 Young MD, Callister R, Collins CE, . Efficacy of a gender-tailored intervention to prevent weight regain in men over 3 years: A weight loss maintenance RCT. Obesity. 2017;25(1):56–65. PMID: 27925437. 10.1002/oby.21696 27925437
318 Beeken R, Leurent B, Vickerstaff V, . A brief intervention for weight control based on habit-formation theory delivered through primary care: results from a randomised controlled trial. Int J Obes (Lond). 2017;41(2):246–54. PMID: 27867204. 10.1038/ijo.2016.206 27867204
319 Fischer IP. Text message support for weight loss in patients with prediabetes: A randomized clinical trial. Diabetes Care. 2016;39(8):1364–70. 10.2337/dc15-2137 26861922
320 Jenkins DJA, Boucher BA, Ashbury FD, . Effect of Current Dietary Recommendations on Weight Loss and Cardiovascular Risk Factors. J Am Coll Cardiol. 2017;69(9):1103–12. PMID: 28254171. 10.1016/j.jacc.2016.10.089 28254171
321 O’Brien MJ, Perez A, Scanlan AB, . PREVENT-DM Comparative Effectiveness Trial of Lifestyle Intervention and Metformin. Am J Prev Med. 2017;52(6):788–97. PMID: 28237635. 10.1016/j.amepre.2017.01.008 28237635
322 Thomas JG, Raynor HA, Bond DS, . Weight loss in Weight Watchers Online with and without an activity tracking device compared to control: A randomized trial. Obesity. 2017;25(6):1014–21. PMID: 28437597. 10.1002/oby.21846 28437597
323 Ahern AL, Wheeler GM, Aveyard P, . Extended and standard duration weight-loss programme referrals for adults in primary care (WRAP): a randomised controlled trial. Lancet. 2017;389(10085):2214–25. PMID: 28478041. 10.1016/s0140-6736(17)30647-5 28478041
324 Logue E, Sutton K, Jarjoura D, . Transtheoretical model-chronic disease care for obesity in primary care: a randomized trial. Obesity Research. 2005;13(5):917–27.15919846
325 Mensink M, Corpeleijn E, Feskens EJ, . Study on lifestyle-intervention and impaired glucose tolerance Maastricht (SLIM): design and screening results. Diabetes Res Clin Pract. 2003;61(1):49–58. PMID: 12849923.12849923
326 Whelton PK, Appel LJ, Espeland MA, . Sodium reduction and weight loss in the treatment of hypertension in older persons: a randomized controlled trial of nonpharmacologic interventions in the elderly (TONE). TONE Collaborative Research Group. JAMA. 1998;279(11):839–46. PMID: 9515998. 10.1001/jama.279.11.839 9515998
327 Nilsen V, Bakke PS, Gallefoss F. Effects of lifestyle intervention in persons at risk for type 2 diabetes mellitus - results from a randomised, controlled trial. BMC public health. 2011;11:893. 10.1186/1471-2458-11-893 22117618
328 Kumanyika SK, Fassbender JE, Sarwer DB, . One-year results of the Think Health! study of weight management in primary care practices. Obesity. 2012;20(6):1249–57. PMID: 22051940. 10.1038/oby.2011.329 22051940
329 Rodriguez-Cristobal JJ, Alonso-Villaverde C, Panisello JM, . Effectiveness of a motivational intervention on overweight/obese patients in the primary healthcare: a cluster randomized trial. BMC Fam Pract. 2017;18(1):74. PMID: 28633627. 10.1186/s12875-017-0644-y 28633627
330 Phelan S, Hagobian T, Brannen A, . Effect of an Internet-Based Program on Weight Loss for Low-Income Postpartum Women. JAMA. 2017;317(23):2381–91. PMID: 28632867. 10.1001/jama.2017.7119 28632867
331 Yeh HC, Clark JM, Emmons KE, . Independent but coordinated trials: insights from the practice-based Opportunities for Weight Reduction Trials Collaborative Research Group. Clin Trials. 2010;7(4):322–32. PMID: 20573639. 10.1177/1740774510374213 20573639
332 Arzola-Paniagua MA, Garcia-Salgado Lopez ER, Calvo-Vargas CG, . Efficacy of an orlistat-resveratrol combination for weight loss in subjects with obesity: A randomized controlled trial. Obesity. 2016;24(7):1454–63. PMID: 27221771. 10.1002/oby.21523 27221771
333 The Trials of Hypertension Prevention Collaborative Research Group. The effects of nonpharmacologic interventions on blood pressure of persons with high normal levels. Results of the Trials of Hypertension Prevention, Phase I. JAMA. 1992;267(9):1213–20. PMID: 1586398. 10.1001/jama.1992.03480090061028 1586398
334 Uusitupa M, Peltonen M, Lindstrom J, . Ten-year mortality and cardiovascular morbidity in the Finnish Diabetes Prevention Study-secondary analysis of the randomized trial. PLoS ONE. 2009;4(5):e5656. PMID: 19479072 10.1371/journal.pone.0005656 19479072
335 Shea MK, Nicklas BJ, Houston DK, . The effect of intentional weight loss on all-cause mortality in older adults: results of a randomized controlled weight-loss trial. Am J Clin Nutr. 2011;94(3):839–46. PMID: 21775558. 10.3945/ajcn.110.006379 21775558
336 Ratner R, Goldberg R, Haffner S, . Impact of intensive lifestyle and metformin therapy on cardiovascular disease risk factors in the diabetes prevention program. Diabetes Care. 2005;28(4):888–94. PMID: 15793191. 10.2337/diacare.28.4.888 15793191
337 Rubin RR, Knowler WC, Ma Y, . Depression symptoms and antidepressant medicine use in Diabetes Prevention Program participants. Diabetes Care. 2005;28(4):830–7. PMID: 15793181. 10.2337/diacare.28.4.830 15793181
338 Ruusunen A, Voutilainen S, Karhunen L, . How does lifestyle intervention affect depressive symptoms? Results from the Finnish Diabetes Prevention Study. Diabet Med. 2012;29(7):e126–32. PMID: 22313027. 10.1111/j.1464-5491.2012.03602.x 22313027
339 le Roux CW, Astrup A, Fujioka K, . 3 years of liraglutide versus placebo for type 2 diabetes risk reduction and weight management in individuals with prediabetes: a randomised, double-blind trial. Lancet. 2017. PMID: 28237263. 10.1016/S0140-6736(17)30069-7 28237263
340 Lindstrom J, Peltonen M, Eriksson JG, . Improved lifestyle and decreased diabetes risk over 13 years: Long-term follow-up of the randomised Finnish Diabetes Prevention Study (DPS). Diabetologia. 2013;56(2):284–93. PMID: 23093136. 10.1007/s00125-012-2752-5 23093136
341 Diabetes Prevention Program Research Group, Crandall J, Schade D, . The influence of age on the effects of lifestyle modification and metformin in prevention of diabetes. J Gerontol A Biol Sci Med Sci. 2006;61A(10):1075–81. PMID: 17077202 10.1093/gerona/61.10.1075 17077202
342 West DS, Prewitt TE, Bursac Z, . Weight loss of black, white, and Hispanic men and women in the diabetes prevention program. Obesity (Silver Spring). 2008;16(6):1413–20. PMID: 18421273 10.1038/oby.2008.224 18421273
343 Kumanyika SK, Espeland MA, Bahnson JL, . Ethnic comparison of weight loss in the Trial of Nonpharmacologic Interventions in the Elderly. Obes Res. 2002;10(2):96–106. PMID: 11836455. 10.1038/oby.2002.16 11836455
344 Guo F, Garvey WT. Cardiometabolic Disease Staging Predicts Effectiveness of Weight Loss Therapy to Prevent Type 2 Diabetes: Pooled Results From Phase III Clinical Trials Assessing Phentermine/Topiramate Extended Release. Diabetes Care. 2017. PMID: 28455281. 10.2337/dc17-0088 28455281
345 Peirson L, Douketis J, Ciliska D, . Treatment for overweight and obesity in adult populations: a systematic review and meta-analysis. CMAJ Open. 2014;2(4):E306–17. PMID: 25485258. 10.9778/cmajo.20140012 25485258
346 Peirson L, Fitzpatrick-Lewis D, Ciliska D, . Strategies for weight maintenance in adult populations treated for overweight and obesity: a systematic review and meta-analysis. CMAJ Open. 2015;3(1):E47–54. PMID: 25844369. 10.9778/cmajo.20140050 25844369
347 Nuffer W, Trujillo JM, Megyeri J. A Comparison of New Pharmacological Agents for the Treatment of Obesity. Ann Pharmacother. 2016;50(5):376–88. PMID: 26887340. 10.1177/1060028016634351 26887340
348 Khera R, Murad MH, Chandar AK, . Association of Pharmacological Treatments for Obesity With Weight Loss and Adverse Events: A Systematic Review and Meta-analysis. JAMA. 2016;315(22):2424–34. PMID: 27299618. 10.1001/jama.2016.7602 27299618
349 Wijnhoven HA, van Zon SK, Twisk J, . Attribution of causes of weight loss and weight gain to 3-year mortality in older adults: results from the Longitudinal Aging Study Amsterdam. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2014;69(10):1236–43. PMID: 24522392. 10.1093/gerona/glu005 24522392
350 French SA, Folsom AR, Jeffery RW, . Prospective study of intentionality of weight loss and mortality in older women: the Iowa Women’s Health Study. Am J Epidemiol. 1999;149(6):504–14. PMID: 10084239.10084239
351 Williamson DF, Pamuk E, Thun M, . Prospective study of intentional weight loss and mortality in overweight white men aged 40-64 years. Am J Epidemiol. 1999;149(6):491–503. PMID: 10084238.10084238
352 Sorensen TI, Rissanen A, Korkeila M, . Intention to lose weight, weight changes, and 18-y mortality in overweight individuals without co-morbidities. PLoS medicine. 2005;2(6):e171. PMID: 15971946. 10.1371/journal.pmed.0020171 15971946
353 Yaari S, Goldbourt U. Voluntary and involuntary weight loss: associations with long term mortality in 9,228 middle-aged and elderly men. Am J Epidemiol. 1998;148(6):546–55. PMID: 9753009.9753009
354 Williamson DF, Pamuk E, Thun M, . Prospective study of intentional weight loss and mortality in never-smoking overweight US white women aged 40-64 years. Am J Epidemiol. 1995;141(12):1128–41. PMID: 7771451.7771451
355 Wannamethee SG, Shaper AG, Walker M. Overweight and obesity and weight change in middle aged men: impact on cardiovascular disease and diabetes. J Epidemiol Community Health. 2005;59(2):134–9. PMID: 15650145. 10.1136/jech.2003.015651 15650145
356 Gregg EW, Gerzoff RB, Thompson TJ, . Intentional weight loss and death in overweight and obese U.S. adults 35 years of age and older. Ann Intern Med. 2003;138(5):383–9. PMID: 12614090. 10.7326/0003-4819-138-5-200303040-00007 12614090
357 Parker ED, Folsom AR. Intentional weight loss and incidence of obesity-related cancers: the Iowa Women’s Health Study. Int J Obes Relat Metab Disord. 2003;27(12):1447–52. PMID: 14634673. 10.1038/sj.ijo.0802437 14634673
358 Danaei G, Robins JM, Young JG, . Weight Loss and Coronary Heart Disease: Sensitivity Analysis for Unmeasured Confounding by Undiagnosed Disease. Epidemiology. 2016;27(2):302–10. PMID: 26628428. 10.1097/EDE.0000000000000428 26628428
359 Courcoulas AP, Goodpaster BH, Eagleton JK, . Surgical vs medical treatments for type 2 diabetes mellitus: a randomized clinical trial. JAMA Surg. 2014;149(7):707–15. PMID: 24899268. 10.1001/jamasurg.2014.467 24899268
360 Chang SH, Stoll CR, Song J, . The effectiveness and risks of bariatric surgery: an updated systematic review and meta-analysis, 2003-2012. JAMA Surg. 2014;149(3):275–87. PMID: 24352617. 10.1001/jamasurg.2013.3654 24352617
361 Sarkhosh K, Switzer NJ, El-Hadi M, . The impact of bariatric surgery on obstructive sleep apnea: a systematic review. Obes Surg. 2013;23(3):414–23. PMID: 23299507. 10.1007/s11695-012-0862-2 23299507
362 Sarwer DB, Wadden TA, Moore RH, . Changes in quality of life and body image after gastric bypass surgery. Surg Obes Relat Dis. 2010;6(6):608–14. PMID: 20947446. 10.1016/j.soard.2010.07.015 20947446
363 Dawes AJ, Maggard-Gibbons M, Maher AR, . Mental Health Conditions Among Patients Seeking and Undergoing Bariatric Surgery: A Meta-analysis. JAMA. 2016;315(2):150–63. PMID: 26757464. 10.1001/jama.2015.18118 26757464
364 King WC, Chen JY, Belle SH, . Change in Pain and Physical Function Following Bariatric Surgery for Severe Obesity. JAMA. 2016;315(13):1362–71. PMID: 27046364. 10.1001/jama.2016.3010 27046364
365 Kamvissi-Lorenz V, Raffaelli M, Bornstein S, . Role of the Gut on Glucose Homeostasis: Lesson Learned from Metabolic Surgery. Curr Atheroscler Rep. 2017;19(2):9. PMID: 28185153. 10.1007/s11883-017-0642-5 28185153
366 Leblanc ES, O’Connor E, Whitlock EP, . Effectiveness of primary care-relevant treatments for obesity in adults: a systematic evidence review for the U.S. Preventive Services Task Force. Annals of Internal Medicine. 2011;155(7):434–47. PMID: 21969342. 10.7326/0003-4819-155-7-201110040-00006 21969342
367 Lin JS, O’Connor E, Evans CV, . Behavioral counseling to promote a healthy lifestyle in persons with cardiovascular risk factors: a systematic review for the U.S. Preventive Services Task Force. Annals of Internal Medicine. 2014;161(8):568–78. PMID: 25155549. 10.7326/M14-0130 25155549
368 Wing RR, Phelan S. Long-term weight loss maintenance. Am J Clin Nutr. 2005;82:(1 Suppl):222s–5s. PMID: 16002825.16002825
369 Weiss EC, Galuska DA, Kettel Khan L, . Weight regain in U.S. adults who experienced substantial weight loss, 1999-2002. Am J Prev Med. 2007;33(1):34–40. PMID: 17572309. 10.1016/j.amepre.2007.02.040 17572309
370 Dulloo AG, Montani JP. Pathways from dieting to weight regain, to obesity and to the metabolic syndrome: an overview. Obes Rev. 2015;16: Suppl 1:1–6. PMID: 25614198. 10.1111/obr.12250 25614198
371 Mackie GM, Samocha-Bonet D, Tam CS. Does weight cycling promote obesity and metabolic risk factors? Obes Res Clin Pract. 2017;11(2):131–9. PMID: 27773644. 10.1016/j.orcp.2016.10.284 27773644
372 DerSarkissian M, Bhak RH, Huang J, . Maintenance of weight loss or stability in subjects with obesity: a retrospective longitudinal analysis of a real-world population. Curr Med Res Opin. 2017;33(6):1105–10. PMID: 28294635. 10.1080/03007995.2017.1307173 28294635
373 Krist AH, Baumann LJ, Holtrop JS, . Evaluating Feasible and Referable Behavioral Counseling Interventions. Am J Prev Med. 2015;49(3 Suppl 2):S138–49. 10.1016/j.amepre.2015.05.009 26296548
374 Padwal RS, Pajewski NM, Allison DB, . Using the Edmonton obesity staging system to predict mortality in a population-representative cohort of people with overweight and obesity. CMAJ: Canadian Medical Association journal = journal de l’Association medicale canadienne. 2011;183(14):E1059–66. 10.1503/cmaj.110387
375 Sharma AM, Campbell-Scherer DL. Redefining obesity: Beyond the numbers. Obesity (Silver Spring). 2017;25(4):660–1. 10.1002/oby.21801 28349662
376 Asselin J, Salami E, Osunlana AM, . Impact of the 5As Team study on clinical practice in primary care obesity management: a qualitative study. CMAJ Open. 2017;5(2):E322–E9. PMID: 28450428. 10.9778/cmajo.20160090 28450428
377 Garvey WT, Mechanick JI, Brett EM, . American Association of Clinical Endocrinologists and American College of Endocrinology Comprehensive Clinical Practice Guidelines for Medical Care of Patients with Obesity. Endocr Pract. 2016;22: Suppl 3:1–203. PMID: 27219496. 10.4158/EP161365.GL 27219496
378 Rubin RR, Peyrot M, Wang NY, . Patient-reported outcomes in the practice-based opportunities for weight reduction (POWER) trial. Qual Life Res. 2013;22(9):2389–98. PMID: 23515902. 10.1007/s11136-013-0363-3 23515902
379 Florez H, Pan Q, Ackermann RT, . Impact of lifestyle intervention and metformin on health-related quality of life: the diabetes prevention program randomized trial. J Gen Intern Med. 2012;27(12):1594–601. PMID: 22692637. 10.1007/s11606-012-2122-5 22692637
380 Ackermann RT, Edelstein SL, Narayan KM, . Changes in health state utilities with changes in body mass in the Diabetes Prevention Program. Obesity (Silver Spring). 2009;17(12):2176–81. PMID: 19390518 10.1038/oby.2009.114 19390518
381 Demark-Wahnefried W, Colditz GA, Rock CL, . Quality of life outcomes from the Exercise and Nutrition Enhance Recovery and Good Health for You (ENERGY)-randomized weight loss trial among breast cancer survivors. Breast Cancer Res Treat. 2015;154(2):329–37. PMID: 26518022. 10.1007/s10549-015-3627-5 26518022
382 McCarroll ML, Armbruster S, Frasure HE, . Self-efficacy, quality of life, and weight loss in overweight/obese endometrial cancer survivors (SUCCEED): a randomized controlled trial. Gynecol Oncol. 2014;132(2):397–402. PMID: 24369301. 10.1016/j.ygyno.2013.12.023 24369301
383 Sarwer DB, Moore RH, Diewald LK, . The impact of a primary care-based weight loss intervention on the quality of life. Int J Obes (Lond). 2013;37: Suppl 1:S25–30. PMID: 23921778. 10.1038/ijo.2013.93 23921778
384 Swencionis C, Wylie-Rosett J, Lent MR, . Weight change, psychological well-being, and vitality in adults participating in a cognitive-behavioral weight loss program. Health Psychol. 2013;32(4):439–46. PMID: 22888821. 10.1037/a0029186 22888821
385 Sedjo RL, Flatt SW, Byers T, . Impact of a behavioral weight loss intervention on comorbidities in overweight and obese breast cancer survivors. Support Care Cancer. 2016;24(8):3285–93. PMID: 26945570. 10.1007/s00520-016-3141-2 26945570
386 Berrigan D, Troiano RP, Graubard BI. BMI and mortality: the limits of epidemiological evidence. Lancet. 2016;388(10046):734–6. PMID: 27423263. 10.1016/S0140-6736(16)30949-7 27423263
387 Knudtson MD, Klein BE, Klein R, . Associations with weight loss and subsequent mortality risk. Ann Epidemiol. 2005;15(7):483–91. PMID: 16029840. 10.1016/j.annepidem.2004.12.003 16029840
388 Fontanarosa P, Christiansen S. Conventional Units and SI Units in JAMA and the Archives Journals. In: AMA Manual of Style: A Guide for Authors and Editors (10th edition). Oxford, UK: Oxford University Press; 2007. PMID: None.
389 Parker DR, Evangelou E, Eaton CB. Intraclass correlation coefficients for cluster randomized trials in primary care: the cholesterol education and research trial (CEART). Contemp Clin Trials. 2005;26(2):260–7. PMID: 15837446. 10.1016/j.cct.2005.01.002 15837446
390 IntHout J, Ioannidis JP, Borm GF. The Hartung-Knapp-Sidik-Jonkman method for random effects meta-analysis is straightforward and considerably outperforms the standard DerSimonian-Laird method. BMC Med Res Methodol. 2014;14:25. PMID: 24548571. 10.1186/1471-2288-14-25 24548571
391 Hartung J, Knapp G. A refined method for the meta-analysis of controlled clinical trials with binary outcome. Stat Med. 2001;20(24):3875–89. PMID: 11782040.11782040
392 Coughlin JW, Brantley PJ, Champagne CM, . The impact of continued intervention on weight: Five-year results from the weight loss maintenance trial. Obesity. 2016;24(5):1046–53. PMID: 26991814. 10.1002/oby.21454 26991814