# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Caitlyn Senger, MPH, for assistance with data abstraction; Smyth Lai, MLS, for creating and conducting literature searches; and Katherine Essick, BS, for her editorial support. The authors also thank Iris Mabry-Hernandez, MD, MPH, at AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic discussions; George A. Bray, MD, Stephanie Fitzpatrick, PhD, Katherine Flegal, PhD, James O. Hill, PhD, Xavier Pi-Sunyer, MD, Nancy E. Sherwood, PhD, and Thomas A. Wadden, PhD, who provided expert review of the draft report; and four federal partners, specifically the Centers for Disease Control and Prevention, Department of Veterans Affairs, National Cancer Institute, and National Institutes of Health, for providing federal partner review of the draft report.