# Chapter 4 Discussion

## Summary of Evidence

We conducted this systematic review to assist the USPSTF in updating its 2012 recommendation on screening for and management of adult obesity.^196^ The current review focused specifically on the effectiveness and harms of primary care–relevant weight loss and weight loss maintenance interventions. We included 124 unique trials, two-thirds of which (k=83) were published after the 2011 USPSTF review. More studies were included for each KQ, and the included trials are of longer duration. The effect estimate found for weight loss in our updated systematic review is slightly smaller in magnitude compared with the 2011 review on this topic, and the evidence on health outcomes and intermediate outcomes remains sparse.^197^

Table 18 summarizes the findings and our assessment of the strength of evidence for this review. We found that behavior-based weight loss interventions were associated with more weight loss and that behavior-based weight loss maintenance interventions were associated with less weight regain than control conditions over 12 to 18 months. Although addressed in fewer trials, weight loss or weight loss maintenance interventions lasting up to 36 months reported significantly greater weight loss or weight loss maintenance in the intervention participants compared with control participants. Given the consistency in the effect estimates and precision in those estimates over time, we are moderately confident that our pooled estimates for weight loss and weight loss maintenance from behavior-based interventions lie close to the true effects. However, pooled analyses resulted in considerable statistical heterogeneity, reflecting the clinical heterogeneity across studies. The heterogeneity in each individual intervention arm and differences in the populations, settings, and trial quality made it difficult to disentangle what variables might be driving larger effects. The trials used various modes of intervention delivery (group, individual, mixed, technology-based, and print-based) but were generally designed to help participants achieve or maintain a 5 percent or greater weight loss through a combination of dietary changes (including specific caloric goals) and increased physical activity (generally promoting at least 150 minutes of moderate-intensity activity per week). In addition, most interventions encouraged self-monitoring of weight and provided additional tools to assist with weight loss or maintenance (e.g., pedometers, food scales, exercise videos).

Table 18 Summary of Evidence, by Key Question and Intervention Type

KQ | Intervention | No. of Studies (k), no. of Observations (n) | Summary of Findings | Consistency/Precision | Other Limitations | Strength of Evidence | Applicability
KQ1: Health outcomes | Behavior-based weight loss | k=18 RCTs (13 trials identified in update) n=9543 | All-cause mortality: 4 trials reported no differences between groups at up to 16 years FU. CVD: 2 trials reported no differences between groups in the incidence of CVD events after 3 and 10 years of FU. QOL: 15 trials reported no consistent effects at 1 year or greater FU. | Reasonably consistent/Imprecise | Few trials reported CVD morbidity or CVD- or all-cause related-mortality with longer term followup or sufficient power to detect differences. QOL variably measured and few trials reported absolute values. No reporting bias suspected | Low for benefit | Trials reporting all-cause mortality and CVD events were limited to adults with obesity with prediabetes or prehypertension.
KQ1: Health outcomes | Behavior-based weight maintenance | k=2 RCTs (both trials identified in update) n=366 | QOL: No consistent effects of maintenance interventions on QOL after 1- to 2-years FU. | Inconsistent/Imprecise | No trials reported health outcomes beyond QOL. QOL data limited and poorly reported. No reporting bias suspected | Insufficient | Design of trials was mixed with one including a weight loss intervention for all participants within trial and the other recruiting participants after ≥5% weight loss in past year. Trials represented a general, unselected population with BMI ≥30 (in trial with weight loss before study entry) to ≥35 kg/m^2^ (in trial with weight loss as part of study).
KQ1: Health outcomes | Medication-based weight loss | k=10 RCTs (8 trials identified in update) n=17,315 | CVD: 2 trials reported few events in either group. QOL: 10 trials generally reported improved QOL scores in those randomized to medications compared to placebo. | Reasonably consistent/Imprecise | Number of CVD events low, with insufficient power to detect differences. Trials with high drop-out rates and QOL absolute values not reported in 4/10 trials. In studies with value, differences were small and of unclear clinical significance. No reporting bias suspected | Low for benefit | Trials were of highly selected populations with multiple exclusions relevant to health outcomes (e.g. history of serious medical conditions, CV events, psychiatric illness)
KQ1: Health outcomes | Medication-based weight maintenance | k=0 | NA | NA | NA | NA | NA
KQ2: Weight Outcomes | Behavior-based weight loss | k=80 RCTs (60 trials identified in update) n=24,101 | Pooled results of 67 trials indicated greater weight loss from behavior-based weight loss interventions vs. control conditions at 12-18 months (MD, −2.39 kg [95% CI, −2.86 to −1.93]; k=67; n=22,065; I^2^=90.0%). Mean absolute changes in weight ranged from −0.5 kg (1.1 lb) to −9.3 kg (20.5 lb) in intervention participants and from 1.4 kg (3.1 lb) to −5.6 (12.3 lb) in control participants. Weight change at FU beyond 12-18 months was not as well reported but found consistent, although generally attenuated, effects over time. Heterogeneity within each individual intervention arm confounded with differences in the populations, settings, and trial quality, making it nearly impossible to disentangle what variables might be driving larger effects. A meta-analysis of 38 trials reported that intervention participants had a 1.94 times greater probability of losing 5% of their initial weight vs. control groups over 12-18 months (RR, 1.94 [95% CI, 1.70 to 2.22], k=38; n=12,231, I^2^=67.2%), which translated into a NNT of 8. | Reasonably consistent/Reasonably precise | Few trials reported baseline cardiovascular risk status of participants. Very few trials reported differences in weight change at longer FU (e.g., ≥2 years) or after a period of no intervention to examine maintenance of effects. Considerable statistical heterogeneity in all pooled analyses. No reporting bias suspected | Moderate for benefit | Majority took place in US in community-based or research settings. Few included primary care involvement. Interventions were highly variable in delivery mode but used similar behavior change strategies and messages. Most interventions were 1-2 years in duration and over one-third were group-based interventions. Half of trials represented an unselected population eligible for participation based on BMI. The remaining half recruited adults who were overweight or with obesity and at high CV risk (prediabetes, hypertension, high-normal blood pressure, metabolic syndrome). Median BMI was 33.4 kg/m^2^ across trials. Median age was 50.3 years.
KQ2: Weight Outcomes | Behavior-based weight maintenance | k=9 (6 trials identified in update) n=2701 | Pooled results of 8 trials indicated greater weight maintenance from behavior-based maintenance interventions than control conditions at 12-18 months (MD, −1.59 kg [3.5 lb] [95% CI, −2.38 to −0.79]; k=8; n=1408; I^2^=26.8%). 8 of 9 trials reported that both intervention and control participants regained weight over 12-18 months of maintenance, with the intervention participants experiencing less weight regain; the remaining trial noted that both groups continued to lose weight with no differences between groups. | Reasonably consistent/Reasonably precise | Only 3 trials provided data beyond 18 months FU. No reporting bias suspected | Moderate for benefit | Design of trials was mixed with some including a weight loss intervention for all participants within the trial (k=6) and the others recruiting participants after documented or self-reported weight loss. Majority took place in US in community-based or research settings and few included primary care involvement. All but one of the trials represented a general, unselected population. Mean BMI at enrollment in weight loss phase was 34.2 kg/m^2^. Median age was 49.2 years.
KQ2: Weight Outcomes | Medication-based weight loss | k= 20 (9 trials identified in update) n= 25,742 | Trials indicated greater weight loss from weight loss medications vs. placebo at 12-18 months (mean/LSM MD between medication and placebo ranged from −1.0 to −5.8 kg [2.2 to 12.8 lb]; no meta-analysis conducted). Absolute changes in weight ranged from mean/LSM of −3.3 to −10.6 kg [7.3 to 23.4 lb] in medication participants and from −0.9 to −7.6 kg [2.0 to 16.8 lb] in placebo participants over 12-18 months. Medication participants had a 1.2 to 3.9 times greater probability of losing 5% of their initial weight vs. placebo participants over 12-18 months. | Reasonable consistent/Imprecise | Trials generally had low followup (10 trials with ≥35% attrition) and most were of short duration (≤13 months FU). Limited data reporting (only report LSM), no between-group difference in mean change or variability around difference) Very few trials reported differences in weight change at longer followup (≥2 years) or after a period of no intervention to examine maintenance of effects. No reporting bias suspected | Low for benefit | One-half took place in the US, with the majority occurring in academic, research, or specialty care settings. Few included primary care involvement. Nearly one-half had run-in periods to assess medication compliance. Most interventions were 1-2 years in duration. Median BMI was 36.1 kg/m^2^ and median age was 45 years.
KQ2: Weight Outcomes | Medication-based weight maintenance | k= 3 (1 trial identified in update) n= 1273 | Trials indicate greater weight maintenance in medication than placebo participants over 12 to 36 months (MD ranged from −0.6 to −3.5; no meta-analysis conducted). Absolute changes ranged from weight loss of 6.3 kg [14.0 lb] to gain of 5.1 kg [11.2 lb] in medication participants vs. gain of 0.1 to 7.1 kg [0.2 to 15.7 lb] in placebo participants. | Reasonable consistent/Imprecise | Trials generally had low followup (23%-30% attrition or NR) and were of short duration (2 trials of only 12-13 months duration). No reporting bias suspected | Insufficient | All were conducted in research clinics in the US, Canada, and Scandinavia. Participants were required to lose 5 to 8 percent of baseline weight prior to randomization. The mean baseline Median BMI was 35.6 kg/m^2^ and median age was 46.2 years.
KQ2: Intermed-iate Outcomes | Behavior-based weight loss | k=22 RCTs (17 trials identified in update) n=9135 | Incident diabetes (13 trials, n=4095): Absolute cumulative incidence of diabetes at up to 3 years FU ranged from 0%-15% in IG and 0%-28.9% in CG. DPP and Finnish DPS found statistically significant lower incidence of developing diabetes at 3-9 years; no other trial found differences between groups but trials generally had smaller sample sizes and shorter FU. Other IOs: Prevalence of hypertension, metabolic syndrome, use of CVD medications, and estimated 10-year risk of CVD were sparsely reported. Limited evidence from larger trials for reduced prevalence of hypertension and use of CVD medications; limited and mixed results for metabolic syndrome and 10-year CVD risk. | Reasonably consistent/Imprecise | Intermediate health outcomes were not well reported. Small size and short duration of many studies limited power to detect differences in intermediate outcomes in majority of studies. No reporting bias suspected | Moderate for benefit (incident diabetes) Low for benefit (other interm-ediate outcomes) | All but one trial reporting incident diabetes was limited to adults with prediabetes.
KQ2: Intermed-iate Outcomes | Behavior-based weight maintenance | k=0 | NA | NA | NA | NA | NA
KQ2: Intermed-iate Outcomes | Medication-based weight loss | k=6 (4 trials identified in update) n=13256 | Incident diabetes (3 trials; n=9484): Absolute cumulative incidence of diabetes at up to 4 years FU ranged from 0%-6% in medication and 1%-11% in placebo arms, which were statistically different for most drugs. Other IOs: 4 trials reported mixed results for use of lipid-lowering and antihypertensive medications, prevalence of metabolic syndrome, and 10-year CVD risk score. | Reasonably consistent^*^/Imprecise | Trials generally had high dropout rates. No reporting bias suspected | Insufficient | 21%-67% of participants had prediabetes.
KQ2: Intermed-iate Outcomes | Medication-based weight maintenance | k=1 (no trials identified in update) n=309 | Incident diabetes: Absolute cumulative incidence of diabetes at 3 years FU was 5% in medication and 11% in placebo arms, which was statistically different. | NA | Only 1 trial with 35% dropout No reporting bias suspected | Insufficient | 26% of participants had prediabetes.
KQ3: Harms | Behavior-based weight loss and weight maintenance | k=30 RCTs (28 trials identified in update) n=12824 | There were no serious harms related to the interventions and most trials noted no differences between groups in the rates of adverse events, including cardiovascular events. In the 3 trials large enough to examine musculoskeletal issues between groups, results were mixed. | Reasonably consistent/Precise | Harms sparsely reported for included trials. Few details provided about how harms were recorded and specific events that occurred. Did not include observational evidence on harms related to intentional weight loss. No reporting bias suspected^†^ | Low for harm | Applicable to US primary care population.
KQ3: Harms | Medication-based weight loss and weight maintenance | k=33 RCTs and 2 observational studies (17 studies identified in update) n=239428 | SAEs were relatively uncommon and generally similar between groups. Those randomized to medications experienced more adverse events, which resulted in higher drop out rates in the medication arms than in the placebo arms. | Reasonably consistent/Imprecise | Few conducted statistical testing of differences between groups; harms listed on labels not well evaluated No reporting bias suspected | Moderate for harm | Highly selected group chosen for low risk of serious AEs.

* Data for incident diabetes is consistent but data for CVD are inconsistent

† Suspected in one case for a behavior-based maintenance trial

Abbreviations: AE = adverse event; BMI = body mass index; CG = control group; CI = confidence interval; CV = cardiovascular; CVD = cardiovascular disease; DPP = Diabetes Prevention Program; DPS = Diabetes Prevention Study; EPC = evidence-based practice center; FU = followup; IG = intervention group; IO = intermediate outcome; kg = kilogram(s); kg/m^2^ = kilogram per square meter; lb. = pound(s); LSM = least squares mean; MD = mean difference; NA = not applicable; NNT = number needed to treat; No. = number; NR = not reported; QOL = quality of life; RCT = randomized controlled trial; RR = risk ratio; SAE = serious adverse event

We have moderate confidence that behavior-based weight loss interventions are associated with a decreased risk of progressing from prediabetes to type 2 diabetes at up to 36 months of followup. The association between weight loss interventions and other intermediate health outcomes (e.g., CVD risk factors) was sparsely reported and considered to have low strength of evidence. Weight loss maintenance interventions did not report on any intermediate outcomes.

We have limited confidence in the evidence regarding the effects of behavior-based weight loss interventions on longer-term health outcomes, including all-cause mortality, CVD events, and QOL. Although some of the studies reporting these outcomes were generally large and of good quality, most were still underpowered to detect differences during followup. Therefore, although behavior-based weight loss interventions consistently showed no difference in all-cause mortality and CVD events, we rated the strength of evidence as low. Studies of behavior-based weight loss and maintenance reported inconsistent effects on QOL.

Overall, a limited number of trials reported on adverse events of behavior-based weight loss and weight loss maintenance interventions but none reported serious harms related to the interventions. Most trials noted no differences between arms in the rates of adverse events, including cardiovascular events. Results were mixed in the three trials large enough to examine musculoskeletal issues between arms. Given the small body of evidence related to harms and inconsistent reporting, we have low confidence that our body of evidence represents the actual incidence of harms related to behavior-based weight interventions.

We found that weight loss medications were associated with more weight loss and weight loss maintenance over 12 to 18 months compared with those randomized to placebo. While fewer trials addressed longer-term interventions, weight loss or weight loss maintenance interventions lasting up to 48 months reported significantly greater effects in the medication arms compared with placebo. Although the effects are consistent, we were unable to pool data due to the small number of trials for each medication, methodological variability, missing data regarding dispersion, and poor followup (often <65%). Because of these issues, we rated the strength of evidence as low. The medication trials have limited applicability given that most participants had to meet narrowly defined inclusion criteria. In addition, many studies required participants to show compliance with taking pills and/or meet weight loss goals before study entry.

Weight loss medications in populations with a 20 to 70 percent prevalence of prediabetes at study enrollment were associated with a decreased incidence of progression to type 2 diabetes compared with placebo at up to 48 months of followup. Although the effect estimates were consistent, they were imprecise and limited by a high degree of withdrawals. We therefore rated the strength of evidence as low. Pooled data from over 3000 participants who were overweight or had obesity in three RCTs of phentermine/topiramate extended release (CONQUER, EQUIP, and SEQUEL) were not included in this review due to recruitment of an excluded population in one trial; however, pooled findings were consistent with those of this review—a decrease in risk of developing diabetes, especially in those at highest risk, in those randomized to the weight loss medication.^344^ The association between weight loss medications and other intermediate health outcomes (CVD risk factors) was sparsely reported with mixed findings.

In terms of longer-term health outcomes with medications, the evidence related to CVD outcomes was sparse, precluding any definite conclusions. Studies of weight loss medications reported improvements on obesity-specific QOL measures; however, actual QOL scores were often missing, and when available, differences were small and of unclear significance. We rated the strength of evidence as low given these issues and the high dropout rates in studies.

All of the medication trials included for weight loss or weight loss maintenance outcomes also reported on potential harms; in addition, we examined additional trials for potential harms (often excluded from weight-based outcome evidence due to short duration of followup and/or quality issues). Serious adverse events were relatively uncommon and rates were generally similar between groups. However, those randomized to medications consistently experienced more adverse events in general, resulting in higher withdrawal rates in the medication arms than in the placebo arms. The absolute incidence of events was imprecise, ranging from 63 to 96 percent. Few trials conducted statistical testing of differences between groups; those that did usually noted a statistically greater number of adverse events in those on medications. In addition, many of the trials selected participants at low risk of harms (due to restrictive inclusion criteria), potentially underestimating the rate of harms that will occur among the general population. Despite the lack of statistical testing, we feel moderately confident that there are more harms associated with weight loss medications than with placebo.

## Comparison With Findings From Other Systematic Reviews

The findings of our review are consistent with findings of other similarly scoped, recent systematic reviews. A systematic review conducted for the Canadian Task Force on Preventive Health Care found similar results for the effects of behavior-based interventions on weight loss. An overall pooled effect of 3.02-kg greater weight loss was found among intervention participants, with greater rates of losing at least 5 percent of baseline body weight (RR, 1.77 [95% CI, 1.58 to 1.99]), with a NNT of 5 (95% CI, 4 to 7). This review also concluded that for individuals who are at risk of type 2 diabetes, weight loss interventions could delay the onset of type 2 diabetes. Results on the effect of behavior-based weight loss maintenance interventions (pooled MD, −1.56 kg [95% CI, −3.10 to −0.02]) and orlistat for weight loss (pooled MD, −3.05 kg [95% CI, −3.75 to −2.35]) were also consistent with our findings.^345,^ ^346^

Compared with other recent reviews of the effectiveness of new weight loss medications, similar rates of weight loss were cited, along with high rates of adverse events in participants.^169,^ ^347,^ ^348^

## Observational Evidence on the Association Between Intentional Weight Loss and Health Outcomes

Due to sparse direct trial evidence on the effect of weight loss interventions on health outcomes (KQ1), we present observational evidence to contextualize our results (Appendix A). There is little evidence to suggest that intentional weight loss among those who are overweight, especially those with BMIs less than 28 kg/m^2^, is associated with decreased mortality.^349-353^ Intentional weight loss among those who have obesity may lead to a small decrease in mortality risk, although the literature is conflicting, especially for men and individuals without obesity-related comorbidities.^354-356^ The literature is scant and limited on the effects of intentional weight loss on other outcomes such as CVD and cancer.^357,^ ^358^

In persons who undergo bariatric surgery, there are significant improvements in diabetes,^359,^ ^360^ sleep apnea,^360,^ ^361^ QOL,^362^ depression,^363^ and pain and physical function.^364^ Data on long-term health outcomes, such as mortality, CVD, and cancer, are still lacking. However, the amount of weight loss that occurs with weight loss surgery is much greater than what can usually be achieved with behavior-based weight loss interventions, and only persons with severe obesity or obesity with comorbidities are candidates for bariatric surgery. In addition, there are metabolic changes that occur after surgery, independent of weight loss, that could contribute to improvements in health outcomes among those who undergo surgery.^365^

## Considerations for Applicability of Findings

Recruitment in the majority of behavior-based trials had some degree of self-selection, so participants were likely to have been more motivated to change their behaviors than individuals not represented in these trials, making the findings most applicable to those who are motivated to change their body size. We saw generally high rates of retention (>80% at 12 months) and adherence in the behavior-based intervention trials—rates which may not be seen in real-world scenarios.

The vast majority of trials were conducted in the United States. The trials included adults who were a range of ages and BMIs. The risk status of the populations varied broadly, with one-half of the trials requiring participants to have increased or subclinical cardiovascular risk or cancer risk and the other half selecting participants only on weight status (comorbidities of participants were variably reported). Race/ethnicity were inconsistently reported and only a small proportion of trials focused specifically on underrepresented racial/ethnic groups. Most trials did not stratify results by any of these important factors (BMI, age, race/ethnicity, health status). Although we were limited in examining effects by subgroup due to population heterogeneity, we noted through meta-regression that those who had increased cardiovascular risk (e.g., hypertension, prediabetes, metabolic syndrome) had greater weight loss than those who were unselected. However, this finding is limited by the variability between intervention components and other population characteristics (e.g., age) among the trials. Despite the limitations related to examination of specific population subgroups, we have found no evidence to suggest the findings of the behavior-based weight loss and maintenance interventions review would not be applicable to the U.S. primary care population; however, the magnitude of the effects may be slightly lower when applied to general practice.

It is nearly impossible to determine to what extent specific population and intervention characteristics were driving intervention effects given the within- and between-study heterogeneity in population, intervention, and broader study characteristics. Few interventions included interaction with a PCP, and among those that did, the level of PCP interaction was variable. In addition, no two studies had exactly the same intervention messaging, schedule, or mode delivery, although many built off of learnings from earlier trials (e.g., the DPP^205^). We applied a priori subgroup analyses and meta-regression in an effort to identify whether any particular intervention modes or characteristics were driving larger effects. We did not find that the main intervention mode (group vs. individual vs. technology vs. mixed), the involvement of a PCP, or the duration of the intervention significantly affected the direction or magnitude of the benefit. In contrast to our previous review, we did not find that a greater number of sessions in the first year were associated with greater weight loss. However, most of the interventions had at least 12 sessions within the first year of the intervention. In addition, there were many more trials in this update that focused on technology-based interventions, with few (if any) actual counseling sessions; rather, such studies used multiple contacts with participants via emails, text messages, or social networking applications. Given the inclusion of more interventions with few formal sessions but a high number of contacts (a more inclusive measure than our previous counting of a formal “session”), we also examined the effect of the number of participant contacts. This analysis was also not associated with effect size. The one intervention component that was related to greater weight loss was the inclusion of any use of group sessions in the intervention (whether that was the main mode of delivery or an additional component). While it is possible that including some group interaction creates a social bond that leads to greater weight loss, there were also many other differences among studies (i.e., age of participants, health status of participants, other delivery components), which precludes any firm conclusions about this finding. To fully address whether certain intervention components are more effective would require examination of comparative-effectiveness studies (which were specifically excluded in this review). The ideal counseling intervention for any given individual likely depends on consideration of his or her specific clinical characteristics and preferences.

Most weight loss medication trials included self-selected volunteers who had to meet multiple, highly selective inclusion and exclusion criteria, with many trials requiring specific levels of medication compliance and/or ability to reach weight loss goals prior to randomization. The large number of exclusions (e.g., history of serious medical conditions, CVD events, psychiatric illness) likely resulted in a highly motivated, relatively healthy population. The mean age of the studies was relatively narrow, from 41 to 58 years, and race/ethnicity was reported in just over half the studies, with the majority of participants (>60%) reported as non-Hispanic white. Therefore, it is unclear whether the findings of the review on weight loss medications are generally applicable to the general U.S. primary care population.

## Limitations of Our Approach

The current review excluded studies specifically focused on persons with conditions for which weight loss is considered as part of disease management (e.g., diabetes, polycystic ovarian syndrome). Literature specific to these populations is considered tertiary prevention and therefore not within the scope of the current review. Aspects of the care in these populations generally fall within the domain of other condition-specific reviews within the USPSTF portfolio. We also excluded trials focused on weight gain prevention, including general health promotion, as this evidence is included in separate reviews on counseling for healthful diet and physical activity. Trials of weight management during pregnancy were also excluded. In addition, we did not systematically examine the effectiveness of screening or the best screening approach to identify adults who may be candidates for weight loss interventions (but did examine this body of research contextually) (Appendix A).

Our review was limited to interventions that were conducted in primary care or those that are feasible for referral from primary care. Surgical weight loss interventions or nonsurgical weight loss devices were considered to be outside the scope of primary care–referable interventions. Additionally, we included only trials conducted in developed countries so as to identify the evidence with the highest applicability to current U.S. practice.

We also excluded studies without a true control group and thus did not address the comparative effectiveness of different types of behavior-based interventions. Our requirement was that the behavior-based intervention trials have control groups with no more than quarterly contact via counseling sessions or generic brochures to be reflective of the current standard of care within the United States. This criterion led to the exclusion of 81 comparative-effectiveness trials, which likely have key data for determining whether certain intervention modes or components are more effective. We did examine this issue by describing and synthesizing intervention characteristics; however, doing so for such complex interventions is difficult. The included interventions varied considerably in terms of the mode of delivery, delivery schedule, and providers. However, in many cases, detailed reporting of the number, length, and content of sessions and contacts was lacking, so we had to make several assumptions.

We did not include continuous intermediate outcomes (e.g., continuous measures of blood pressure, cholesterol levels, glucose levels, and cardiorespiratory fitness). Instead, we examined the effects of weight management interventions on the incidence and prevalence of obesity-related conditions such as diabetes, hypertension, dyslipidemia, and sleep apnea. In our previous adult obesity review and cardiovascular prevention reviews for the USPSTF, diet and physical activity counseling interventions were associated with decreases in low-density lipoprotein cholesterol (approximately 2.6 to 4.9 mg/dL), total cholesterol (approximately 2.8 to 5.8 mg/dL), systolic blood pressure (1.3 to 2.5 mm Hg), and diastolic blood pressure (0.5 to 2 mm Hg).^366,^ ^367^ Although we did not formally abstract or analyze these data in this update, the newly included evidence that did report results on these continuous cardiometabolic outcomes are generally of the same magnitude seen previously. In addition, we discuss the association between intentional weight loss and health outcomes in epidemiological studies in order to contextualize the long-term clinical significance of intentional weight loss. Additionally, we did not collect or evaluate any data on costs or cost-effectiveness of the interventions.

Finally, we pooled across a body of literature that was heterogeneous with respect to clinical and demographic characteristics, interventions, and settings. The statistical heterogeneity was considerable (I^2^>85%), indicating the pooled averages should be interpreted with caution and confidence interval estimates should be primarily used to understand the magnitude of effects. In addition, across the trials, there were large SDs relative to the average change, suggesting that some adults showed fairly large reductions in weight, some showed no or modest changes, and some gained weight. In light of the considerable amount of participant withdrawals and missing data, we chose not to present the pooled effects for the weight loss medication trials.

## Limitations of the Studies and Future Research Needs

Although the evidence in the current review indicates that weight loss interventions (both behavior- and medication-based) result in short-term weight loss, there remains a paucity of data on what happens to weight in the long term. Only a limited number of trials reported followup beyond 24 months, and in most of those, ongoing weight loss or maintenance sessions occurred throughout followup. Therefore, relatively little is known about what happens to weight after an active weight or maintenance program intervention ends. Survey data suggest that a minority of individuals are successful at long-term weight loss.^368,^ ^369^

There was also a paucity of data on long-term health outcomes. While it appears that weight loss interventions can reduce diabetes incidence, additional larger trials with longer-term followup are required to understand the full benefits of these interventions on health outcomes and whether those effects are long lasting. Additionally, there were little data on patient-centered outcomes such as QOL and psychological outcomes such as weight stigmatization from both the general public and within the health care system,^98^ eating disorders,^99-101^ and weight fluctuation (“yo-yo” dieting).^370-372^ Future trials should include psychosocial, QOL, and patient-centered outcomes. In addition, future trials should examine whether interventions that focus not only on weight loss, but also on how to best support persons living with obesity regardless of weight loss success, improve these patient-centered outcomes.

In general, the included behavior-based interventions all included similar messages related to energy balance (i.e., gradual increases in moderate-to-vigorous intensity physical activity and healthful dietary patterns following national guidelines) and similar behavior change technique (e.g., goal setting, weighing pros and cons, increasing self-efficacy). In contrast, the specific modes of delivery, including the number and length of sessions and total duration of the interventions, and interventionists varied greatly. More data from well-designed pragmatic trials and better reporting of intervention characteristics to facilitate evaluation and dissemination of evidence-based practices are warranted. As outlined by Krist and colleagues,^373^ research on behavioral counseling interventions such as the type synthesized here would benefit from application of checklists and frameworks such as the Template for Intervention Description and Replication (TIDierR); Research, Effectiveness, Adoption, Implementation, and Maintenance (RE-AIM); and the Pragmatic-Explanatory Continuum Indicator Summary (PRECIS) to assess the feasibility and applicability of interventions, as well as to improve replication and dissemination.

Many of the trials, especially those examining weight loss medications, may have been biased by high attrition. We chose to include studies with high attrition because we believed that early discontinuation was likely due to the interventions (medication side effects, lack of weight loss, time commitments) and not necessarily due to a design flaw. Although we required that trials examine multiple methods of imputing data, imputing such large amounts of data might have led to biased comparisons in unknown directions.

Almost all of the studies relied on BMI to identify their populations for weight loss or maintenance interventions. While long-term health risks increase with increasing BMI, the precise BMI at which increased risk occurs and the strength of the relationship appears to vary by race/ethnicity, age, and personal/lifestyle factors.^6-20,^ ^29,^ ^70,^ ^73-82^ BMI may not be the best predictor of future disease and mortality, especially in particular subgroups, and future trials should consider employing more recently developed classification systems that include assessment of physical, mental, and functional health to characterize obesity severity.^374,^ ^375^ In the meantime, an important consideration for PCPs is whether to recommend weight loss for participants with BMIs in the overweight range, especially if they are older, of certain racial/ethnic groups, or “metabolically healthy.” Participants in the weight loss trials generally fell into the overweight and obesity categories, and results were not reliably stratified by BMI. We were therefore unable to make conclusions about whether the health effects of weight loss interventions vary according to baseline BMI category, age, or race/ethnicity. Future research should focus on these important subgroups to determine if weight loss has lasting benefits in these lower risk populations. In addition, future research should focus on interventions that include identification and treatment of factors that may prevent adults from losing weight during behavioral interventions such as the microbiome, genetics, or other unmanaged medical or psychological conditions.

We identified nine trials, including four being conducted in the United States, currently underway that may contribute to this evidence base (Appendix H). One of particular interest that may address several of these future research needs is the 5A trial. This trial will examine an intervention that supports the 5As of Obesity Management™—Ask, Assess, Advise, Agree, and Assist—for use in clinical care.^376^ There are also a number of comparative effectiveness trials underway that we did not list here.

## Conclusion

We found that behavior-based weight loss interventions with or without weight loss medications resulted in more weight loss than usual care. The degree of weight loss we observed in the current review is slightly smaller but consistent in magnitude with our 2011 review on this topic. As in the previous review, we noted that weight loss interventions resulted in a decreased risk of developing diabetes, particularly among those with prediabetes, although the prevalence of other intermediate health outcomes were less well reported. Limited evidence exists regarding health outcomes associated with weight loss interventions. Weight loss medications, but not behavior-based interventions, were associated with more harms compared with control arms. Long-term weight and health outcomes data as well as data on important subgroups (e.g., those who are older, nonwhite, or overweight) were lacking and should be a high priority for future study.