# Appendix H List of Ongoing Studies

Study Reference Trial Identifier | Study Name | Location | Estimated N | Description | 2017 Status
10.1155/2014/245347 | Long-Term Effect of Interactive Online Dietician Weight Loss Advice in General Practice (LIVA) | Denmark | 340 | To evaluate the impact of a complex intervention using face-to-face contact with trained dieticians combined with interactive online support and follow-up, as compared with usual care, on BMI and metabolic risk factors. | Ongoing: No Est. Completion Date.
NCT01967797 | 5As Framework of Obesity Management (5AsT) | Canada | 255 | The 5AsT trial will provide a wide range of insights into current practices, knowledge gaps and barriers that limit obesity management in primary practice. | Ongoing: Est. Completion Date Dec 2016 No Results Published
ISRCTN14657176 | NULevel | UK | 288 | The primary aim of NULevel is to evaluate the effectiveness of an inexpensive, scalable, technology-assisted, behavioural intervention for reducing weight regain among adults with obesity after initial weight loss. | Completed. No Published Results Yet.
ISRCTN52341938 | Lighten Up weight maintenance study (LIMIT) | UK | 560 | The primary aim of this study is to evaluate the effectiveness and cost effectiveness of a brief behavioral intervention delivered by non-specialist staff to promote regular self-weighing to prevent weight regain after intentional weight loss. | Completed. No Published Results Yet.
ISRCTN88405328 | NoHoW: Evidence-based ICT Tools For Weight Loss Maintenance | Denmark, Portugal, UK | 1600 | To evaluate the effectiveness of evidence-based information and communications technology behavior change tools for weight loss maintenance in individuals who are overweight or have obesity and have experienced clinically significant weight loss. | Ongoing: Est. Completion Date Dec 2020
NCT01542671 | Tailored Lifestyle Intervention in Obese Adults Within Primary Care Practice - Choose to Lose (CTL) | US | 200 | The primary objective of the study is to evaluate the effectiveness of tailored lifestyle intervention in primary care by comparing changes in the primary measure of weight and body mass index (BMI) and secondarily: physical activity (PA), fat calories consumed, and fruit/vegetable servings within the two arms (intervention and control) of the study. | Completed. No Published Results Yet.
NCT02829229 | Community-based Obesity Treatment in African American Women After Childbirth | US | 300 | The purpose of this study is to determine the effect of the community-based obesity treatment (PP), compared to usual care (UC), on changes in maternal weight over 12 months. | Ongoing: Estimated Completion Date Jun 2020
NCT02561221 | Promoting Successful Weight Loss in Primary Care in Louisiana (PROPEL) | US | 1080 | The primary aim of this trial is to develop and test the effectiveness of a 24 month, patient-centered, pragmatic and scalable obesity treatment program delivered within primary care, inclusive of an underserved population. Half of the participants will receive a behavioral intervention delivered in a primary care setting and half of the participants will receive usual care. | Ongoing: Estimated Completion Date Jun 2019
NCT02963935 | Effect and Safety of Liraglutide 3.0 mg as an Adjunct to Intensive Behaviour Therapy for Obesity in a Non-specialist Setting (SCALE™ IBT) | US | 282 | The purpose of the trial is to investigate the effect and safety of liraglutide 3.0 mg as an adjunct to intensive behaviour therapy for obesity in a non-specialist setting (IBT-CMS: Intensive Behaviour Therapy for obesity in a primary care setting according to Centers for Medicare & Medicaid Services (CMS) visit schedule). | Ongoing: Est. Completion Date Jun 2018
NCT03038620 | Impact of Liraglutide 3.0 on Body Fat Distribution | US | 356 | This study is a clinical study to investigate the efficacy of liraglutide compared to placebo in reducing visceral adiposity measured by MRI in overweight or obese subjects at high risk for cardiovascular disease after 40 weeks on-treatment. | Ongoing: Est. Completion Date Dec 2020
NCT02019264 | A Study to Evaluate the Effect of Long-term Treatment With BELVIQ (Lorcaserin HCl) on the Incidence of Major Adverse Cardiovascular Events and Conversion to Type 2 Diabetes Mellitus in Obese and Overweight Subjects With Cardiovascular Disease or Multiple Cardiovascular Risk Factors | US, Australia, Bahamas, Canada, Chile, Mexico, New Zealand, Poland | 1200 | To evaluate the effect of long-term treatment with BELVIQ (Lorcaserin HCL) on the incidence of major adverse cardiovascular events and conversion to type 2 diabetes mellitus in subjects with obesity and overweight and with cardiovascular disease or multiple cardiovascular risk factors. | Ongoing: Est. Completion Date Nov 2018
NCT02400359 | Lorcaserin in Obesity: Identification of CNS Targets Using fMRI | US | 40 | The purpose of this protocol is to investigate the effect of treatment with the study drug, called lorcaserin on centers of the brain that control appetite and food intake, as well as lorcaserin’s other metabolic effects. | Ongoing: Est. Completion Date Dec 2018
NCT01480466 | Use of Electronic Health Records for Addressing Overweight and Obesity in Primary Care | US | 65278 | The objectives of the proposed research are to develop and evaluate a set of tools within electronic health records (EHRs) to assist primary care clinicians with the diagnosis and treatment of overweight and obesity and to help patients manage their weight. | Completed. No Published Results Yet.
ACTRN12615000114549 | Do Making Habits or Breaking Habits Influence Weight Loss and Weight Loss Maintenance: A Randomised Controlled Trial | Australia | 75 | The primary purpose of this study is to investigate the effectiveness of 2 weight management interventions which focus on habitual behavior and assess whether we can maintain weight loss for at least 12 months if habits are altered. | Completed. No Published Results Yet.
ACTRN12612000997853 | Living Well after Breast Cancer | Australia | 160 | The purpose of this study is to evaluate a 12-month telephone-delivered weight loss program, as compared to usual care, for women who have recently completed primary treatment for breast cancer. | Ongoing: No Est. Completion Date
NCT03006328 | The GEM (Goals for Eating and Moving) Study (GEM) | US | 384 | Test the impact of the GEM intervention on weight change, and clinical and behavioral outcomes. | Ongoing: Est. Completion Date Sep 2017
NCT01946191 | Computer-Based Weight Maintenance in Primary Care (MAINTAIN-PC) | US | 194 | The purpose of this study is to test whether online tracking tools and weight maintenance coaching visits for patients and real-time electronic progress reports for primary care providers (PCPs) [Continued Coaching (CC)] will support more successful weight maintenance than online tracking tools alone [Tracking Only (TO)] in a group of primary care patients who have lost ≥ 5% of their body weight. | Ongoing: Est. Completion Date Sep 2017
NCT01795248 | The Impact of Liraglutide on Glucose Tolerance and the Risk of Type 2 Diabetes in Women With Previous Pregnancy-induced Diabetes | Denmark | 100 | To examine the effect of the type 2 diabetes medicine, liraglutide (Victoza), in women with previous gestational diabetes with the aim of reducing the risk of developing type 2 diabetes. | Ongoing: Est. Completion Date Aug 2020
NCT03032731 | Trial of a New Online Programme for Physical Activity and Healthy Eating | UK | 60 | To investigate the efficacy of a self-directed, website-based intervention to promote physical activity and healthy dietary behaviors. | Ongoing: Est. Completion Date Oct 2017
NCT03163264 | The Move Toward Your Goals Intervention (MTG) | US | 520 | To explore the feasibility and impact of a technology-assisted intervention on intermediate, behavioral, and weight loss outcomes at 3, 6 and 12 months post-intervention when compared to enhanced usual care. | Ongoing: Est. Completion Date Mar 2020
NCT03203655 | Text Based Mobile Technology and Weight Loss | US | 40 | To test the efficacy of a culturally sensitive and linguistically appropriate internet and mobile-based weight loss therapy inHispanic/Latino women with obesity. | Ongoing: Est. Completion Date Dec 2017