# Appendix G Detailed Results for Outcomes

Appendix G Table 1 Detailed Results for Weight Loss–Related Outcomes for Behavior-Based Weight Loss Interventions, by Author

Appendix G Table 2 Detailed Results for Meeting Weight Loss Goals for Behavior-Based Weight Loss Interventions, by Author

Appendix G Table 3 Detailed Results for Weight Maintenance Outcomes for Behavior-Based Weight Maintenance Interventions, By Author

Appendix G Table 4 Detailed Results for Meeting Weight Loss Goals for Behavior-Based Weight Loss Maintenance Interventions, by Author

Appendix G Table 5 Detailed Results for Weight Loss-Related Outcomes for Medication-Based Weight Loss Interventions, by Drug

Appendix G Table 6 Detailed Results for Meeting Weight Loss Goals for Medication-Based Weight Loss Interventions, by Drug

Appendix G Table 7 Detailed Results for Weight Maintenance Outcomes for Medication-Based Weight Maintenance Interventions, By Drug

Appendix G Table 8 Detailed Results for Meeting Weight Maintenance Goals for Medication-Based Weight Loss Maintenance Interventions, By Drug