# Appendix F Detailed Intervention Characteristics

Appendix F Table 1 Detailed Intervention Characteristics for Behavior-Based Weight Loss

Appendix F Table 2 Intervention Details for Behavior-Based Weight Loss Maintenance Trials