# Appendix E List of Excluded Studies

Reason for Exclusion^*^
E1. | Study aim: Not behavioral or pharmacologic treatment for weight loss
E2a. | Setting: Not conducted in a ‘very high’ HDI country
E2b. | Setting: Conducted in or recruited from settings not generalizable to primary care (e.g., worksites)
E3a. | Population: Not selected based on weight-related measure
E3b. | Population: Adults with a chronic disease for which weight loss/maintenance is part of disease management (e.g., asthma, DM)
E3c. | Population: Adults with a known chronic disease not generalizable or with secondary causes of obesity (e.g., steroid use)
E3d. | Population: Other population not relevant to current review (e.g., children, pregnant women, institutionalized adults)
E4a. | Outcomes: No relevant outcomes
E4b. | Outcomes: Weight and/height via self-report only
E4c. | Outcomes: Studies not performed in a exclusively overweight or obese population where results for overweight/obese participants were not reported separately
E5a. | Interventions: Intervention out-of-scope
E5b. | Interventions: Surgical procedure or nonsurgical device
E6a. | Study design: Excluded study design
E6b. | Study design: <12 months follow up (no minimum for harms)
E6c. | Study design: not an included comparator (e.g., active intervention, control told not to change diet and/or PA)
E7. | Study quality: Poor quality rating
E8. | Language
E9. | Protocol only

* Assigned at abstract and full-text phase

Abbreviations: E = exclude; HDI = human development index

1 Ackermann RT, Finch EA, Caffrey HM, . Long-term effects of a community-based lifestyle intervention to prevent type 2 diabetes: the DEPLOY extension pilot study. Chronic Illn. 2011;7(4):279–90. PMID: 21840914. KQ1E4a, KQ2E4a KQ3E4a.21840914
2 Adler E, Dhruva A, Moran PJ, . Impact of a Mindfulness-Based Weight-Loss Intervention on Sleep Quality Among Adults with Obesity: Data from the SHINE Randomized Controlled Trial. J Altern Complement Med. 2016. PMID: 28029852. KQ1E6c, KQ2E6c, KQ3E6c.28029852
3 Admiraal WM, Vlaar EM, Nierkens V, . Intensive lifestyle intervention in general practice to prevent type 2 diabetes among 18 to 60-year-old South Asians: 1-year effects on the weight status and metabolic profile of participants in a randomized controlled trial. PLoS ONE [Electronic Resource]. 2013;8(7):e68605. PMID: 23894322. KQ1E5a, KQ2E5a, KQ3E5a.23894322
4 Aguiar EJ, Morgan PJ, Collins CE, . Efficacy of the Type 2 Diabetes Prevention Using LifeStyle Education Program RCT. Am J Prev Med. 2016;50(3):353–64. PMID: 26526160. KQ1E6b, KQ2E6b, KQ3E4a.26526160
5 Ahern A, Boyland E, Jebb S, . Weight loss interventions in primary care: A qualitative study of participants; accounts of commercial referral and standard care. Obesity facts. 2012;5:196. KQ1E4a, KQ2E4a KQ3E4a.22647302
6 Ahn SM, Kim H, Ji E, . The effect of orlistat on weight reduction in obese and overweight Korean patients. Arch Pharm Res. 2014;37(4):512–9. PMID: 23839080. KQ1E6a, KQ2E6a, KQ3E6a.23839080
7 Alfaris N, Wadden TA, Sarwer DB, . Effects of a 2-year behavioral weight loss intervention on sleep and mood in obese individuals treated in primary care practice. Obesity. 2015;23(3):558–64. PMID: 25611944. KQ1E4a, KQ2E4a, KQ3E4a.25611944
8 Amano S, Tsubone H, Hanafusa M, . Physical and physiological effectiveness of an overall health care program for middle-aged Japanese women with mild obesity: A pilot study. Journal of Traditional & Complementary Medicine. 2015;5(2):88–95. PMID: 26151017. KQ1E3a, KQ2E3a, KQ3E3a.26151017
9 Ambeba EJ, Ye L, Sereika SM, . The use of mHealth to deliver tailored messages reduces reported energy and fat intake. Journal of Cardiovascular Nursing. 2015;30(1):35–43. PMID: 24434827. KQ1E6c, KQ2E6c, KQ3E6c.24434827
10 Anderssen S, Holme I, Urdal P, . Diet and exercise intervention have favourable effects on blood pressure in mild hypertensives: the Oslo Diet and Exercise Study (ODES). Blood Press. 1995;4(6):343–9. PMID: 8746601. KQ1E4a, KQ2E6c, KQ3E4a.8746601
11 Annesi JJ, Johnson PH, Tennant GA, . Weight Loss and the Prevention of Weight Regain: Evaluation of a Treatment Model of Exercise Self-Regulation Generalizing to Controlled Eating. Perm. 2016;20(3):4–17. PMID: 26901268. KQ1E6c, KQ2E6c, KQ3E6c.26901268
12 Annesi JJ, Mareno N. Indirect effects of exercise on emotional eating through psychological predictors of weight loss in women. Appetite. 2015;95:219–27. PMID: 26184339. KQ1E6c, KQ2E6c, KQ3E6c.26184339
13 Annesi JJ, Mareno N, McEwen K. Psychosocial predictors of emotional eating and their weight-loss treatment-induced changes in women with obesity. Eat Weight Disord. 2015. PMID: 26233235. KQ1E6c, KQ2E6c, KQ3E6c.26233235
14 Anonymous. Contrave-a combination of bupropion and naltrexone for weight loss. Med Lett Drugs Ther. 2014;56(1455):112–4. PMID: 25372849. KQ1E6a, KQ2E6a, KQ3E6a.25372849
15 Anton SD, Manini TM, Milsom VA, . Effects of a weight loss plus exercise program on physical function in overweight, older women: a randomized controlled trial. Clin Interv Aging. 2011;6:141–9. PMID: 21753869. KQ1E3b, KQ2E3b, KQ3E3b.21753869
16 Applegate WB, Miller ST, Elam JT, . Nonpharmacologic intervention to reduce blood pressure in older patients with mild hypertension. Arch Intern Med. 1992;152(6):1162–6. PMID: 1599343. KQ1E6b, KQ2E6b, KQ3E4a.1599343
17 Ariel D, Kim SH, Abbasi F, . Effect of liraglutide administration and a calorie-restricted diet on lipoprotein profile in overweight/obese persons with prediabetes. Nutrition, Metabolism and Cardiovascular Diseases. 2014;24(12):1317–22. KQ1E6b, KQ2E6b, KQ3E4a.
18 Armamento-Villareal R, Aguirre LE, Qualls C, . Effect of Lifestyle Intervention on the Hormonal Profile of Frail, Obese Older Men. Journal of Nutrition, Health & Aging. 2016;20(3):334–40. PMID: 26892583. KQ1E3c, KQ2E3c, KQ3E3c.26892583
19 Armamento-Villareal R, Sadler C, Napoli N, . Weight loss in obese older adults increases serum sclerostin and impairs hip geometry but both are prevented by exercise training. J Bone Miner Res. 2012;27(5):1215–21. PMID: 22392834. KQ1E3c, KQ2E3c, KQ3E3c.22392834
20 Arzola-Paniagua MA, Garcia-Salgado Lopez ER, Calvo-Vargas CG, . Efficacy of an orlistat-resveratrol combination for weight loss in subjects with obesity: A randomized controlled trial. Obesity. 2016;24(7):1454–63. PMID: 27221771. KQ1E6b, KQ2E6b, KQ3E7.27221771
21 Austel A, Ranke C, Wagner N, . Weight loss with a modified Mediterranean-type diet using fat modification: a randomized controlled trial. European Journal of Clinical Nutrition. 2015;69(8):878–84. PMID: 25690866. KQ1E6c, KQ2E6c, KQ3E6c.25690866
22 Azadbakht L, Izadi V, Surkan PJ, . Effect of a High Protein Weight Loss Diet on Weight, High-Sensitivity C-Reactive Protein, and Cardiovascular Risk among Overweight and Obese Women: A Parallel Clinical Trial. International journal of endocrinology print. 2013;2013:971724. KQ1E2a, KQ2E2a, KQ3E2a.
23 Azar KM, Aurora M, Wang EJ, . Virtual small groups for weight management: an innovative delivery mechanism for evidence-based lifestyle interventions among obese men. Translational Behavioral Medicine. 2015;5(1):37–44. PMID: 25729451. KQ1E6b, KQ2E6b, KQ3E4a.25729451
24 Baer HJ, Wee CC, Oray J, . Use of Electronic Health Records for Addressing Overweight and Obesity in Primary Care. Brigham and Women’s Hospital, Division of General Medicine and Primary Care. AHRQ/K01 HS019789; 2015. PMID: KQ1E9, KQ2E9, KQ3E9.
25 Baetge C, Earnest CP, Lockard B, . Efficacy of a randomized trial examining commercial weight loss programs and exercise on metabolic syndrome in overweight and obese women. Appl Physiol Nutr Metab. 2017:1–12. PMID: 28044449. KQ1E6c, KQ2E6c, KQ3E4a.28044449
26 Barone Gibbs B, Kinzel LS, Pettee Gabriel K, . Short- and long-term eating habit modification predicts weight change in overweight, postmenopausal women: results from the WOMAN study. J Acad Nutr Diet. 2012;112(9):1347–55, 55.e1–2. PMID: 22939439. KQ1E4a, KQ2E4a, KQ3E4a.22939439
27 Bays H, Pi-Sunyer X, Hemmingsson JU, . Liraglutide 3.0mg for weight management: weight-loss dependent and independent effects. Curr Med Res Opin. 2017;33(2):225–9. PMID: 27817208. KQ1E4a, KQ2E4a, KQ3E4a.27817208
28 Beavers KM, Beavers DP, Nesbit BA, . Effect of an 18-month physical activity and weight loss intervention on body composition in overweight and obese older adults. Obesity. 2014;22(2):325–31. PMID: 23963786. KQ1E3c, KQ2E3c, KQ3E3c.23963786
29 Beavers KM, Case LD, Blackwell CS, . Effects of weight regain following intentional weight loss on glucoregulatory function in overweight and obese adults with pre-diabetes. Obes Res Clin Pract. 2015;9(3):266–73. PMID: 25293586. KQ1E4a, KQ2E4a, KQ3E4a.25293586
30 Befort CA, Klemp JR, Fabian C, . Protocol and recruitment results from a randomized controlled trial comparing group phone-based versus newsletter interventions for weight loss maintenance among rural breast cancer survivors. Contemp Clin Trials. 2014;37(2):261–71. PMID: 24486636. KQ1E4a, KQ2E6c, KQ3E4a.24486636
31 Befort CA, Klemp JR, Sullivan DK, . Weight loss maintenance strategies among rural breast cancer survivors: The rural women connecting for better health trial. Obesity. 2016;24(10):2070–7. PMID: 27581328. KQ1E4a, KQ2E6c, KQ3E4a.27581328
32 Bennett WL, Gudzune KA, Appel LJ, . Insights from the POWER practice-based weight loss trial: a focus group study on the PCP’s role in weight management. J Gen Intern Med. 2014;29(1):50–8. PMID: 24002616. KQ1E4a, KQ2E4a, KQ3E4a.24002616
33 Bennett WL, Wang NY, Gudzune KA, . Satisfaction with primary care provider involvement is associated with greater weight loss: Results from the practice-based POWER trial. Patient Educ Couns. 2015;98(9):1099–105. PMID: 26026649. KQ1E4a, KQ2E4a, KQ3E4a.26026649
34 Berne C, the Orlistat ST. A randomized study of orlistat in combination with a weight management programme in obese patients with Type 2 diabetes treated with metformin. Diabet Med. 2005;22(5):612–8. PMID: 15842517. KQ1E3b, KQ2E3b, KQ3E3b.15842517
35 Bernstein AM, Gendy G, Rudd N, . Management of prediabetes through lifestyle modification in overweight and obese African-American women: the Fitness, Relaxation, and Eating to Stay Healthy (FRESH) randomized controlled trial. Public Health. 2014;128(7):674–7. PMID: 24996961. KQ1E6b, KQ2E6b, KQ3E4a.24996961
36 Bertz F, Brekke HK, Ellegard L, . Diet and exercise weight-loss trial in lactating overweight and obese women. Am J Clin Nutr. 2012;96(4):698–705. PMID: 22952179. KQ1E4a, KQ2E7, KQ3E4a.22952179
37 Bertz F, Winkvist A, Brekke HK. Sustainable weight loss among overweight and obese lactating women is achieved with an energy-reduced diet in line with dietary recommendations: results from the LEVA randomized controlled trial. J Acad Nutr Diet. 2015;115(1):78–86. PMID: 25088520. KQ1E4a, KQ2E4a, KQ3E4a.25088520
38 Blackford K, Jancey J, Lee AH, . Effects of a home-based intervention on diet and physical activity behaviours for rural adults with or at risk of metabolic syndrome: A randomised controlled trial. The International Journal of Behavioral Nutrition and Physical Activity Vol 13 2016, ArtID 13. 2016;13. KQ1E6b, KQ2E6b, KQ3E4a.
39 Blackman A, Foster GD, Zammit G, . Effect of liraglutide 3.0mg in individuals with obesity and moderate or severe obstructive sleep apnea: the SCALE Sleep Apnea randomized clinical trial. Int J Obes (Lond). 2016;40(8):1310–9. PMID: 27005405. KQ1E3b, KQ2E3b, KQ3E3b.27005405
40 Block G, Azar KM, Romanelli RJ, . Improving diet, activity and wellness in adults at risk of diabetes: randomized controlled trial. Nutr Diabetes. 2016;6(9):e231. PMID: 27643726. KQ1E1a, KQ2E1a, KQ3E1a.27643726
41 Blumenthal JA, Babyak MA, Hinderliter A, . Effects of the DASH diet alone and in combination with exercise and weight loss on blood pressure and cardiovascular biomarkers in men and women with high blood pressure: the ENCORE study. Arch Intern Med. 2010;170(2):126–35. PMID: 20101007. KQ1E4a, KQ2E6c, KQ3E6c.20101007
42 Borkoles E, Carroll S, Clough P, . Effect of a non-dieting lifestyle randomised control trial on psychological well-being and weight management in morbidly obese pre-menopausal women. Maturitas. 2016;83:51–8. PMID: 26602363. KQ1E1a, KQ2E1a, KQ3E1a.26602363
43 Bouchonville M, Armamento-Villareal R, Shah K, . Weight loss, exercise or both and cardiometabolic risk factors in obese older adults: results of a randomized controlled trial. Int J Obes (Lond). 2014;38(3):423–31. PMID: 23823329. KQ1E3c, KQ2E3c, KQ3E3c.23823329
44 Brawley L, Rejeski WJ, Gaukstern JE, . Social cognitive changes following weight loss and physical activity interventions in obese, older adults in poor cardiovascular health. Ann Behav Med. 2012;44(3):353–64. PMID: 22773225. KQ1E3c, KQ2E3c, KQ3E3c.22773225
45 Burke V, Mansour J, Beilin LJ, . Long-term follow-up of participants in a health promotion program for treated hypertensives (ADAPT). Nutr Metab Cardiovasc Dis. 2008;18(3):198–206. KQ1E4a, KQ2E4a, KQ3E4a.17327140
46 Cadmus Bertram LA, Pierce JP, Patterson RE, . Training overweight/obese older women at high risk for breast cancer to use web-based weight loss tools: The HELP pilot study. J Clin Oncol. 2011;29(15_suppl):e11128. PMID: 28023850. KQ1E6c, KQ2E6c, KQ3E6c.
47 Campbell K, Foster-Schubert K, Xiao L, . Injuries in sedentary individuals enrolled in a 12-month, randomized, controlled, exercise trial. Journal of Physical Activity & Health. 2012;9(2):198–207. PMID: 22368219. KQ1E1a, KQ2E1a, KQ3E1a.22368219
48 Campbell PT, Gross MD, Potter JD, . Effect of exercise on oxidative stress: a 12-month randomized, controlled trial. Medicine & Science in Sports & Exercise. 2010;42(8):1448–53. PMID: 20139793. KQ1E1a, KQ2E1a, KQ3E1a.20139793
49 Campbell-Scherer DL, Asselin J, Osunlana AM, . Implementation and evaluation of the 5As framework of obesity management in primary care: design of the 5As Team (5AsT) randomized control trial. Implement Sci. 2014;9:78. PMID: 24947045. KQ1E9, KQ2E9, KQ3E9.24947045
50 Carels RA, Young KM, Koball A, . Transforming your life: an environmental modification approach to weight loss. Journal of Health Psychology. 2011;16(3):430–8. PMID: 20929947. KQ1E6b, KQ2E6b, KQ3E4a.20929947
51 Cavallo DN, Sisneros JA, Ronay AA, . Assessing the Feasibility of a Web-Based Weight Loss Intervention for Low-Income Women of Reproductive Age: A Pilot Study. JMIR Res Protoc. 2016;5(1):e30. PMID: 26920252. KQ1E6a, KQ2E6a, KQ3E6a.26920252
52 Chang SH, Chen MC, Chien NH, . Effectiveness of community-based exercise intervention programme in obese adults with metabolic syndrome. Journal of Clinical Nursing. 2016;25(17-18):2579–89. PMID: 27501160. KQ1E6b, KQ2E6b, KQ3E4a.27501160
53 Chao D, Espeland MA, Farmer D, . Effect of voluntary weight loss on bone mineral density in older overweight women. J Am Geriatr Soc. 2000;48(7):753–9. PMID: 10894313. KQ1E3a, KQ2E3a, KQ3E3a.10894313
54 Christian JG, Bessesen DH, Byers TE, . Clinic-based support to help overweight patients with type 2 diabetes increase physical activity and lose weight. Arch Intern Med. 2008;168(2):141–6. PMID: 18227359. KQ1E3b, KQ2E3b, KQ3E3b.18227359
55 Colleran HL, Lovelady CA. Use of MyPyramid Menu Planner for Moms in a weight-loss intervention during lactation. J Acad Nutr Diet. 2012;112(4):553–8. PMID: 22709705. KQ1E6b, KQ2E6b, KQ3E4a.22709705
56 Conroy MB, Bryce CL, McTigue KM, . Promoting weight maintenance with electronic health record tools in a primary care setting: Baseline results from the MAINTAIN-pc trial. Contemp Clin Trials. 2017;54:60–7. PMID: 28089764. KQ1E9, KQ2E9, KQ3E9.28089764
57 Conroy MB, Sward KL, Spadaro KC, . Effectiveness of a physical activity and weight loss intervention for middle-aged women: healthy bodies, healthy hearts randomized trial. J Gen Intern Med. 2015;30(2):207–13. PMID: 25391601. KQ1E4a, KQ2E7, KQ3E4a.25391601
58 Cooper Z, Doll HA, Hawker DM, . Testing a new cognitive behavioural treatment for obesity: A randomized controlled trial with three-year follow-up. Behaviour Research & Therapy. 2010;48(8):706–13. PMID: 20691328. KQ1E6c, KQ2E6c, KQ3E6c.20691328
59 Courteix D, Valente-dos-Santos J, Ferry B, . Multilevel Approach of a 1-Year Program of Dietary and Exercise Interventions on Bone Mineral Content and Density in Metabolic Syndrome-the RESOLVE Randomized Controlled Trial.[Erratum appears in PLoS One. 2015;10(10):e0140307; PMID: 26440101]. PLoS ONE [Electronic Resource]. 2015;10(9):e0136491. PMID: 26376093. KQ1E6a, KQ2E6a, KQ3E6a.26376093
60 Cox KL, Burke V, Beilin LJ, . A comparison of the effects of swimming and walking on body weight, fat distribution, lipids, glucose, and insulin in older women-the Sedentary Women Exercise Adherence Trial 2. Metabolism: Clinical & Experimental. 2010;59(11):1562–73. PMID: 20197194. KQ1E6c, KQ2E6c, KQ3E6c.20197194
61 Crain AL, Sherwood NE, Martinson BC, . Mediators of Weight Loss Maintenance in the Keep It Off Trial. Ann Behav Med. 2017. PMID: 28508330. KQ1E4a, KQ2E4a, KQ3E4a.28508330
62 Davis BR, Oberman A, Blaufox MD, . Effect of antihypertensive therapy on weight loss. The Trial of Antihypertensive Interventions and Management Research Group. Hypertension. 1992;19(4):393–9. PMID: 1555871. KQ1E4a, KQ2E7, KQ3E4a.1555871
63 Davis KK, Tate DF, Lang W, . Racial Differences in Weight Loss Among Adults in a Behavioral Weight Loss Intervention: Role of Diet and Physical Activity. J Phys Act Health. 2015. PMID: 25742122. KQ1E6c, KQ2E6c, KQ3E6c.25742122
64 Davy B, Winett R, Savla J, . Resist diabetes: a randomized clinical trial for resistance training maintenance in adults with prediabetes. Plos one. 2017;12(2) (no pagination). KQ1E1a, KQ2E1a, KQ3E1a.
65 Dekkers JC, van Wier MF, Ariens GA, . Comparative effectiveness of lifestyle interventions on cardiovascular risk factors among a Dutch overweight working population: a randomized controlled trial. BMC Public Health. 2011;11(1):49. PMID: 21261935. KQ1E4a, KQ2E4a, KQ3E4a.21261935
66 Demark-Wahnefried W, Morey MC, Sloane R, . Reach out to enhance wellness home-based diet-exercise intervention promotes reproducible and sustainable long-term improvements in health behaviors, body weight, and physical functioning in older, overweight/obese cancer survivors. J Clin Oncol. 2012;30(19):2354–61. PMID: 22614994. KQ1E1a, KQ2E1a, KQ3E1a.22614994
67 Dennison L, Morrison L, Lloyd S, . Does brief telephone support improve engagement with a web-based weight management intervention? Randomized controlled trial. J Med Internet Res. 2014;16(3):e95. PMID: 24681761. KQ1E6b, KQ2E6b, KQ3E4a.24681761
68 Derosa G, Maffioli P, Salvadeo SA, . Comparison of orlistat treatment and placebo in obese type 2 diabetic patients. Expert Opinion on Pharmacotherapy. 2010;11(12):1971–82. PMID: 20569086. KQ1E3b, KQ2E3b, KQ3E3b.20569086
69 Dong F, Zhang Y, Huang Y, . Long-term lifestyle interventions in middle-aged and elderly men with nonalcoholic fatty liver disease: a randomized controlled trial. Sci. 2016;6:36783. PMID: 27830836. KQ1E3b, KQ2E3b, KQ3E3b.27830836
70 Donnelly JE, Goetz J, Gibson C, . Equivalent weight loss for weight management programs delivered by phone and clinic. Obesity. 2013;21(10):1951–9. KQ1E6c, KQ2E6c, KQ3E6c.23408579
71 Donnelly JE, Washburn RA, Smith BK, . A randomized, controlled, supervised, exercise trial in young overweight men and women: the Midwest Exercise Trial II (MET2). Contemp Clin Trials. 2012;33(4):804–10. PMID: 22504223. KQ1E6c, KQ2E6c, KQ3E6c.22504223
72 Douglas IJ, Bhaskaran K, Batterham RL, . The effectiveness of pharmaceutical interventions for obesity: weight loss with orlistat and sibutramine in a United Kingdom population-based cohort. British Journal of Clinical Pharmacology. 2015;79(6):1020–7. PMID: 25641659. KQ1E6a, KQ2E6a, KQ3E4a.25641659
73 Douglas IJ, Langham J, Bhaskaran K, . Orlistat and the risk of acute liver injury: self controlled case series study in UK Clinical Practice Research Datalink. BMJ. 2013;346:f1936. PMID: 23585064. KQ1E6a, KQ2E6a, KQ3E6a.23585064
74 Driehuis F, Barte JC, Ter Bogt NC, . Maintenance of lifestyle changes: 3-year results of the Groningen Overweight and Lifestyle study. Patient Educ Couns. 2012;88(2):249–55. PMID: 22560253. KQ1E1a, KQ2E1a, KQ3E1a.22560253
75 Duggan C, Tapsoba J, Wang C, . Dietary weight loss and exercise effects on serum biomarkers of angiogenesis in overweight postmenopausal women: A randomized controlled trial. Cancer Res. 2016;76(14):4226–35. PMID: 27417562. KQ1E6c, KQ2E6c, KQ3E6c.27417562
76 Duggan C, Tapsoba JD, Wang CY, . Dietary Weight Loss, Exercise, and Oxidative Stress in Postmenopausal Women: A Randomized Controlled Trial. Cancer Prev Res (Phila Pa). 2016;9(11):835–43. PMID: 27803047. KQ1E4a, KQ2E4a, KQ3E4a.27803047
77 Duggan C, Xiao L, Wang CY, . Effect of a 12-month exercise intervention on serum biomarkers of angiogenesis in postmenopausal women: a randomized controlled trial. Cancer Epidemiol Biomarkers Prev. 2014;23(4):648–57. PMID: 24501378. KQ1E4a, KQ2E4a, KQ3E4a.24501378
78 Duncan S, Goodyear-Smith F, McPhee J, . Family-centered brief intervention for reducing obesity and cardiovascular disease risk: A randomized controlled trial. Obesity. 2016;24(11):2311–8. PMID: 27616217. KQ1E1a, KQ2E1a, KQ3E1a.27616217
79 Durso LE. The relationship of internalized weight bias to weight change in treatment-seeking overweight adults. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2013;73(7-B(E)):No Pagination Specified. KQ1E6c, KQ2E6c, KQ3E6c.
80 E B. A 12-week web based intervention to treat overweight and obesity. Nutridate. 2013;24:2–4. KQ1E6b, KQ2E6b, KQ3E4a.
81 Faurschou A, Gyldenløve M, Rohde U, . Lack of effect of the glucagon-like peptide-1 receptor agonist liraglutide on psoriasis in glucose-tolerant patients-a randomized placebo-controlled trial. Journal of the European Academy of Dermatology and Venereology: JEADV. 2015;29(3):555–9. KQ1E3b, KQ2E3b, KQ3E3b.25139195
82 Fianu A, Bourse L, Naty N, . Long-Term Effectiveness of a Lifestyle Intervention for the Primary Prevention of Type 2 Diabetes in a Low Socio-Economic Community-An Intervention Follow-Up Study on Reunion Island. PLoS ONE [Electronic Resource]. 2016;11(1):e0146095. PMID: 26731676. KQ1E6a, KQ2E6a, KQ3E6a.26731676
83 Finkelstein EA, Kruger E, Karnawat S. Cost-Effectiveness Analysis of Qsymia for Weight Loss. Pharmacoeconomics. 2015;33(7):699–706. PMID: 24986038. KQ1E4a, KQ2E4a, KQ3E4a.24986038
84 Fjeldsoe BS, Goode AD, Phongsavan P, . Evaluating the Maintenance of Lifestyle Changes in a Randomized Controlled Trial of the ‘Get Healthy, Stay Healthy’ Program. JMIR Mhealth Uhealth. 2016;4(2):e42. PMID: 27166643. KQ1E3a, KQ2E3a, KQ3E3a.27166643
85 Foley P, Steinberg D, Levine E, . Track: A randomized controlled trial of a digital health obesity treatment intervention for medically vulnerable primary care patients. Contemp Clin Trials. 2016;48:12–20. PMID: 26995281. KQ1E9, KQ2E9, KQ3E9.26995281
86 Fontbonne A, Charles MA, Juhan-Vague I, . The effect of metformin on the metabolic abnormalities associated with upper-body fat distribution. BIGPRO Study Group. Diabetes Care. 1996;19(9):920–6. PMID: 8875083. KQ1E5a, KQ2E5a, KQ3E5a.8875083
87 Forman EM, Butryn ML, Manasse SM, . Acceptance-based versus standard behavioral treatment for obesity: Results from the mind your health randomized controlled trial. Obesity (Silver Spring). 2016;24(10):2050–6. KQ1E6c, KQ2E6c, KQ3E6c.27670400
88 Foster-Schubert KE, Alfano CM, Duggan CR, . Effect of diet and exercise, alone or combined, on weight and body composition in overweight-to-obese postmenopausal women. Obesity. 2012;20(8):1628–38. PMID: 21494229. KQ1E4a, KQ2E6c, KQ3E4a.21494229
89 Frank LL, Sorensen BE, Yasui Y, . Effects of exercise on metabolic risk variables in overweight postmenopausal women: a randomized clinical trial. Obesity Res. 2005;13(3):615–25. PMID: 15833948 KQ1E4a, KQ2E6c, KQ3E6c.15833948
90 Frey-Hewitt B, Vranizan KM, Dreon DM, . The effect of weight loss by dieting or exercise on resting metabolic rate in overweight men. Int J Obes. 1990;14(4):327–34. PMID: 2361810. KQ1E6c, KQ2E6c, KQ3E4a.2361810
91 Friedenreich CM, Woolcott CG, McTiernan A, . Adiposity changes after a 1-year aerobic exercise intervention among postmenopausal women: a randomized controlled trial. Int J Obes (Lond). 2011;35(3):427–35. PMID: 20820172. KQ1E3a, KQ2E3a, KQ3E3a.20820172
92 Fujioka K, O’Neil P, Davies M, . Early Weight Loss with Liraglutide 3.0 mg Predicts 1-Year Weight Loss and is Associated with Improvements in Clinical Markers. Obesity (silver spring, md). 2016;24(11):2278–88. PMID: 27804269. KQ1E4a, KQ2E4a, KQ3E4a.27804269
93 Fujioka K, Plodkowski R, O’Neil PM, . The relationship between early weight loss and weight loss at 1 year with naltrexone ER/bupropion ER combination therapy. Int J Obes (Lond). 2016;40(9):1369–75. PMID: 27328752. KQ1E3b, KQ2E3b, KQ3E3b.27328752
94 Fukuoka Y, Gay CL, Joiner KL, . A Novel Diabetes Prevention Intervention Using a Mobile App: A Randomized Controlled Trial With Overweight Adults at Risk. Am J Prev Med. 2015;49(2):223–37. PMID: 26033349. KQ1E6b, KQ2E6b, KQ3E4a.26033349
95 Fuller NR, Lau NS, Markovic TP, . Investigating general medication prescription by general practitioners during a 12-month randomized controlled weight loss trial. Clin Obes. 2017. PMID: 28429577. KQ1E4a, KQ2E4a, KQ3E4a.28429577
96 Fuller NR, Williams K, Shrestha R, . Changes in physical activity during a weight loss intervention and follow-up: a randomized controlled trial. Clin. 2014;4(3):127–35. PMID: 25826767. KQ1E4a, KQ2E4a, KQ3E4a.25826767
97 Gagnon C, Brown C, Couture C, . A cost-effective moderate-intensity interdisciplinary weight-management programme for individuals with prediabetes. Diabetes & Metabolism. 2011;37(5):410–8. PMID: 21489843. KQ1E6c, KQ2E6c, KQ3E6c.21489843
98 Gambineri A, Patton L, Vaccina A, . Treatment with flutamide, metformin, and their combination added to a hypocaloric diet in overweight-obese women with polycystic ovary syndrome: a randomized, 12-month, placebo-controlled study. J Clin Endocrinol Metab. 2006;91(10):3970–80. PMID: 16868063. KQ1E5a, KQ2E5a, KQ3E5a.16868063
99 Ganjali S, Sahebkar A, Mahdipour E, . Investigation of the effects of curcumin on serum cytokines in obese individuals: a randomized controlled trial. ScientificWorldJournal. 2014;2014:898361. PMID: 24678280. KQ1E3a, KQ2E3a, KQ3E3a.24678280
100 Garvey WT, Ryan DH, Henry R, . Prevention of type 2 diabetes in subjects with prediabetes and metabolic syndrome treated with phentermine and topiramate extended release. Diabetes care. 2014;37(4):912–21. KQ1E4a, KQ2E4a, KQ3E4a.24103901
101 Gerdes S, Dethlefs B, Personke Y, . Online weight-loss coaching for patients with psoriasis: results of a pilot study. Br J Dermatol. 2016;174(3):674–6. PMID: 26399576. KQ1E6b, KQ2E6b, KQ3E4a.26399576
102 Gill DP, Blunt W, De Cruz A, . Hockey Fans in Training (Hockey FIT) pilot study protocol: a gender-sensitized weight loss and healthy lifestyle program for overweight and obese male hockey fans. BMC Public Health. 2016;16(1):1096. PMID: 27756351. KQ1E6c, KQ2E6c, KQ3E6c.27756351
103 Gilliam ML. Long-term effects of weight-reducing diets in hypertensive patients. Obstetrics and gynecology. 2012;119(1):180–1. PMID: None. KQ1E6a, KQ2E6a, KQ3E6a.
104 Gillison F, Greaves C, Stathi A, . ‘Waste the Waist’: the development of an intervention to promote changes in diet and physical activity for people with high cardiovascular risk. Br J Health Psychol. 2012;17(2):327–45. PMID: 22107451. KQ1E4a, KQ2E4a, KQ3E4a.22107451
105 Gillison F, Stathi A, Reddy P, . Processes of behavior change and weight loss in a theory-based weight loss intervention program: a test of the process model for lifestyle behavior change. Int. 2015;12:2. PMID: 25592314. KQ1E4a, KQ2E4a, KQ3E4a.25592314
106 Gjevestad E, Karlsen TI, Roislien J, . The effectiveness of secondary and tertiary care lifestyle intervention in morbidly obese patients: a 1-year non-randomized controlled pragmatic clinical trial. Clin. 2013;3(1-2):39–50. PMID: 25586390. KQ1E6c, KQ2E6c, KQ3E6c.25586390
107 Gnagnarella P, Draga D, Baggi F, . Promoting weight loss through diet and exercise in overweight or obese breast cancer survivors (InForma): study protocol for a randomized controlled trial. Trials. 2016;17:363. PMID: 27464488. KQ1E9, KQ2E9, KQ3E9.27464488
108 Gogebakan O, Kohl A, Osterhoff MA, . Effects of weight loss and long-term weight maintenance with diets varying in protein and glycemic index on cardiovascular risk factors: the diet, obesity, and genes (DiOGenes) study: a randomized, controlled trial. Circulation. 2011;124(25):2829–38. PMID: 22104550. KQ1E6b, KQ2E6b, KQ3E4a.22104550
109 Gokcel A, Gumurdulu Y, Karakose H, . Evaluation of the safety and efficacy of sibutramine, orlistat and metformin in the treatment of obesity. Diabetes Obes Metab. 2002;4(1):49–55. PMID: 11874442. KQ1E5a, KQ2E5a, KQ3E5a11874442
110 Gomez-Pardo E, Fernandez-Alvira JM, Vilanova M, . A Comprehensive Lifestyle Peer Group-Based Intervention on Cardiovascular Risk Factors: The Randomized Controlled Fifty-Fifty Program.[Erratum appears in J Am Coll Cardiol. 2016 Mar 22;67(11):1385]. J Am Coll Cardiol. 2016;67(5):476–85. PMID: 26562047. KQ1E1a, KQ2E1a, KQ3E1a.26562047
111 Goodfellow J, Agarwal S, Harrad F, . Cluster randomised trial of a tailored intervention to improve the management of overweight and obesity in primary care in England. Implement Sci. 2016;11(1):77. PMID: 27233633. KQ1E6b, KQ2E6b, KQ3E4a.27233633
112 Greenway FL, Dunayevich E, Tollefson G, . Comparison of combined bupropion and naltrexone therapy for obesity with monotherapy and placebo. J Clin Endocrinol Metab. 2009;94(12):4898–906. KQ1E4a, KQ2E6b, KQ3E5a.19846734
113 Greenway FL, Whitehouse MJ, Guttadauria M, . Rational design of a combination medication for the treatment of obesity. Obesity (Silver Spring). 2009;17(1):30–9. KQ1E4a, KQ2E6b, KQ3E5a.18997675
114 Grilo CM, White MA. Orlistat with behavioral weight loss for obesity with versus without binge eating disorder: randomized placebo-controlled trial at a community mental health center serving educationally and economically disadvantaged Latino/as. Behaviour Research & Therapy. 2013;51(3):167–75. PMID: 23376451. KQ1E4a, KQ2E6b, KQ3E3d.23376451
115 Groeneveld IF, Proper KI, van der Beek AJ, . Sustained body weight reduction by an individual-based lifestyle intervention for workers in the construction industry at risk for cardiovascular disease: results of a randomized controlled trial. Prev Med. 2010;51(3-4):240–6. PMID: 20692282. KQ1E1a, KQ2E1a, KQ3E1a.20692282
116 Guo F, Garvey WT. Cardiometabolic Disease Staging Predicts Effectiveness of Weight Loss Therapy to Prevent Type 2 Diabetes: Pooled Results From Phase III Clinical Trials Assessing Phentermine/Topiramate Extended Release. Diabetes Care. 2017. PMID: 28455281. KQ1E4a, KQ2E4a, KQ3E4a.28455281
117 Haas MC, Bodner EV, Brown CJ, . Calorie restriction in overweight seniors: response of older adults to a dieting study: the CROSSROADS randomized controlled clinical trial. J Nutr Gerontol Geriatr. 2014;33(4):376–400. PMID: 25424512. KQ1E6c, KQ2E6c, KQ3E6c.25424512
118 Habermann N, Makar KW, Abbenhardt C, . No effect of caloric restriction or exercise on radiation repair capacity. Medicine & Science in Sports & Exercise. 2015;47(5):896–904. PMID: 25160845. KQ1E4a, KQ2E4a, KQ3E4a.25160845
119 Hales S, Turner-McGrievy GM, Wilcox S, . Social networks for improving healthy weight loss behaviors for overweight and obese adults: A randomized clinical trial of the social pounds off digitally (Social POD) mobile app. Int J Med Inf. 2016;94:81–90. PMID: 27573315. KQ1E6c, KQ2E6c, KQ3E6c.27573315
120 Hall KS, Pieper CF, Edelman DE, . Lessons learned when innovations go awry: a baseline description of a behavioral trial-the Enhancing Fitness in Older Overweight Veterans with Impaired Fasting Glucose study. Transl Behav Med. 2011;1(4):573–87. PMID: 22866170. KQ1E1a, KQ2E1a, KQ3E1a.22866170
121 Halseth A, Shan K, Walsh B, . Method-of-use study of naltrexone sustained release (SR)/bupropion SR on body weight in individuals with obesity. Obesity. 2017;25(2):338–45. PMID: 28026920. KQ1E6c, KQ2E6c, KQ3E6c.28026920
122 Handelsman Y, Odeh S, Troupin B, editors. Use of phentermine/topiramate extended-release (PHEN/TPM ER) in obese/overweight subjects with dysglycemia. 11th Annual World Congress on Insulin Resistance, Diabetes and Cardiovascular Disease, WCIRDC 2014 Nov 7-9; Los Angeles, CA. KQ Search 1 - CENTRAL: Endocrine Practice; I1a to Gadde 2011 [7242]. KQ1E4a, KQ2E4a, KQ3E4a.
123 Hanefeld M, Sachse G. The effects of orlistat on body weight and glycaemic control in overweight patients with type 2 diabetes: a randomized, placebo-controlled trial. Diabetes Obes Metab. 2002;4(6):415–23. PMID: 12406041. KQ1E3b, KQ2E3b, KQ3E3b.12406041
124 Hardcastle S, Taylor A, Bailey M, . A randomised controlled trial on the effectiveness of a primary health care based counselling intervention on physical activity, diet and CHD risk factors. Patient Educ Couns. 2008;70(1):31–9. PMID: 17997263. KQ1E1a, KQ2E1a, KQ3E1a.17997263
125 Hardcastle SJ, Taylor AH, Bailey MP, . Effectiveness of a motivational interviewing intervention on weight loss, physical activity and cardiovascular disease risk factors: a randomised controlled trial with a 12-month post-intervention follow-up. Int. 2013;10:40. PMID: 23537492. KQ1E1a, KQ2E1a, KQ3E1a.23537492
126 Harris L, Melville C, Jones N, . A single-blind, pilot randomised trial of a weight management intervention for adults with intellectual disabilities and obesity: study protocol. Pilot feasibility stud. 2015;1:5. PMID: 27965785. KQ1E6c, KQ2E6c, KQ3E6c.27965785
127 Hartman SJ, Nelson SH, Cadmus-Bertram LA, . Technology- and Phone-Based Weight Loss Intervention: Pilot RCT in Women at Elevated Breast Cancer Risk. Am J Prev Med. 2016;51(5):714–21. PMID: 27593420. KQ1E6b, KQ2E6b, KQ3E4a.27593420
128 Heideman WH, Wit M, Middelkoop BJC, . Diabetes risk reduction in overweight first degree relatives of type 2 diabetes patients: Effects of a low-intensive lifestyle education program (DiAlert) A randomized controlled trial. Patient education and counseling. 2015;98(4):476–83. KQ1E6b, KQ2E6b, KQ3E4a.25577471
129 Hersey JC, Khavjou O, Strange LB, . The efficacy and cost-effectiveness of a community weight management intervention: a randomized controlled trial of the health weight management demonstration. Prev Med. 2012;54(1):42–9. PMID: 22001689. KQ1E6c, KQ2E6c, KQ3E6c.22001689
130 Hesselink AE, Rutten GE, Slootmaker SM, . Effects of a lifestyle program in subjects with Impaired Fasting Glucose, a pragmatic cluster-randomized controlled trial. BMC Fam Pract. 2015;16:183. PMID: 26695176. KQ1E5a, KQ2E5a, KQ3E5a.26695176
131 Hinderliter AL, Sherwood A, Craighead LW, . The long-term effects of lifestyle change on blood pressure: One-year follow-up of the ENCORE study. Am J Hypertens. 2014;27(5):734–41. PMID: 24084586. KQ1E4a, KQ2E6c, KQ3E6c.24084586
132 Hollander P, Gupta AK, Plodkowski R, . Effects of naltrexone sustained-release/bupropion sustained-release combination therapy on body weight and glycemic parameters in overweight and obese patients with type 2 diabetes.[Erratum appears in Diabetes Care. 2014 Feb;37(2):587]. Diabetes Care. 2013;36(12):4022–9. PMID: 24144653. KQ1E3b, KQ2E3b, KQ3E3b.24144653
133 Hollander PA, Elbein SC, Hirsch IB, . Role of orlistat in the treatment of obese patients with type 2 diabetes. A 1-year randomized double-blind study. Diabetes Care. 1998;21(8):1288–94. PMID: 9702435. KQ1E3b, KQ2E3b, KQ3E3b.9702435
134 Hollenbeak CS, Weinstock RS, Cibula D, . Cost-effectiveness of SHINE: A Telephone Translation of the Diabetes Prevention Program. Health serv. 2016;9:21–8. PMID: 27429556. KQ1E6c, KQ2E6c, KQ3E6c.27429556
135 Hope AA, Kumanyika SK, Shults J, . Changes in Health-Related Quality of Life among African-Americans in a lifestyle weight loss program. Quality of Life Research. 2010;19(7):1025–33. PMID: 20458545. KQ1E6a, KQ2E6a, KQ3E6a.20458545
136 HPT. The Hypertension Prevention Trial: three-year effects of dietary changes on blood pressure. Hypertension Prevention Trial Research Group. Arch Intern Med. 1990;150(1):153–62. PMID: 2404477. KQ1E4a, KQ2E3a, KQ3E4a.2404477
137 Hu G, Tian H, Zhang F, . Tianjin Gestational Diabetes Mellitus Prevention Program: study design, methods, and 1-year interim report on the feasibility of lifestyle intervention program. Diabetes Research & Clinical Practice. 2012;98(3):508–17. PMID: 23010556. KQ1E2a, KQ2E2a, KQ3E2a.23010556
138 Hua K, Hao G, Li W. Cardiovascular outcomes of lifestyle intervention in hypertensive patients with antihypertensive agents. Int J Cardiol. 2017;227:751–6. PMID: 27810294. KQ1E3a, KQ2E3a, KQ3E3a.27810294
139 Hunter GR, Brock DW, Byrne NM, . Exercise training prevents regain of visceral fat for 1 year following weight loss. Obesity. 2010;18(4):690–5. PMID: 19816413. KQ1E6c, KQ2E6c, KQ3E6c.19816413
140 Iepsen EW, Lundgren J, Dirksen C, . Treatment with a GLP-1 receptor agonist diminishes the decrease in free plasma leptin during maintenance of weight loss. Int J Obes (Lond). 2015;39(5):834–41. PMID: 25287751. KQ1E6c, KQ2E6c, KQ3E6c.25287751
141 Iepsen EW, Lundgren JR, Hartmann B, . GLP-1 Receptor Agonist Treatment Increases Bone Formation and Prevents Bone Loss in Weight-Reduced Obese Women. Journal of Clinical Endocrinology & Metabolism. 2015;100(8):2909–17. PMID: 26043228. KQ1E6c, KQ2E6c, KQ3E6c.26043228
142 Imayama I, Alfano CM, Kong A, . Dietary weight loss and exercise interventions effects on quality of life in overweight/obese postmenopausal women: a randomized controlled trial. Int. 2011;8:118. PMID: 22026966. KQ1E6c, KQ2E6c, KQ3E4a.22026966
143 Imayama I, Alfano CM, Mason C, . Weight and metabolic effects of dietary weight loss and exercise interventions in postmenopausal antidepressant medication users and non-users: a randomized controlled trial. Prev Med. 2013;57(5):525–32. PMID: 23859929. KQ1E4a, KQ2E6c, KQ3E4a.23859929
144 Irwin ML, Yasui Y, Ulrich CM, . Effect of exercise on total and intra-abdominal body fat in postmenopausal women: a randomized controlled trial. JAMA. 2003;289(3):323–30. PMID: 12525233. KQ1E4a, KQ2E6c, KQ3E6c.12525233
145 Jakicic JM, Davis KK, Rogers RJ, . Effect of Wearable Technology Combined With a Lifestyle Intervention on Long-term Weight Loss: The IDEA Randomized Clinical Trial. JAMA. 2016;316(11):1161–71. PMID: 27654602. KQ1E6c, KQ2E6c, KQ3E6c.27654602
146 Jakicic JM, Rickman AD, Lang W, . Time-based physical activity interventions for weight loss: a randomized trial. Medicine & Science in Sports & Exercise. 2015;47(5):1061–9. PMID: 25160843. KQ1E4a, KQ2E6a, KQ3E4a.25160843
147 Janney CA, Jakicic JM. The influence of exercise and BMI on injuries and illnesses in overweight and obese individuals: A randomized control trial. The International Journal of Behavioral Nutrition and Physical Activity Vol 7 Jan 2010, ArtID 1. 2010;7. KQ1E3a, KQ2E3a, KQ3E3a.
148 Janus ED, Best JD, Davis-Lameloise N, . Scaling-up from an implementation trial to state-wide coverage: results from the preliminary Melbourne Diabetes Prevention Study. Trials. 2012;13:152. PMID: 22929458. KQ1E3a, KQ2E3a, KQ3E3a.22929458
149 Jay MR, Gillespie CC, Schlair SL, . The impact of primary care resident physician training on patient weight loss at 12 months. Obesity. 2013;21(1):45–50. PMID: 23505167. KQ1E6a, KQ2E6a, KQ3E6a.23505167
150 Jeffery RW, Wing RR, Sherwood NE, . Physical activity and weight loss: does prescribing higher physical activity goals improve outcome? Am J Clin Nutr. 2003;78(4):684–9. PMID: 14522725. KQ1E6c, KQ2E6c, KQ3E6c.14522725
151 Jensen P, Zachariae C, Christensen R, . Effect of weight loss on the cardiovascular risk profile of obese patients with psoriasis. Acta Derm Venereol. 2014;94(6):691–4. PMID: 24556829. KQ1E6b, KQ2E6b, KQ3E4a.24556829
152 Jerome GJ, Rubin RR, Clark JM, . From efficacy to effectiveness: lessons learned from the Practice-Based Opportunities for Weight Reduction (POWER) trial. J. 2012;1(3):213–6. PMID: 24237403. KQ1E4a, KQ2E4a, KQ3E4a.24237403
153 Jordan J, Astrup AV, Day WW. Effects of phentermine and extended-release topiramate alone and in combination on cardiovascular risk factors. Diabetologia. 2012;55:S285. KQ1E6a, KQ2E6a, KQ3E6a.
154 Juul L, Andersen VJ, Arnoldsen J, . Effectiveness of a brief theory-based health promotion intervention among adults at high risk of type 2 diabetes: One-year results from a randomised trial in a community setting. Primary care diabetes. 2016;10(2):111–20. PMID: 26259517. KQ1E3a, KQ2E3a, KQ3E3a.26259517
155 Kaholokula JK, Mau MK, Efird JT, . A family and community focused lifestyle program prevents weight regain in Pacific Islanders: a pilot randomized controlled trial. Health Education & Behavior. 2012;39(4):386–95. PMID: 21551421. KQ1E6c, KQ2E6c, KQ3E6c.21551421
156 Kallings LV, Sierra Johnson J, Fisher RM, . Beneficial effects of individualized physical activity on prescription on body composition and cardiometabolic risk factors: results from a randomized controlled trial. European journal of cardiovascular prevention and rehabilitation: official journal of the European Society of Cardiology, Working Groups on Epidemiology & Prevention and Cardiac Rehabilitation and Exercise Physiology. 2009;16(1):80–4. PMID: 19237997. KQ1E6b, KQ2E6b, KQ3E4a.19237997
157 Kastarinen MJ, Puska PM, Korhonen MH, . Non-pharmacological treatment of hypertension in primary health care: a 2-year open randomized controlled trial of lifestyle intervention against hypertension in eastern Finland. J Hypertens. 2002;20(12):2505–12. PMID: 12473876. KQ1E4a, KQ2E3a, KQ3E4a.12473876
158 Kegler MC, Haardorfer R, Alcantara IC, . Impact of Improving Home Environments on Energy Intake and Physical Activity: A Randomized Controlled Trial. Am J Public Health. 2016;106(1):143–52. PMID: 26696290. KQ1E1a, KQ2E1a, KQ3E1a.26696290
159 Kelley DE, Bray GA, Pi-Sunyer FX, . Clinical efficacy of orlistat therapy in overweight and obese patients with insulin-treated type 2 diabetes: A 1-year randomized controlled trial. Diabetes Care. 2002;25(6):1033–41. PMID: 12032111. KQ1E3b, KQ2E3b, KQ3E3b.12032111
160 Keranen AM, Strengell K, Savolainen MJ, . Effect of weight loss intervention on the association between eating behaviour measured by TFEQ-18 and dietary intake in adults. Appetite. 2011;56(1):156–62. PMID: 20955744. KQ1E6c, KQ2E6c, KQ3E6c.20955744
161 Keyserling TC, Samuel-Hodge CD, Pitts SJ, . A community-based lifestyle and weight loss intervention promoting a Mediterranean-style diet pattern evaluated in the stroke belt of North Carolina: the Heart Healthy Lenoir Project. BMC Public Health. 2016;16:732. PMID: 27495295. KQ1E6c, KQ2E6c, KQ3E6c.27495295
162 Kiernan M, Brown SD, Schoffman DE, . Promoting healthy weight with “stability skills first”: a randomized trial. Journal of Consulting & Clinical Psychology. 2013;81(2):336–46. KQ1E6c, KQ2E6c, KQ3E6c.23106759
163 Kiernan M, King AC, Stefanick ML, . Men gain additional psychological benefits by adding exercise to a weight-loss program. Obes Res. 2001;9(12):770–7. PMID: 11743061. KQ1E6c, KQ2E6c, KQ3E4a.11743061
164 Kim Y, Pike J, Adams H, . Telephone intervention promoting weight-related health behaviors. Prev Med. 2010;50(3):112–7. PMID: 20006642. KQ1E6b, KQ2E6b, KQ3E4a.20006642
165 Kirk EP, Jacobsen DJ, Gibson C, . Time course for changes in aerobic capacity and body composition in overweight men and women in response to long-term exercise: the Midwest Exercise Trial (MET). Int J Obes Relat Metab Disord. 2003;27(8):912–9. PMID: 12861232. KQ1E1a, KQ2E1a, KQ3E1a.12861232
166 Kolotkin RL, Chen S, Klassen P, . Patient-reported quality of life in a randomized placebo-controlled trial of naltrexone/bupropion for obesity. Clin. 2015;5(5):237–44. PMID: 26222044. KQ1E3b, KQ2E3b, KQ3E3b.26222044
167 Kolotkin RL, Gadde KM, Peterson CA, . Health-related quality of life in two randomized controlled trials of phentermine/topiramate for obesity: What mediates improvement? Qual Life Res. 2015. PMID: 26446094. KQ1E4a, KQ2E4a, KQ3E4a.26446094
168 Kraschnewski JL, Stuckey HL, Rovniak LS, . Efficacy of a weight-loss website based on positive deviance. A randomized trial. Am J Prev Med. 2011;41(6):610–4. PMID: 22099238. KQ1E6b, KQ2E6b, KQ3E4a.22099238
169 Krukowski RA, DiLillo V, Ingle K, . Design and Methods of a Synchronous Online Motivational Interviewing Intervention for Weight Management. JMIR Res Protoc. 2016;5(2):e69. PMID: 27095604. KQ1E6c, KQ2E6c, KQ3E6c.27095604
170 Kuller LH, Simkin-Silverman LR, Wing RR, . Women’s Healthy Lifestyle Project: A randomized clinical trial: results at 54 months. Circulation. 2001;103(1):32–7. PMID: 11136682. KQ1E1a, KQ2E1a, KQ3E1a.11136682
171 Kulzer B, Hermanns N, Krichbaum M, . Primary prevention of type 2 diabetes by lifestyle modification. Results of the PRAEDIAS prevention program. [German]. Diabetologe. 2014;10(4):276–85. KQ1E8, KQ2E8, KQ3E8.
172 Laitner MH, Minski SA, Perri MG. The role of self-monitoring in the maintenance of weight loss success. Eat. 2016;21:193–7. KQ1E6c, KQ2E6c, KQ3E6c.
173 Langford HG, Blaufox MD, Oberman A, . Dietary therapy slows the return of hypertension after stopping prolonged medication. JAMA. 1985;253(5):657–64. PMID: 3881608. KQ1E4a, KQ2E3a, KQ3E4a.3881608
174 Latner JD, Ciao AC, Wendicke AU, . Community-based behavioral weight-loss treatment: long-term maintenance of weight loss, physiological, and psychological outcomes. Behaviour Research & Therapy. 2013;51(8):451–9. PMID: 23747584. KQ1E2b, KQ2E2b, KQ3E2b.23747584
175 Leahey T, Fava J, Seiden A, . A randomized controlled trial testing an Internet delivered cost-benefit approach to weight loss maintenance. Prev Med. 2016;92:51–7. PMID: 27095323. KQ1E6b, KQ2E6b, KQ3E4a.27095323
176 Levy RL, Jeffery RW, Langer SL, . Maintenance-tailored therapy vs. standard behavior therapy for 30-month maintenance of weight loss. Prev Med. 2010;51(6):457–9. PMID: 20869984. KQ1E6c, KQ2E6c, KQ3E6c.20869984
177 Lillis J, Niemeier HM, Thomas JG, . A randomized trial of an acceptance-based behavioral intervention for weight loss in people with high internal disinhibition. Obesity. 2016;24(12):2509–14. PMID: 27804255. KQ1E6c, KQ2E6c, KQ3E6c.27804255
178 Lim SS, Noakes M, Keogh JB, . Long-term effects of a low carbohydrate, low fat or high unsaturated fat diet compared to a no-intervention control. Nutrition, metabolism, and cardiovascular diseases: NMCD. 2010;20(8):599–607. KQ1E4a, KQ2E7, KQ3E7.
179 Lin M, Mahmooth Z, Dedhia N, . Tailored, interactive text messages for enhancing weight loss among African American adults: the TRIMM randomized controlled trial. American Journal of Medicine. 2015;128(8):896–904. PMID: 25840035. KQ1E4a, KQ2E6b, KQ3E4a.25840035
180 Livia B, Elisa R, Claudia R, . Stage of Change and Motivation to a Healthier Lifestyle before and after an Intensive Lifestyle Intervention. J Obes [serial on the Internet]. 2016 [cited Bridge Search 2 - CENTRAL; 2016(no pagination): Available from: http://onlinelibrary.wiley.com/o/cochrane/clcentral/articles/220/CN-01167220/frame.html. KQ1E6c, KQ2E6c, KQ3E6c.
181 Lopez-Olmedo N, Hernandez-Cordero S, Neufeld LM, . The Associations of Maternal Weight Change with Breastfeeding, Diet and Physical Activity During the Postpartum Period. Matern Child Health J. 2016;20(2):270–80. PMID: 26525558. KQ1E5a, KQ2E5a, KQ3E5a.26525558
182 Lowe MR, Butryn ML, Thomas JG, . Meal replacements, reduced energy density eating, and weight loss maintenance in primary care patients: a randomized controlled trial. Obesity. 2014;22(1):94–100. PMID: 23894101. KQ1E6c, KQ2E6c, KQ3E6c.23894101
183 Lutes LD, Damschroder LJ, Masheb R, . Behavioral Treatment for Veterans with Obesity: 24-Month Weight Outcomes from the ASPIRE-VA Small Changes Randomized Trial. J Gen Intern Med. 2017;32:(Suppl 1):40–7. PMID: 28271430. KQ1E6c, KQ2E6c, KQ3E6c.28271430
184 Ma W, Huang T, Zheng Y, . Weight-Loss Diets, Adiponectin, and Changes in Cardiometabolic Risk in the 2-Year POUNDS Lost Trial. Journal of Clinical Endocrinology & Metabolism. 2016;101(6):2415–22. PMID: 27055193. KQ1E6c, KQ2E6c, KQ3E6c.27055193
185 Madigan CD, Aveyard P, Jolly K, . Regular self-weighing to promote weight maintenance after intentional weight loss: a quasi-randomized controlled trial. Journal of Public Health. 2014;36(2):259–67. PMID: 23753256. KQ1E4a, KQ2E4a, KQ3E4a.23753256
186 Martin CK, Miller AC, Thomas DM, . Efficacy of SmartLoss, a smartphone-based weight loss intervention: results from a randomized controlled trial. Obesity. 2015;23(5):935–42. PMID: 25919921. KQ1E6b, KQ2E6b, KQ3E4a.25919921
187 Martin-Borras C, Gine-Garriga M, Martinez E, . Effectiveness of a primary care-based intervention to reduce sitting time in overweight and obese patients (SEDESTACTIV): a randomized controlled trial; rationale and study design. BMC Public Health. 2014;14:228. PMID: 24597534. KQ1E1a, KQ2E1a, KQ3E1a.24597534
188 Mateo KF, Jay M. Access to a behavioral weight loss website with or without group sessions increased weight loss in statewide campaign. Journal of clinical outcomes management. 2014;21(8):345–8. PMID: None. KQ1E6c, KQ2E6c, KQ3E6c.
189 Mayer-Davis EJ, D’Antonio AM, Smith SM, . Pounds off with empowerment (POWER): a clinical trial of weight management strategies for black and white adults with diabetes who live in medically underserved rural communities. Am J Public Health. 2004;94(10):1736–42. PMID: 15451743. KQ1E3b, KQ2E3b, KQ3E3b.15451743
190 McRobbie H, Hajek P, Peerbux S, . Tackling obesity in areas of high social deprivation: clinical effectiveness and cost-effectiveness of a task-based weight management group programme - a randomised controlled trial and economic evaluation. Health Technology Assessment (Winchester, England). 2016;20(79):1–150. PMID: 27802843. KQ1E6c, KQ2E6c, KQ3E6c.27802843
191 Megakli T, Vlachopoulos SP, Theodorakis Y. Effects of an aerobic and resistance exercise intervention on health-related quality of life in women with obesity. Journal of Applied Biobehavioral Research. 2016;21(2):82–106. KQ1E1a, KQ2E1a, KQ3E1a.
192 Mellberg C, Sandberg S, Ryberg M, . Long-term effects of a Palaeolithic-type diet in obese postmenopausal women: a 2-year randomized trial. European journal of clinical nutrition. 2014;68(3):350–7. KQ1E6c, KQ2E6c, KQ3E6c.24473459
193 Mensinger JL, Calogero RM, Stranges S, . A weight-neutral versus weight-loss approach for health promotion in women with high BMI: A randomized-controlled trial. Appetite. 2016;105:364–74. PMID: 27289009. KQ1E6c, KQ2E6c, KQ3E6c.27289009
194 Mensinger JL, Calogero RM, Tylka TL. Internalized Weight Stigma Moderates Eating Behavior Outcomes in Women with High BMI Participating in a Healthy Living Program. Appetite. 2016. PMID: 2682937026829370. KQ1E4a, KQ2E4a, KQ3E4a.
195 Mensink M, Blaak EE, Corpeleijn E, . Lifestyle intervention according to general recommendations improves glucose tolerance. Obes Res. 2003;11(12):1588–96. PMID: 14694225. KQ1E4a, KQ2E3a, KQ3E3a.14694225
196 Miles JM, Leiter L, Hollander P, . Effect of orlistat in overweight and obese patients with type 2 diabetes treated with metformin. Diabetes Care. 2002;25(7):1123–8. PMID: 12087008. KQ1E3b, KQ2E3b, KQ3E3b.12087008
197 Miller GD, Isom S, Morgan TM, . Effects of a community-based weight loss intervention on adipose tissue circulating factors. Diabetes Metab Syndr. 2014;8(4):205–11. PMID: 25293442. KQ1E4a, KQ2E4a, KQ3E4a.25293442
198 Mohanka M, Irwin M, Heckbert SR, . Serum lipoproteins in overweight/obese postmenopausal women: a one-year exercise trial. Med Sci Sports Exerc. 2006;38(2):231–9. PMID: 16531889 KQ1E4a, KQ2E6c, KQ3E6c.16531889
199 Moin T, Damschroder LJ, AuYoung M, . Diabetes Prevention Program Translation in the Veterans Health Administration. Am J Prev Med. 2017;13:13. PMID: 28094135. KQ1E6c, KQ2E6c, KQ3E6c.28094135
200 Moore R, Diewald L, Wadden T, . The impact of a primary care-based weight loss intervention on the quality of life. Int J Obes (Lond). 2013;37(Suppl.1):S25–s30. KQ1E4a, KQ2E4a, KQ3E4a.23921778
201 Morey MC, Pieper CF, Edelman DE, . Enhanced fitness: a randomized controlled trial of the effects of home-based physical activity counseling on glycemic control in older adults with prediabetes mellitus. J Am Geriatr Soc. 2012;60(9):1655–62. PMID: 22985140. KQ1E1a, KQ2E1a, KQ3E1a.22985140
202 Muggia C, Falchi AG, Michelini I, . Brief group cognitive behavioral treatment in addition to prescriptive diet versus standard care in obese and overweight patients. A randomized controlled trial. e-SPEN Journal. 2014;9(1):e26–e33. KQ1E6c, KQ2E6c, KQ3E6c.
203 Munoz-Rivas N. A randomized, multicentric trial on lorcaserin versus placebo in the management of overweight and obesity. [Spanish]. Revista clinica espanola. 2011;211(1):52–3. KQ1E8, KQ2E8, KQ3E8.
204 Murphy PJ, Williams RL. Weight-loss study in African-American Women: lessons learned from project take HEED and future, technologically enhanced directions. Perm. 2013;17(2):55–9. PMID: 23704845. KQ1E4a, KQ2E4a, KQ3E4a.23704845
205 Mutsaerts MA, van Oers AM, Groen H, . Randomized Trial of a Lifestyle Program in Obese Infertile Women. New England Journal of Medicine. 2016;374(20):1942–53. PMID: 27192672. KQ1E6b, KQ2E6b, KQ3E4a.27192672
206 Neoh SL, Sumithran P, Haywood CJ, . Combination phentermine and topiramate for weight maintenance: the first Australian experience. Med J Aust. 2014;201(4):224–6. PMID: 25164851. KQ1E6a, KQ2E6a, KQ3E6a.25164851
207 Nezami BT, Lang W, Jakicic JM, . The Effect of Self-Efficacy on Behavior and Weight in a Behavioral Weight-Loss Intervention. Health Psychol. 2016. PMID: 27183306. KQ1E6c, KQ2E6c, KQ3E6c.27183306
208 Nguyen CT, Zhou S, Shanahan W, . Lorcaserin in Obese and Overweight Patients Taking Prohibited Serotonergic Agents: A Retrospective Analysis. Clinical Therapeutics. 2016;38(6):1498–509. PMID: 27206567. KQ1E3b, KQ2E3b, KQ3E3b.27206567
209 Nicklas JM, Sacks FM, Smith SR, . Effect of dietary composition of weight loss diets on high-sensitivity c-reactive protein: the Randomized POUNDS LOST trial. Obesity. 2013;21(4):681–9. PMID: 23712970. KQ1E6c, KQ2E6c, KQ3E6c.23712970
210 Nissen SE, Wolski KE, Prcela L, . Effect of Naltrexone-Bupropion on Major Adverse Cardiovascular Events in Overweight and Obese Patients With Cardiovascular Risk Factors: A Randomized Clinical Trial. JAMA. 2016;315(10):990–1004. PMID: 26954408. KQ1E4a, KQ2E4a, KQ3E3b.26954408
211 Noakes M, Foster P, Keogh J, . Comparison of isocaloric very low carbohydrate/high saturated fat and high carbohydrate/low saturated fat diets on body composition and cardiovascular risk. Nutr Metab (Lond). 2006;3:7. PMID: 16403234. KQ1E4a, KQ2E4a, KQ3E4a.16403234
212 Nurkkala M, Kaikkonen K, Vanhala ML, . Lifestyle intervention has a beneficial effect on eating behavior and long-term weight loss in obese adults. Eat. 2015;18:179–85. PMID: 26112229. KQ1E4a, KQ2E7, KQ3E4a.26112229
213 Oh B, Cho B, Han MK, . The Effectiveness of Mobile Phone-Based Care for Weight Control in Metabolic Syndrome Patients: Randomized Controlled Trial. JMIR Mhealth Uhealth. 2015;3(3):e83. PMID: 26293568. KQ1E6c, KQ2E6c, KQ3E6c.26293568
214 Olszanecka-Glinianowicz M, Dabrowski P, Kocelak P, . Long-term inhibition of intestinal lipase by orlistat improves release of gut hormones increasing satiety in obese women. Pharmacol Rep. 2013;65(3):666–71. PMID: 23950589. KQ1E6b, KQ2E6b, KQ3E4a.23950589
215 O’Neil PM, Garvey WT, Gonzalez-Campoy JM, . Effects of Liraglutide 3.0 Mg on Weight and Risk Factors in Hispanic Versus Non-Hipanic Populations: Subgroup Analysis from Scale Randomized Trials. Endocr Pract. 2016;22(11):1277–87. PMID: 27482610. KQ1E3b, KQ2E3b, KQ3E3b.27482610
216 Osunlana AM, Asselin J, Anderson R, . 5As Team obesity intervention in primary care: development and evaluation of shared decision-making weight management tools. Clin. 2015;5(4):219–25. PMID: 26129630. KQ1E4a, KQ2E4a, KQ3E4a.26129630
217 Paloyo AR, Reichert AR, Reuss-Borst M, . Who responds to financial incentives for weight loss? Evidence from a randomized controlled trial. Soc Sci Med. 2015;145:44–52. PMID: 26448164. KQ1E6b, KQ2E6b, KQ3E4a.26448164
218 Park HA, Lee JS, Kuller LH, . Effects of weight control during the menopausal transition on bone mineral density. J Clin Endocrinol Metab. 2007;92(10):3809–15. PMID: 17635939 KQ1E4a, KQ2E1a, KQ3E1a.17635939
219 Peacock AS, Bogossian FE, Wilkinson SA, . A Randomised Controlled Trial to Delay or Prevent Type 2 Diabetes after Gestational Diabetes: Walking for Exercise and Nutrition to Prevent Diabetes for You. International Journal of Endocrinology Print. 2015;2015:423717. PMID: 26089886. KQ1E6b, KQ2E6b, KQ3E4a.26089886
220 Perri MG, Limacher MC, von Castel-Roberts K, . Comparative effectiveness of three doses of weight-loss counseling: two-year findings from the rural LITE trial. Obesity. 2014;22(11):2293–300. PMID: 25376396. KQ1E6c, KQ2E6c, KQ3E6c.25376396
221 Phillips EG, Wells MT, Winston G, . Innovative approaches to weight loss in a high-risk population: The small changes and lasting effects (SCALE) trial. Obesity. 2017;25(5):833–41. PMID: 28382755. KQ1E6c, KQ2E6c, KQ3E6c.28382755
222 Poddar KH, Ames M, Hsin-Jen C, . Positive effect of mushrooms substituted for meat on body weight, body composition, and health parameters. A 1-year randomized clinical trial. Appetite. 2013;71:379–87. PMID: 24056209. KQ1E6c, KQ2E6c, KQ3E6c.24056209
223 Poelman MP, de Vet E, Velema E, . PortionControl@HOME: results of a randomized controlled trial evaluating the effect of a multi-component portion size intervention on portion control behavior and body mass index. Ann Behav Med. 2015;49(1):18–28. PMID: 25142041. KQ1E4a, KQ2E7, KQ3E4a.25142041
224 Ponzani P. Long-term effectiveness and safety of liraglutide in clinical practice. Minerva Endocrinologica. 2013;38(1):103–12. PMID: 23435446. KQ1E6b, KQ2E6b, KQ3E4a.23435446
225 Pritchard DA, Hyndman J, Taba F. Nutritional counselling in general practice: a cost effective analysis. J Epidemiol Community Health. 1999;53(5):311–6. PMID: 10396539. KQ1E4a, KQ2E7, KQ3E4a.10396539
226 Promrat K, Kleiner DE, Niemeier HM, . Randomized controlled trial testing the effects of weight loss on nonalcoholic steatohepatitis. Hepatology. 2010;51(1):121–9. PMID: 19827166. KQ1E4a, KQ2E3b, KQ3E3b.19827166
227 Ptomey LT, Willis EA, Goetz JR, . Portion-controlled meals provide increases in diet quality during weight loss and maintenance. J Hum Nutr Diet. 2015. PMID: 25664818. KQ1E6c, KQ2E6c, KQ3E6c.25664818
228 Puhkala J, Raitanen J, Kolu P, . Metabolic syndrome in Finnish women 7 years after a gestational diabetes prevention trial. BMJ Open. 2017;7(3):e014565. PMID: 28298369. KQ1E3d, KQ2E3d, KQ3E3d.28298369
229 Radcliff TA, Bobroff LB, Lutes LD, . Comparing Costs of Telephone vs Face-to-Face Extended-Care Programs for the Management of Obesity in Rural Settings. J Acad Nutr Diet. 2012;112(9):1363–73. PMID: 22818246. KQ1E6c, KQ2E6c, KQ3E6c.22818246
230 Rautio N, Jokelainen J, Saaristo T, . Predictors of success of a lifestyle intervention in relation to weight loss and improvement in glucose tolerance among individuals at high risk for type 2 diabetes: the FIN-D2D project. Journal of Primary Care & Community Health. 2013;4(1):59–66. PMID: 23799691. KQ1E6a, KQ2E6a, KQ3E6a.23799691
231 Reeves MM, Terranova CO, Erickson JM, . Living well after breast cancer randomized controlled trial protocol: evaluating a telephone-delivered weight loss intervention versus usual care in women following treatment for breast cancer. BMC Cancer. 2016;16(1):830. PMID: 27793125. KQ1E9, KQ2E9, KQ3E9.27793125
232 Rejeski WJ, Brubaker PH, Goff DC, Jr., . Translating weight loss and physical activity programs into the community to preserve mobility in older, obese adults in poor cardiovascular health. Arch Intern Med. 2011;171(10):880–6. PMID: 21263080. KQ1E3c, KQ2E3c, KQ3E3c.21263080
233 Rickel KA, Milsom VA, Ross KM, . Differential response of African American and Caucasian women to extended-care programs for obesity management. Ethn Dis. 2011;21(2):170–5. PMID: 21749020. KQ1E6c, KQ2E6c, KQ3E6c.21749020
234 Rock CL, Flatt SW, Sherwood NE, . Effect of a Free Prepared Meal and Incentivized Weight Loss Program on Weight Loss and Weight Loss Maintenance in Obese and Overweight Women: A Randomized Controlled Trial. JAMA. 2010;304(16):1803–10. KQ1E6c, KQ2E6c, KQ3E6c.20935338
235 Romano M. A Randomized Clinical Trial of a Tailored Lifestyle Intervention for Obese, Sedentary, Primary Care Patients. Ann Fam Med. 2016;14(4):iii. PMID: 27401435. KQ1E6a, KQ2E6a, KQ3E6a.
236 Rosal MC, Haughton CF, Estabrook BB, . Fresh Start, a postpartum weight loss intervention for diverse low-income women: design and methods for a randomized clinical trial. BMC Public Health. 2016;16:953. PMID: 27612615. KQ1E9, KQ2E9, KQ3E9.27612615
237 Rosas LG, Lv N, Xiao L, . Evaluation of a culturally-adapted lifestyle intervention to treat elevated cardiometabolic risk of Latino adults in primary care (Vida Sana): A randomized controlled trial. Contemp Clin Trials. 2016;48:30–40. PMID: 26995280. KQ1E9, KQ2E9, KQ3E9.26995280
238 Rosenstock J, Klaff LJ, Schwartz S, . Effects of exenatide and lifestyle modification on body weight and glucose tolerance in obese subjects with and without pre-diabetes. Diabetes Care. 2010;33(6):1173–5. PMID: 20332357. KQ1E5a, KQ2E5a, KQ3E5a.20332357
239 Ross R, Hudson R, Stotz PJ, . Effects of exercise amount and intensity on abdominal obesity and glucose tolerance in obese adults: a randomized trial.[Summary for patients in Ann Intern Med. 2015 Mar 3;162(5):I19; PMID: 25732298]. Annals of Internal Medicine. 2015;162(5):325–34. PMID: 25732273. KQ1E6b, KQ2E6b, KQ3E6c.25732273
240 Runhaar J, Deroisy R, van Middelkoop M, . The role of diet and exercise and of glucosamine sulfate in the prevention of knee osteoarthritis: Further results from the PRevention of knee Osteoarthritis in Overweight Females (PROOF) study. Semin Arthritis Rheum. 2016. PMID: 26806185. KQ1E4a, KQ2E4a, KQ3E4a.26806185
241 Runhaar J, van Middelkoop M, Reijman M, . Prevention of knee osteoarthritis in overweight females: the first preventive randomized controlled trial in osteoarthritis. Am J Med. 2015;128(8):888–95.e4. PMID: 25818496. KQ1E4a, KQ2E4a, KQ3E4a.25818496
242 Ryan DH, Johnson WD, Myers VH, . Nonsurgical weight loss for extreme obesity in primary care settings: results of the Louisiana Obese Subjects Study. Arch Intern Med. 2010;170(2):146–54. PMID: 20101009. KQ1E5a, KQ2E5a, KQ3E5a.20101009
243 Sakane N, Dohi S, Sakata K, . Effects of Visceral Fat Accumulation Awareness on a Web-Based Weight-Loss Program: Japanese Study of Visceral Adiposity and Lifestyle Information-Utilization and Evaluation (J-VALUE). ISRN Obesity. 2013;2013:473764. PMID: 24555144. KQ1E6b, KQ2E6b, KQ3E4a.24555144
244 Sakane N, Kotani K, Takahashi K, . Effects of telephone-delivered lifestyle support on the development of diabetes in participants at high risk of type 2 diabetes: J-DOIT1, a pragmatic cluster randomised trial. BMJ Open. 2015;5(8):e007316. KQ1E3a, KQ2E3a, KQ3E3a.
245 Sakane N, Sato J, Tsushita K, . Prevention of type 2 diabetes in a primary healthcare setting: three-year results of lifestyle intervention in Japanese subjects with impaired glucose tolerance. BMC Public Health. 2011;11(1):40. PMID: 21235825. KQ1E3a, KQ2E3a, KQ3E3a.21235825
246 Schmittdiel JA, Adams SR, Goler N, . The impact of telephonic wellness coaching on weight loss: A “Natural Experiments for Translation in Diabetes (NEXT-D)” study. Obesity (Silver Spring). 2017;25(2):352–6. PMID: 28124501. KQ1E6a, KQ2E6a, KQ3E6a.28124501
247 Scholz U, Ochsner S, Luszczynska A. Comparing different boosters of planning interventions on changes in fat consumption in overweight and obese individuals: a randomized controlled trial. Int J Psychol. 2013;48(4):604–15. PMID: 22519565. KQ1E1a, KQ2E1a, KQ3E1a.22519565
248 Schusdziarra V, Hausmann M, Wiedemann C, . Successful weight loss and maintenance in everyday clinical practice with an individually tailored change of eating habits on the basis of food energy density. Eur J Nutr. 2011;50(5):351–61. PMID: 21120658. KQ1E6a, KQ2E6a, KQ3E6a.21120658
249 Schuster RJ, Tasosa J, Terwoord NA. Translational research-implementation of NHLBI Obesity Guidelines in a primary care community setting: the Physician Obesity Awareness Project. Journal of Nutrition, Health & Aging. 2008;12(10):764S–9S. KQ1E6c, KQ2E6c, KQ3E6c.
250 Shahnazari M, Ceresa C, Foley S, . Nutrition-focused wellness coaching promotes a reduction in body weight in overweight US veterans. J Acad Nutr Diet. 2013;113(7):928–35. PMID: 23706353. KQ1E1a, KQ2E1a, KQ3E1a.23706353
251 Shaw PA, Yancy WS, Jr., Wesby L, . The design and conduct of Keep It Off: An online randomized trial of financial incentives for weight-loss maintenance. Clin Trials. 2016. PMID: 27646508. KQ1E9, KQ2E9, KQ3E9.27646508
252 Shea MK, Houston DK, Nicklas BJ, . The effect of randomization to weight loss on total mortality in older overweight and obese adults: the ADAPT Study. Journals of Gerontology Series A-Biological Sciences & Medical Sciences. 2010;65(5):519–25. PMID: 20080875. KQ1E3b, KQ2E3b, KQ3E3b.20080875
253 Sheppard VB, Hicks J, Makambi K, . The feasibility and acceptability of a diet and exercise trial in overweight and obese black breast cancer survivors: The Stepping STONE study. Contemp Clin Trials. 2016;46:106–13. KQ1E4a, KQ2E6b, KQ3E4a.26655430
254 Shin DW, Yun JM, Shin JH, . Enhancing physical activity and reducing obesity through smartcare and financial incentives: A pilot randomized trial. Obesity. 2017;25(2):302–10. PMID: 28063226. KQ1E6b, KQ2E6b, KQ3E4a.28063226
255 Sidhu MS, Daley A, Jolly K. Evaluation of a text supported weight maintenance programme ‘Lighten Up Plus’ following a weight reduction programme: randomised controlled trial. Int. 2016;13:19. PMID: 26867588. KQ1E4a, KQ2E6b, KQ3E4a.26867588
256 Simkin-Silverman LR, Wing RR, Boraz MA, . Lifestyle intervention can prevent weight gain during menopause: results from a 5-year randomized clinical trial. Ann Behav Med. 2003;26(3):212–20. PMID: 14644697. KQ1E1a, KQ2E1a, KQ3E1a.14644697
257 Simkin-Silverman LR, Wing RR, Boraz MA, . Maintenance of cardiovascular risk factor changes among middle-aged women in a lifestyle intervention trial. Womens Health. 1998;4(3):255–71. PMID: 9787651. KQ1E1a, KQ2E1a, KQ3E1a.9787651
258 SM K, J VG-P, A W, . Effectiveness of a web-based intervention aimed at healthy dietary and physical activity behavior: A randomized controlled trial about users and usage. J Med Internet Res. 2011;13:e32. KQ1E3a, KQ2E3a, KQ3E3a.21493191
259 Sniehotta FF, Dombrowski SU, Avenell A, . Randomised controlled feasibility trial of an evidence-informed behavioural intervention for obese adults with additional risk factors. PLoS ONE [Electronic Resource]. 2011;6(8):e23040. PMID: 21897841. KQ1E6b, KQ2E6b, KQ3E4a.21897841
260 Soe K, Dungan K. Subcutaneous liraglutide reduces weight and improves metabolic control in obese participants. Evidence-based medicine. 2015;20(6):203. KQ1E6a, KQ2E6a, KQ3E6a.26385492
261 Spring B, Duncan JM, Janke EA, . Integrating technology into standard weight loss treatment: a randomized controlled trial. JAMA Internal Medicine. 2013;173(2):105–11. PMID: 23229890. KQ1E6c, KQ2E6c, KQ3E6c.23229890
262 Steinberg DM. Effect of daily self-weighing on weight loss in adults. Dissertation Abstracts International: Section B: The Sciences and Engineering. 2013;74(5-B(E)):No Pagination Specified. KQ1E6a, KQ2E6a, KQ3E6a.
263 Steinberg DM, Tate DF, Bennett GG, . The efficacy of a daily self-weighing weight loss intervention using smart scales and e-mail. Obesity. 2013;21(9):1789–97. PMID: 23512320. KQ1E6b, KQ2E6b, KQ3E4a.23512320
264 Steinberg DM, Tate DF, Bennett GG, . Daily self-weighing and adverse psychological outcomes: a randomized controlled trial. Am J Prev Med. 2014;46(1):24–9. PMID: 24355668. KQ1E6b, KQ2E6b, KQ3E4a.24355668
265 Steinberg WM, Rosenstock J, Wadden TA, . Impact of Liraglutide on Amylase, Lipase, and Acute Pancreatitis in Participants With Overweight/Obesity and Normoglycemia, Prediabetes, or Type 2 Diabetes: Secondary Analyses of Pooled Data From the SCALE Clinical Development Program. Diabetes Care. 2017. PMID: 28473337. KQ1E4a, KQ2E4a, KQ3E4a.28473337
266 Stumm G, Blaik A, Kropf S, . Long-Term Follow-Up of the Telemonitoring Weight-Reduction Program “Active Body Control”. J Diabetes Res. 2016;2016:3798729. PMID: 27088096. KQ1E7, KQ2E7, KQ3E7.27088096
267 Tate DF, Jeffery RW, Sherwood NE, . Long-term weight losses associated with prescription of higher physical activity goals. Are higher levels of physical activity protective against weight regain? Am J Clin Nutr. 2007;85(4):954–9. KQ1E6c, KQ2E6c, KQ3E6c.17413092
268 ter Bogt NC, Bemelmans WJ, Beltman FW, . Preventing weight gain: one-year results of a randomized lifestyle intervention. Am J Prev Med. 2009;37(4):270–7. PMID: 19765497. KQ1E1a, KQ2E1a, KQ3E1a.19765497
269 ter Bogt NC, Bemelmans WJ, Beltman FW, . Preventing weight gain by lifestyle intervention in a general practice setting: three-year results of a randomized controlled trial. Arch Intern Med. 2011;171(4):306–13. PMID: 21357805. KQ1E1a, KQ2E1a, KQ3E1a.21357805
270 Thomas EL, Makwana A, Newbould R, . Pragmatic study of orlistat 60mg on abdominal obesity. European Journal of Clinical Nutrition. 2011;65(11):1256–62. PMID: 21697820. KQ1E6a, KQ2E6a, KQ3E6a.21697820
271 Thompson WG, Kuhle CL, Koepp GA, . “Go4Life” exercise counseling, accelerometer feedback, and activity levels in older people. Archives of gerontology and geriatrics. 2014;58(3):314–9. PMID: 24485546. KQ1E6c, KQ2E6c, KQ3E6c.24485546
272 Thurston RC, Ewing LJ, Low CA, . Behavioral weight loss for the management of menopausal hot flashes: a pilot study. Menopause. 2015;22(1):59–65. PMID: 24977456. KQ1E6b, KQ2E6b, KQ3E4a.24977456
273 Toji C, Okamoto N, Kobayashi T, . Effectiveness of diet versus exercise intervention on weight reduction in local Japanese residents. Environ. 2012;17(4):332–40. PMID: 22270698. KQ1E4a, KQ2E6b, KQ3E4a.22270698
274 Tometich DB, Mosher CE, Winger JG, . Effects of diet and exercise on weight-related outcomes for breast cancer survivors and their adult daughters: an analysis of the DAMES trial. Support Care Cancer. 2017. PMID: 28417203. KQ1E4a, KQ2E4a, KQ3E4a.28417203
275 Toriola AT, Liu J, Ganz PA, . Effect of weight loss on bone health in overweight/obese postmenopausal breast cancer survivors. Breast Cancer Res Treat. 2015;152(3):637–43. PMID: 26175059. KQ1E4a, KQ2E4a, KQ3E4a.26175059
276 Trepanowski JF, Kroeger CM, Barnosky A, . Effect of Alternate-Day Fasting on Weight Loss, Weight Maintenance, and Cardioprotection Among Metabolically Healthy Obese Adults: A Randomized Clinical Trial. JAMA Intern Med. 2017. PMID: 28459931. KQ1E6c, KQ2E6c, KQ3E6c.28459931
277 Trief PM, Weinstock RS, Cibula D, . Sustained weight loss one year after group telephone intervention: 3-year results from the SHINE study. Diabetes research and clinical practice. 2014;106(3):e74–e8. KQ1E4a, KQ2E6c, KQ3E4a.25451907
278 Trolle B, Flyvbjerg A, Kesmodel U, . Efficacy of metformin in obese and non-obese women with polycystic ovary syndrome: a randomized, double-blinded, placebo-controlled cross-over trial. Hum Reprod. 2007;22(11):2967–73. PMID: 17766923. KQ1E5a, KQ2E5a, KQ3E5a.17766923
279 Tsai AG, Felton S, Wadden TA, . A randomized clinical trial of a weight loss maintenance intervention in a primary care population. Obesity. 2015;23(10):2015–21. PMID: 26334108. KQ1E6c, KQ2E6c, KQ3E6c.26334108
280 Tseng E, Wang N-Y, Clark J, . Role of PCP referral and weight loss in the Hopkins POWER trial. Preventive Medicine Reports. 2015;2:968–72. KQ1E4a, KQ2E4a, KQ3E4a.26844176
281 Tur JJ, Escudero AJ, Alos MM, . One year weight loss in the TRAMOMTANA study. A randomized controlled trial. Clinical Endocrinology. 2013;79(6):791–9. PMID: 23163735. KQ1E4a, KQ2E7, KQ3E4a.23163735
282 Turk MW, Elci OU, Wang J, . Self-monitoring as a mediator of weight loss in the SMART randomized clinical trial. International Journal of Behavioral Medicine. 2013;20(4):556–61. PMID: 22936524. KQ1E6b, KQ2E6b, KQ3E4a.22936524
283 Uusi-Rasi K, Rauhio A, Kannus P, . Three-month weight reduction does not compromise bone strength in obese premenopausal women. Bone. 2010;46(5):1286–93. PMID: 19857618. KQ1E6a, KQ2E6a, KQ3E6a.19857618
284 van Gemert WA, May AM, Schuit AJ, . Effect of Weight Loss with or without Exercise on Inflammatory Markers and Adipokines in Postmenopausal Women: The SHAPE-2 Trial, A Randomized Controlled Trial. Cancer Epidemiol Biomarkers Prev. 2016;25(5):799–806. PMID: 26908432. KQ1E6b, KQ2E6b, KQ3E4a.26908432
285 van Genugten L, van Empelen P, Boon B, . Results from an online computer-tailored weight management intervention for overweight adults: randomized controlled trial. J Med Internet Res. 2012;14(2):e44. PMID: 22417813. KQ1E4a, KQ2E6b, KQ3E4a.22417813
286 Van Name MA, Camp AW, Magenheimer EA, . Effective Translation of an Intensive Lifestyle Intervention for Hispanic Women With Prediabetes in a Community Health Center Setting. Diabetes Care. 2016;39(4):525–31. PMID: 26908915. KQ1E3a, KQ2E3a, KQ3E3a.26908915
287 van Oers AM, Groen H, Mutsaerts MA, . Effectiveness of lifestyle intervention in subgroups of obese infertile women: a subgroup analysis of a RCT.[Erratum appears in Hum Reprod. 2017 Feb;32(2):482; PMID: 27989990]. Human Reproduction. 2016;31(12):2704–13. PMID: 27798042. KQ1E4a, KQ2E4a, KQ3E4a.27798042
288 VanWormer JJ, Martinez AM, Benson GA, . Telephone counseling and home telemonitoring: the Weigh by Day Trial. American Journal of Health Behavior. 2009;33(4):445–54. KQ1E6c, KQ2E6c, KQ3E6c.19182989
289 Venn BJ, Perry T, Green TJ, . The effect of increasing consumption of pulses and wholegrains in obese people: a randomized controlled trial. J Am Coll Nutr. 2010;29(4):365–72. PMID: 21041811. KQ1E6c, KQ2E6c, KQ3E6c.21041811
290 Vermunt PW, Milder IE, Wielaard F, . A lifestyle intervention to reduce Type 2 diabetes risk in Dutch primary care: 2.5-year results of a randomized controlled trial. Diabet Med. 2012;29(8):e223–31. PMID: 22416789. KQ1E1a, KQ2E1a, KQ3E1a.22416789
291 Vilchez Barboza V, Klijn TP, Salazar Molina A, . Effectiveness of personalized face-to-face and telephone nursing counseling interventions for cardiovascular risk factors: a controlled clinical trial. Rev Lat Am Enfermagem. 2016;24:e2747. PMID: 27508917. KQ1E1a, KQ2E1a, KQ3E1a.27508917
292 Villareal DT, Banks M, Sinacore DR, . Effect of weight loss and exercise on frailty in obese older adults. Arch Intern Med. 2006;166(8):860–6. PMID: 16636211 KQ1E4a, KQ2E3c, KQ3E3c.16636211
293 Villareal DT, Chode S, Parimi N, . Weight loss, exercise, or both and physical function in obese older adults. New England Journal of Medicine. 2011;364(13):1218–29. PMID: 21449785. KQ1E3c, KQ2E3c, KQ3E3c.21449785
294 Villareal DT, Fontana L, Das SK, . Effect of Two-Year Caloric Restriction on Bone Metabolism and Bone Mineral Density in Non-Obese Younger Adults: A Randomized Clinical Trial. J Bone Miner Res. 2016;31(1):40–51. PMID: 26332798. KQ1E3a, KQ2E3a, KQ3E3a.26332798
295 Villareal DT, Fontana L, Weiss EP, . Bone mineral density response to caloric restriction-induced weight loss or exercise-induced weight loss: a randomized controlled trial.[erratum appears in Arch Intern Med. 2007 Mar 12;167(5):452]. Arch Intern Med. 2006;166(22):2502–10. KQ1E3a, KQ2E3a, KQ3E3a.17159017
296 Villareal DT, Miller BV, III, Banks M, . Effect of lifestyle intervention on metabolic coronary heart disease risk factors in obese older adults. Am J Clin Nutr. 2006;84(6):1317–23. PMID: 17158411. KQ1E4a, KQ2E3c, KQ3E3c.17158411
297 Villareal DT, Shah K, Banks MR, . Effect of weight loss and exercise therapy on bone metabolism and mass in obese older adults: a one-year randomized controlled trial. J Clin Endocrinol Metab. 2008;93(6):2181–7. PMID: 18364384. KQ1E4a, KQ2E3c, KQ3E3c.18364384
298 Vinkers CD, Adriaanse MA, Kroese FM, . Efficacy of a self-management intervention for weight control in overweight and obese adults: a randomized controlled trial. J Behav Med. 2014;37(4):781–92. PMID: 23954938. KQ1E6b, KQ2E6b, KQ3E4a.23954938
299 Vissers D, Verrijken A, Mertens I, . Effect of long-term whole body vibration training on visceral adipose tissue: a preliminary report. Obesity Facts. 2010;3(2):93–100. PMID: 20484941. KQ1E6a, KQ2E6a, KQ3E6a.20484941
300 Voils CI, Grubber JM, McVay MA, . Recruitment and Retention for a Weight Loss Maintenance Trial Involving Weight Loss Prior to Randomization. Obesity science & practice. 2016;2(4):355–65. PMID: 28090340. KQ1E6b, KQ2E6b, KQ3E4a.28090340
301 Volger S, Wadden TA, Sarwer DB, . Changes in eating, physical activity and related behaviors in a primary care-based weight loss intervention. Int J Obes (Lond). 2013;37: Suppl 1:S12–8. PMID: 23921776. KQ1E4a, KQ2E4a, KQ3E4a.23921776
302 von Scholten BJ, Davies MJ, Persson F, . Effect of weight reductions on estimated kidney function: Post-hoc analysis of two randomized trials. J Diabetes Complications. 2017. PMID: 28462892. KQ1E4a, KQ2E4a, KQ3E4a.28462892
303 Wadden TA, Foster GD, Sarwer DB, . Dieting and the development of eating disorders in obese women: results of a randomized controlled trial. Am J Clin Nutr. 2004;80(3):560–8. KQ1E6c, KQ2E6c, KQ3E6c.15321793
304 Wang J, Sereika SM, Chasens ER, . Effect of adherence to self-monitoring of diet and physical activity on weight loss in a technology-supported behavioral intervention. Patient Prefer Adherence. 2012;6:221–6. PMID: 22536058. KQ1E6c, KQ2E6c, KQ3E6c.22536058
305 Warren M, Schmitz KH. Safety of strength training in premenopausal women: musculoskeletal injuries from a two-year randomized trial. Am J Health Promot. 2009;23(5):309–14. PMID: 19445432 KQ1E1a, KQ2E1a, KQ3E1a.19445432
306 Wassertheil-Smoller S, Langford HG, Blaufox MD, . Effective dietary intervention in hypertensives: sodium restriction and weight reduction. J Am Diet Assoc. 1985;85(4):423–30. PMID: 3884691. KQ1E3a, KQ2E3a, KQ3E3a.3884691
307 Waters DL, Vawter R, Qualls C, . Long-term maintenance of weight loss after lifestyle intervention in frail, obese older adults. Journal of Nutrition, Health & Aging. 2013;17(1):3–7. PMID: 23299370. KQ1E6a, KQ2E6a, KQ3E6a.23299370
308 Watson S, Woodside JV, Ware LJ, . Effect of a Web-Based Behavior Change Program on Weight Loss and Cardiovascular Risk Factors in Overweight and Obese Adults at High Risk of Developing Cardiovascular Disease: Randomized Controlled Trial. J Med Internet Res. 2015;17(7):e177. PMID: 26183659. KQ1E4a, KQ2E7, KQ3E4a.26183659
309 Weinstock RS, Trief PM, Cibula D, . Weight loss success in metabolic syndrome by telephone interventions: results from the SHINE Study. J Gen Intern Med. 2013;28(12):1620–8. PMID: 23843020. KQ1E4a, KQ2E6c, KQ3E4a.23843020
310 Weisman CS, Hillemeier MM, Downs DS, . Improving women’s preconceptional health: long-term effects of the Strong Healthy Women behavior change intervention in the central Pennsylvania Women’s Health Study. Womens Health Issues. 2011;21(4):265–71. PMID: 21536455. KQ1E1a, KQ2E1a, KQ3E1a.21536455
311 Weiss EP, Racette SB, Villareal DT, . Improvements in glucose tolerance and insulin action induced by increasing energy expenditure or decreasing energy intake: a randomized controlled trial. Am J Clin Nutr. 2006;84(5):1033–42. KQ1E3a, KQ2E3a, KQ3E3a.17093155
312 Weissman N, Smith S, Fain R, . Effects of lorcaserin on pre-existing valvulopathy: a pooled analysis of phase 3 trials. Obesity (silver spring, md). 2017;25(1):39–44. PMID: 27888609. KQ1E3d, KQ2E3d, KQ3E3d.27888609
313 Welsh P, Cezard G, Gill JM, . Associations between weight change and biomarkers of cardiometabolic risk in South Asians: secondary analyses of the PODOSA trial. Int J Obes (Lond). 2016;40(6):1005–11. PMID: 26927315. KQ1E4a, KQ2E4a, KQ3E4a.26927315
314 Werkman A, Hulshof PJ, Stafleu A, . Effect of an individually tailored one-year energy balance programme on body weight, body composition and lifestyle in recent retirees: a cluster randomised controlled trial. BMC Public Health. 2010;10(1):110. PMID: 20205704. KQ1E1a, KQ2E1a, KQ3E1a.20205704
315 West DS, Gorin AA, Subak LL, . A motivation-focused weight loss maintenance program is an effective alternative to a skill-based approach. Int J Obes (Lond). 2011;35(2):259–69. PMID: 20680012. KQ1E4a, KQ2E6c, KQ3E4a.20680012
316 Whitham C, Mellor DD, Goodwin S, . Weight maintenance over 12 months after weight loss resulting from participation in a 12-week randomised controlled trial comparing all meal provision to self-directed diet in overweight adults. J Hum Nutr Diet. 2014;27(4):384–90. PMID: 24236573. KQ1E6c, KQ2E6c, KQ3E6c.24236573
317 Williamson DA, Martin CK, Anton SD, . Is caloric restriction associated with development of eating-disorder symptoms? Results from the CALERIE trial. Health Psychol. 2008;27(1:Suppl):Suppl-42. PMID: 18248104. KQ1E6c, KQ2E6c, KQ3E6c.18248104
318 Winett RA, Anderson ES, Wojcik JR, . Guide to Health: A Randomized Controlled Trial of the Effects of a Completely WEB-Based Intervention on Physical Activity, Fruit and Vegetable Consumption, and Body Weight. Transl Behav Med. 2011;1(1):165–74. PMID: 23503089. KQ1E6c, KQ2E6c, KQ3E6c.23503089
319 Wing RR, West DS, Grady D, . Effect of weight loss on urinary incontinence in overweight and obese women: results at 12 and 18 months. Journal of Urology. 2010;184(3):1005–10. KQ1E6c, KQ2E6c, KQ3E6c.20643425
320 Womble LG, Wadden TA, McGuckin BG, . A randomized controlled trial of a commercial internet weight loss program. Obes Res. 2004;12(6):1011–8. KQ1E6c, KQ2E6c, KQ3E6c.15229342
321 Wong VW, Chan RS, Wong GL, . Community-based lifestyle modification programme for non-alcoholic fatty liver disease: a randomized controlled trial. Journal of hepatology. 2013;59(3):536–42. KQ1E2a, KQ2E2a, KQ3E2a.23623998
322 Wood PD, Stefanick ML, Dreon DM, . Changes in plasma lipids and lipoproteins in overweight men during weight loss through dieting as compared with exercise. N Engl J Med. 1988;319(18):1173–79. PMID: 3173455. KQ1E4a, KQ2E6c, KQ3E4a.3173455
323 Wood PD, Stefanick ML, Williams PT, . The effects on plasma lipoproteins of a prudent weight-reducing diet, with or without exercise, in overweight men and women. N Engl J Med. 1991;325(7):461–6. PMID: 1852180. KQ1E6c, KQ2E6c, KQ3E6c.1852180
324 Woollard J, Burke V, Beilin LJ, . Effects of a general practice-based intervention on diet, body mass index and blood lipids in patients at cardiovascular risk. J Cardiovasc Risk. 2003;10(1):31–40. PMID: 12569235. KQ1E4a, KQ2E3a, KQ3E4a.12569235
325 Xu F, Letendre J, Bekke J, . Impact of a program of Tai Chi plus behaviorally based dietary weight loss on physical functioning and coronary heart disease risk factors: a community-based study in obese older women. J Nutr Gerontol Geriatr. 2015;34(1):50–65. PMID: 25803604. KQ1E6b, KQ2E6b, KQ3E4a.25803604
326 Yank V, Xiao L, Wilson SR, . Short-term weight loss patterns, baseline predictors, and longer-term follow-up within a randomized controlled trial. Obesity. 2014;22(1):45–51. PMID: 23740619. KQ1E4a, KQ2E4a, KQ3E4a.23740619
327 Yardley L, Ware LJ, Smith ER, . Randomised controlled feasibility trial of a web-based weight management intervention with nurse support for obese patients in primary care. Int. 2014;11:67. PMID: 24886516. KQ1E4a, KQ2E7, KQ3E4a.24886516
328 Yates T, Davies M, Gorely T, . Effectiveness of a pragmatic education program designed to promote walking activity in individuals with impaired glucose tolerance: a randomized controlled trial. Diabetes Care. 2009;32(8):1404–10. PMID: 19602539. KQ1E4a, KQ2E1a, KQ3E4a.19602539
329 Yee CH, So WY, Yip SK, . Effect of weight reduction on the severity of lower urinary tract symptoms in obese male patients with benign prostatic hyperplasia: a randomized controlled trial. Korean J Urol. 2015;56(3):240–6; discussion 6-7. PMID: 25763129. KQ1E3b, KQ2E3b, KQ3E3b.25763129
330 Yeh HC, Clark JM, Emmons KE, . Independent but coordinated trials: insights from the practice-based Opportunities for Weight Reduction Trials Collaborative Research Group. Clin Trials. 2010;7(4):322–32. PMID: 20573639. KQ1E4a, KQ2E4a, KQ3E4a.20573639
331 Young MD, Plotnikoff RC, Collins CE, . Impact of a male-only weight loss maintenance programme on social-cognitive determinants of physical activity and healthy eating: A randomized controlled trial. Br J Health Psychol. 2015;20(4):724–44. PMID: 25777588. KQ1E4a, KQ2E4a, KQ3E4a.25777588
332 Zambrana M. The effect of a supplemental telephonic physical activity coaching program for treating obesity: a randomized controlled trial. 2013:104. KQ1E6a, KQ2E6a, KQ3E6a.
333 Zhang HJ, Pan LL, Ma ZM, . Long-term effect of exercise on improving fatty liver and cardiovascular risk factors in obese adults: A 1-year follow-up study. Diabetes, Obesity & Metabolism. 2017;19(2):284–9. PMID: 27761987. KQ1E3b, KQ2E3b, KQ3E3b.27761987
334 Zheng Y, Sereika SM, Ewing LJ, . Association between Self-Weighing and Percent Weight Change: Mediation Effects of Adherence to Energy Intake and Expenditure Goals. J Acad Nutr Diet. 2015. PMID: 26727241. KQ1E6c, KQ2E6c, KQ3E6c.26727241