# Appendix D List of Included Studies

Below is a list of included studies and their ancillary publications (indented below main results publication):

1. Acharya NV, Wilton LV, Shakir SA. Safety profile of orlistat: results of a prescription-event monitoring study. Int J Obes (Lond). 2006;30(11):1645–52. PMID: 16552401. 10.1038/sj.ijo.0803323 16552401
  a Perrio MJ, Wilton LV, Shakir SA. The safety profiles of orlistat and sibutramine: results of prescription-event monitoring studies in England. Obesity (Silver Spring). 2007;15(11):2712–22. PMID: 18070762 10.1038/oby.2007.323 18070762
2. Ackermann RT, Finch E, Brizendine E, . Translating the Diabetes Prevention Program into the community. The DEPLOY Pilot Study. Am J Prev Med. 2008;35(4):357–63. PMID: 18779029. 10.1016/j.amepre.2008.06.035 18779029
  a Hays LM, Finch EA, Saha C, . Effect of self-efficacy on weight loss: a psychosocial analysis of a community-based adaptation of the diabetes prevention program lifestyle intervention. Diabetes Spectr. 2014;27(4):270–5. PMID: 25647049. 10.2337/diaspect.27.4.270 25647049
  b Lipscomb ER, Finch EA, Brizendine E, . Reduced 10-year risk of coronary heart disease in patients who participated in a community-based diabetes prevention program: the DEPLOY pilot study. Diabetes Care. 2009;32(3):394–6. PMID: 19106377. 10.2337/dc08-1622 19106377
3. Ackermann RT, Liss DT, Finch EA, . A Randomized Comparative Effectiveness Trial for Preventing Type 2 Diabetes. Am J Public Health. 2015;105(11):2328–34. PMID: 26378828. 10.2105/AJPH.2015.302641 26378828
  a Ackermann RT, Finch EA, Schmidt KK, . Rationale, design, and baseline characteristics of a community-based comparative effectiveness trial to prevent type 2 diabetes in economically disadvantaged adults: the RAPID Study. Contemp Clin Trials. 2014;37(1):1–9. PMID: 24177413. 10.1016/j.cct.2013.10.003 24177413
4. Ahern AL, Wheeler GM, Aveyard P, . Extended and standard duration weight-loss programme referrals for adults in primary care (WRAP): a randomised controlled trial. Lancet. 2017;389(10085):2214–25. PMID: 28478041. 10.1016/s0140-6736(17)30647-5 28478041
  a Ahern AL, Aveyard PN, Halford JC, . Weight loss referrals for adults in primary care (WRAP): protocol for a multi-centre randomised controlled trial comparing the clinical and cost-effectiveness of primary care referral to a commercial weight loss provider for 12 weeks, referral for 52 weeks, and a brief self-help intervention [ISRCTN82857232]. BMC Public Health. 2014;14:620. PMID: 24943673. 10.1186/1471-2458-14-620 24943673
5. Allison DB, Gadde KM, Garvey WT, . Controlled-release phentermine/topiramate in severely obese adults: a randomized controlled trial (EQUIP). Obesity. 2012;20(2):330–42. PMID: 22051941. 10.1038/oby.2011.330 22051941
6. Anderson AS, Craigie AM, Caswell S, . The impact of a bodyweight and physical activity intervention (BeWEL) initiated through a national colorectal cancer screening programme: randomised controlled trial. BMJ. 2014;348:g1823. PMID: 24609919. 10.1136/bmj.g1823 24609919
  a Caswell S, Craigie AM, Wardle J, . Detailed protocol for the lifestyle intervention in the BeWEL randomised controlled trial of weight loss in adults who have had a colorectal adenoma. BMJ Open. 2012;2(3). PMID: 22637376. 10.1136/bmjopen-2012-001276 22637376
  b Craigie AM, Caswell S, Paterson C, . Study protocol for BeWEL: the impact of a BodyWEight and physicaL activity intervention on adults at risk of developing colorectal adenomas. BMC Public Health. 2011;11:184. PMID: 21439044. 10.1186/1471-2458-11-184 21439044
7. Apovian CM, Aronne L, Rubino D, . A randomized, phase 3 trial of naltrexone SR/bupropion SR on weight and obesity-related risk factors (COR-II). Obesity. 2013;21(5):935–43. PMID: 23408728. 10.1002/oby.20309 23408728
8. Appel L, Clark J, Yeh H, . Comparative effectiveness of weight-loss interventions in clinical practice. N Engl J Med. 2011;365(21):1959–68. PMID: 22085317 10.1056/NEJMoa1108660 22085317
  a Jerome GJ, Dalcin A, Coughlin JW, . Longitudinal accuracy of web-based self-reported weights: results from the Hopkins POWER Trial. J Med Internet Res. 2014;16(7):e173. PMID: 25042773. 10.2196/jmir.3332 25042773
  b Rubin RR, Peyrot M, Wang NY, . Patient-reported outcomes in the practice-based opportunities for weight reduction (POWER) trial. Qual Life Res. 2013;22(9):2389–98. PMID: 23515902. 10.1007/s11136-013-0363-3 23515902
9. Aronne LJ, Wadden TA, Peterson C, . Evaluation of phentermine and topiramate versus phentermine/topiramate extended-release in obese adults. Obesity. 2013;21(11):2163–71. PMID: 24136928. 10.1002/oby.20584 24136928
10. Astrup A, Carraro R, Finer N, . Safety, tolerability and sustained weight loss over 2 years with the once-daily human GLP-1 analog, liraglutide. Int J Obes (Lond). 2012;36(6):vill843–54. PMID: 21844879. 10.1038/ijo.2011.158 21844879
  a Jerome GJ, Dalcin A, Coughlin JW, . Longitudinal accuracy of web-based self-reported weights: results from the Hopkins POWER Trial. J Med Internet Res. 2014;16(7):e173. PMID: 25042773. 10.2196/jmir.3332 25042773
  b Rubin RR, Peyrot M, Wang NY, . Patient-reported outcomes in the practice-based opportunities for weight reduction (POWER) trial. Qual Life Res. 2013;22(9):2389–98. PMID: 23515902. 10.1007/s11136-013-0363-3 23515902
11. Aveyard P, Lewis A, Tearne S, . Screening and brief intervention for obesity in primary care: a parallel, two-arm, randomised trial. Lancet. 2016. PMID: 27789061. 10.1016/S0140-6736(16)31893-1 27789061
  a Lewis A, Jolly K, Adab P, . A brief intervention for weight management in primary care: study protocol for a randomized controlled trial. Trials. 2013;14:393. PMID: 24252510. 10.1186/1745-6215-14-393 24252510
12. Bakris G, Calhoun D, Egan B, . Orlistat improves blood pressure control in obese subjects with treated but inadequately controlled hypertension. J Hypertens. 2002;20(11):2257–67. PMID: 12409965.12409965
13. Beeken R, Leurent B, Vickerstaff V, . A brief intervention for weight control based on habit-formation theory delivered through primary care: results from a randomised controlled trial. Int J Obes (Lond). 2017;41(2):246–54. PMID: 27867204. 10.1038/ijo.2016.206 27867204
  a Beeken RJ, Croker H, Morris S, . Study protocol for the 10 Top Tips (10TT) trial: randomised controlled trial of habit-based advice for weight control in general practice. BMC public health. 2012;12:667. PMID: 22898059. 10.1186/1471-2458-12-667 22898059
14. Bennett GG, Warner ET, Glasgow RE, . Obesity treatment for socioeconomically disadvantaged patients in primary care practice. Arch Intern Med. 2012;172(7):565–74. PMID: 22412073. 10.1001/archinternmed.2012.1 22412073
  a Greaney ML, Quintiliani LM, Warner ET, . Weight Management Among Patients at Community Health Centers: The “Be Fit, Be Well” Study. Obesity and Weight Management. 2009;5(5):222–8. PMID: None. 10.1089/obe.2009.0507
15. Bhopal RS, Douglas A, Wallia S, . Effect of a lifestyle intervention on weight change in south Asian individuals in the UK at high risk of type 2 diabetes: a family-cluster randomised controlled trial. Lancet Diabetes Endocrinol. 2014;2(3):218–27. PMID: 24622752. 10.1016/S2213-8587(13)70204-3 24622752
  a Douglas A, Bhopal RS, Bhopal R, . Design and baseline characteristics of the PODOSA (Prevention of Diabetes & Obesity in South Asians) trial: a cluster, randomised lifestyle intervention in Indian and Pakistani adults with impaired glycaemia at high risk of developing type 2 diabetes. BMJ Open. 2013;3(2). PMID: 23435795. 10.1136/bmjopen-2012-002226 23435795
  b Wallia S, Bhopal RS, Douglas A, . Culturally adapting the prevention of diabetes and obesity in South Asians (PODOSA) trial. Health Promot Internation. 2014;29(4):768–79. PMID: 23574693. 10.1093/heapro/dat015 23574693
16. Broom I, Hughes E, Dodson P, . The role of orlistat in the treatment of obese patients with mild to moderate hypercholesterolaemia: consequences for coronary risk. Br J Cardiol. 2002;9(8):460–8. PMID: None.
17. Broom I, Wilding J, Stott P, . Randomised trial of the effect of orlistat on body weight and cardiovascular disease risk profile in obese patients: UK Multimorbidity Study. Int J Clin Pract. 2002;56(7):494–9. PMID: 1229661012296610
18. Burke V, Beilin LJ, Cutt HE, . Effects of a lifestyle programme on ambulatory blood pressure and drug dosage in treated hypertensive patients: a randomized controlled trial. J Hypertens. 2005;23(6):1241–9. PMID: 15894901. 10.1097/01.hjh.0000170388.61579.4f 15894901
  a Burke V, Beilin LJ, Cutt HE, . A lifestyle program for treated hypertensives improved health-related behaviors and cardiovascular risk factors, a randomized controlled trial. J Clin Epidemiol. 2007;60(2):133–41. PMID: 17208119. 10.1016/j.jclinepi.2006.05.012 17208119
19. Cadmus-Bertram L, Nelson SH, Hartman S, . Randomized trial of a phone- and web-based weight loss program for women at elevated breast cancer risk: the HELP study. J Behav Med. 2016;39(4):551–9. PMID: 27012848. 10.1007/s10865-016-9735-9 27012848
20. Chirinos DA, Goldberg RB, Llabre MM, . Lifestyle modification and weight reduction among low-income patients with the metabolic syndrome: the CHARMS randomized controlled trial. J Behav Med. 2016;39(3):483–92. PMID: 26846133. 10.1007/s10865-016-9721-2 26846133
21. Christian JG, Byers TE, Christian KK, . A computer support program that helps clinicians provide patients with metabolic syndrome tailored counseling to promote weight loss. J Am Diet Assoc. 2011;111(1):75–83. PMID: 21185968. 10.1016/j.jada.2010.10.006 21185968
22. Cohen MD, D’Amico FJ, Merenstein JH. Weight reduction in obese hypertensive patients. Fam Med. 1991;23(1):25–8. PMID: 2001777.2001777
23. Cussler EC, Teixeira PJ, Going SB, . Maintenance of weight loss in overweight middle-aged women through the Internet. Obesity (Silver Spring). 2008;16(5):1052–60. PMID: 18309301 10.1038/oby.2008.19 18309301
24. Davidson MH, Hauptman J, DiGirolamo M, . Weight control and risk factor reduction in obese subjects treated for 2 years with orlistat: a randomized controlled trial. JAMA. 1999;281(3):235–42. PMID: 9918478. 10.1001/jama.281.3.235 9918478
25. de Vos BC, Runhaar J, Bierma-Zeinstra SM. Effectiveness of a tailor-made weight loss intervention in primary care. Eur J Nutr. 2014;53(1):95–104. PMID: 23429925. 10.1007/s00394-013-0505-y 23429925
  a de Vos BC, Runhaar J, van Middelkoop M, . Long-term effects of a randomized, controlled, tailor-made weight-loss intervention in primary care on the health and lifestyle of overweight and obese women. Am J Clin Nutr. 2016;104(1):33–40. PMID: 27305950. 10.3945/ajcn.116.133512 27305950
26. Demark-Wahnefried W, Jones LW, Snyder DC, . Daughters and Mothers Against Breast Cancer (DAMES): main outcomes of a randomized controlled trial of weight loss in overweight mothers with breast cancer and their overweight daughters. Cancer. 2014;120(16):2522–34. PMID: 24804802. 10.1002/cncr.28761 24804802
27. Derosa G, Mugellini A, Ciccarelli L, . Randomized, double-blind, placebo-controlled comparison of the action of orlistat, fluvastatin, or both an anthropometric measurements, blood pressure, and lipid profile in obese patients with hypercholesterolemia prescribed a standardized diet. Clin Ther. 2003;25(4):1107–22. PMID: 12809960. 10.1016/S0149-2918(03)80070-X 12809960
28. Eaton CB, Hartman SJ, Perzanowski E, . A Randomized Clinical Trial of a Tailored Lifestyle Intervention for Obese, Sedentary, Primary Care Patients. Ann Fam Med. 2016;14(4):311–9. PMID: 27401418. 10.1370/afm.1952 27401418
  a Hartman SJ, Risica PM, Gans KM, . Tailored weight loss intervention in obese adults within primary care practice: rationale, design, and methods of Choose to Lose. Contemp Clin Trials. 2014;38(2):409–19. PMID: 24937016. 10.1016/j.cct.2014.06.001 24937016
29. Farr OM, Upadhyay J, Gavrieli A, . Lorcaserin Administration Decreases Activation of Brain Centers in Response to Food Cues and These Emotion- and Salience-Related Changes Correlate With Weight Loss Effects: A 4-Week-Long Randomized, Placebo-Controlled, Double-Blind Clinical Trial. Diabetes. 2016;65(10):2943–53. PMID: 27385157. 10.2337/db16-0635 27385157
30. Fidler MC, Sanchez M, Raether B, . A one-year randomized trial of lorcaserin for weight loss in obese and overweight adults: the BLOSSOM trial. J Clin Endocrinol Metab. 2011;96(10):3067–77. PMID: 21795446. 10.1210/jc.2011-1256 21795446
  a Aronne L, Shanahan W, Fain R, . Safety and efficacy of lorcaserin: a combined analysis of the BLOOM and BLOSSOM trials. Postgrad Med. 2014;126(6):7–18. PMID: 25414931. 10.3810/pgm.2014.10.2817 25414931
  b Handelsman Y, Fain R, Wang Z, . Lorcaserin treatment allows for decreased number needed to treat for weight and glycemic parameters in week 12 responders with >5% weight loss. Postgrad Med. 2016;128(8):740–6. PMID: 27659698. 10.1080/00325481.2016.1240591 27659698
  c Nesto R, Fain R, Li Y, . Evaluation of lorcaserin on progression of prediabetes to type 2 diabetes and reversion to euglycemia. Postgrad Med. 2016;128(4):364–70. PMID: 27116910. 10.1080/00325481.2016.1178590 27116910
31. Finer N, James WP, Kopelman PG, . One-year treatment of obesity: a randomized, double-blind, placebo-controlled, multicentre study of orlistat, a gastrointestinal lipase inhibitor. Int J Obes Relat Metab Disord. 2000;24(3):306–13. PMID: 10757623. 10.1038/sj.ijo.0801128 10757623
  a James WP, Avenell A, Broom J, . A one-year trial to assess the value of orlistat in the management of obesity. Int J Obes Relat Metab Disord. 1997;21: Suppl 3:S24–S30. PMID: 9225173.9225173
32. Fischer IP. Text message support for weight loss in patients with prediabetes: A randomized clinical trial. Diabetes Care. 2016;39(8):1364–70. 10.2337/dc15-2137 26861922
33. Fitzgibbon ML, Stolley MR, Schiffer L, . Obesity Reduction Black Intervention Trial (ORBIT): 18-Month Results. Obesity (Silver Spring). 2010;18(12):2317–25. PMID: 20300081. 10.1038/oby.2010.47 20300081
  a Fitzgibbon ML, Stolley M, Schiffer L, . Obesity Reduction Black Intervention Trial (ORBIT): design and baseline characteristics. J Womens Health (Larchmt). 2008;17(7):1099–110. PMID: 18774895. 10.1089/jwh.2007.0614 18774895
34. Gadde KM, Allison DB, Ryan DH, . Effects of low-dose, controlled-release, phentermine plus topiramate combination on weight and associated comorbidities in overweight and obese adults (CONQUER): a randomised, placebo-controlled, phase 3 trial.[Erratum appears in Lancet. 2011 Apr 30;377(9776):1494]. Lancet. 2011;377(9774):1341–52. PMID: 21481449. 10.1016/S0140-6736(11)60205-5 21481449
  a Davidson MH, Tonstad S, Oparil S, . Changes in cardiovascular risk associated with phentermine and topiramate extended-release in participants with comorbidities and a body mass index >27 kg/m(2). Am J Cardiol. 2013;111(8):1131–8. PMID: 23375187. 10.1016/j.amjcard.2012.12.038 23375187
  b Garvey WT, Ryan DH, Look M, . Two-year sustained weight loss and metabolic benefits with controlled-release phentermine/topiramate in obese and overweight adults (SEQUEL): a randomized, placebo-controlled, phase 3 extension study. Am J Clin Nutr. 2012;95(2):297–308. PMID: 22158731. 10.3945/ajcn.111.024927 22158731
35. Godino JG, Merchant G, Norman GJ, . Using social and mobile tools for weight loss in overweight and obese young adults (Project SMART): a 2 year, parallel-group, randomised, controlled trial. Lancet Diabetes Endocrinol. 2016;4(9):747–55. PMID: 27426247. 10.1016/S2213-8587(16)30105-X 27426247
  a Patrick K, Marshall SJ, Davila EP, . Design and implementation of a randomized controlled social and mobile weight loss trial for young adults (project SMART). Contemp Clin Trials. 2014;37(1):10–8. PMID: 24215774. 10.1016/j.cct.2013.11.001 24215774
36. Greaves C, Gillison F, Stathi A, . Waste the waist: a pilot randomised controlled trial of a primary care based intervention to support lifestyle change in people with high cardiovascular risk. Int. 2015;12:1. PMID: 25592201. 10.1186/s12966-014-0159-z 25592201
37. Greenway FL, Fujioka K, Plodkowski RA, . Effect of naltrexone plus bupropion on weight loss in overweight and obese adults (COR-I): a multicentre, randomised, double-blind, placebo-controlled, phase 3 trial.[Erratum appears in Lancet. 2010 Oct 23;376(9750):1392], [Erratum appears in Lancet. 2010 Aug 21;376(9741):594]. Lancet. 2010;376(9741):595–605. PMID: 20673995. 10.1016/S0140-6736(10)60888-4 20673995
38. Haapala I, Barengo NC, Biggs S, . Weight loss by mobile phone: a 1-year effectiveness study. Public Health Nutr. 2009;12(12):2382–91. PMID: 19323865. 10.1017/S1368980009005230 19323865
39. Hauptman J, Lucas C, Boldrin MN, . Orlistat in the long-term treatment of obesity in primary care settings. Arch Fam Med. 2000;9(2):160–7. PMID: 10693734.10693734
40. Hill JO, Hauptman J, Anderson JW, . Orlistat, a lipase inhibitor, for weight maintenance after conventional dieting: a 1-y study. Am J Clin Nutr. 1999;69(6):1108–16. PMID: 10357727.10357727
41. Hong JL, Meier CR, Sandler RS, . Risk of colorectal cancer after initiation of orlistat: matched cohort study. BMJ. 2013;347:f5039. PMID: 23982291. 10.1136/bmj.f5039 23982291
42. Hunt K, Wyke S, Gray CM, . A gender-sensitised weight loss and healthy living programme for overweight and obese men delivered by Scottish Premier League football clubs (FFIT): a pragmatic randomised controlled trial. Lancet. 2014;383(9924):1211–21. PMID: 24457205. 10.1016/S0140-6736(13)62420-4 24457205
  a Gray CM, Hunt K, Mutrie N, . Football Fans in Training: the development and optimization of an intervention delivered through professional sports clubs to help men lose weight, become more active and adopt healthier eating habits. BMC Public Health. 2013;13:232. PMID: 23496915. 10.1186/1471-2458-13-232 23496915
  b Wyke S, Hunt K, Gray CM, . Football Fans in Training (FFIT): a randomised controlled trial of a gender-sensitised weight loss and healthy living programme for men – end of study report. Public Health Research. 2015;32. PMID: 25654156. 10.3310/phr03020 25654156
43. Huseinovic E, Bertz F, Leu Agelii M, . Effectiveness of a weight loss intervention in postpartum women: results from a randomized controlled trial in primary health care. Am J Clin Nutr. 2016;104(2):362–70. PMID: 27413127. 10.3945/ajcn.116.135673 27413127
44. Jakicic JM, Otto AD, Lang W, . The effect of physical activity on 18-month weight change in overweight adults. Obesity. 2011;19(1):100–9. PMID: 20539299. 10.1038/oby.2010.122 20539299
45. Jansson SP, Engfeldt P, Magnuson A, . Interventions for lifestyle changes to promote weight reduction, a randomized controlled trial in primary health care. BMC Res Notes. 2013;6:213. PMID: 23711165. 10.1186/1756-0500-6-213 23711165
46. Jebb SA, Ahern AL, Olson AD, . Primary care referral to a commercial provider for weight loss treatment versus standard care: a randomised controlled trial. Lancet. 2011;378(9801):1485–92. PMID: 21906798. 10.1016/S0140-6736(11)61344-5 21906798
  a Holzapfel C, Cresswell L, Ahern AL, . The challenge of a 2-year follow-up after intervention for weight loss in primary care. Int J Obes (Lond). 2014;38(6):806–11. PMID: 24030517. 10.1038/ijo.2013.180 24030517
47. Jeffery RW, Wing RR, Thorson C, . Strengthening behavioral interventions for weight loss: a randomized trial of food provision and monetary incentives. J Consult Clin Psychol. 1993;61(6):1038–45. PMID: 8113481.8113481
  a Jeffery RW, Wing RR. Long-term effects of interventions for weight loss using food provision and monetary incentives. J Consult Clin Psychol. 1995;63(5):793–6. PMID: 7593872. 10.1037/0022-006X.63.5.793 7593872
48. Jenkins DJA, Boucher BA, Ashbury FD, . Effect of Current Dietary Recommendations on Weight Loss and Cardiovascular Risk Factors. J Am Coll Cardiol. 2017;69(9):1103–12. PMID: 28254171. 10.1016/j.jacc.2016.10.089 28254171
49. Jolly K, Lewis A, Beach J, . Comparison of range of commercial or primary care led weight reduction programmes with minimal intervention control for weight loss in obesity: lighten Up randomised controlled trial. BMJ. 2011;343:d6500. PMID: 22053315. 10.1136/bmj.d6500 22053315
  a Jolly K, Daley A, Adab P, . A randomised controlled trial to compare a range of commercial or primary care led weight reduction programmes with a minimal intervention control for weight loss in obesity: the Lighten Up trial. BMC Public Health. 2010;10:439. PMID: 20663185. 10.1186/1471-2458-10-439 20663185
50. Jones DW, Miller ME, Wofford MR, . The effect of weight loss intervention on antihypertensive medication requirements in the hypertension Optimal Treatment (HOT) study. Am J Hypertens. 1999;12(12 Pt 1-2):1175–80. PMID: 10619579.10619579
  a Hansson L, Zanchetti A. The Hypertension Optimal Treatment (HOT) Study-patient characteristics: randomization, risk profiles, and early blood pressure results. Blood Press. 1994;3(5):322–7. PMID: 7866597. 10.3109/08037059409102281 7866597
  b The H.O.T. Study Group. The Hypertension Optimal Treatment Study (the HOT Study). Blood Press. 1993;2(1):62–8. PMID: 8193735. 10.3109/08037059309077529 8193735
51. Kanke S, Kawai T, Takasawa N, . Interventions for body weight reduction in obese patients during short consultations: an open-label randomized controlled trial in the Japanese primary care setting. Asia Pac Fam Med. 2015;14(1):5. PMID: 26015773. 10.1186/s12930-015-0022-7 26015773
52. Katula JA, Vitolins MZ, Rosenberger EL, . One-year results of a community-based translation of the Diabetes Prevention Program: Healthy-Living Partnerships to Prevent Diabetes (HELP PD) Project.[Erratum appears in Diabetes Care. 2012 Feb;35(2):455]. Diabetes Care. 2011;34(7):1451–7. PMID: 21593290. 10.2337/dc10-2115 21593290
  a Katula JA, Vitolins MZ, Morgan TM, . The Healthy Living Partnerships to Prevent Diabetes study: 2-year outcomes of a randomized controlled trial. Am J Prev Med. 2013;44(4 Suppl 4):S324–32. PMID: 23498294. 10.1016/j.amepre.2012.12.015 23498294
  b Pedley CF, Case D, Vitolins MZ, . 24 month metabolic benefits of a community-based translation of the diabetes prevention program. 36th Annual Meeting of the Society of General Internal Medicine. J Gen Intern Med. 2013;28:S2–s3. PMID: 23625304. 10.1007/s11606-013-2436-y 23625304
  c Blackwell CS, Foster KA, Isom S, . Healthy Living Partnerships to Prevent Diabetes: recruitment and baseline characteristics. Contemp Clin Trials. 2011;32(1):40–9. PMID: 20974289. 10.1016/j.cct.2010.10.006 20974289
  d Katula JA, Vitolins MZ, Rosenberger EL, . Healthy Living Partnerships to Prevent Diabetes (HELP PD): design and methods. Contemp Clin Trials. 2010;31(1):71–81. PMID: 19758580. 10.1016/j.cct.2009.09.002 19758580
53. Kim SH, Abbasi F, Lamendola C, . Benefits of liraglutide treatment in overweight and obese older individuals with prediabetes. Diabetes Care. 2013;36(10):3276–82. PMID: 23835684. 10.2337/dc13-0354 23835684
  a Kim SH, Liu A, Ariel D, . Pancreatic beta cell function following liraglutide-augmented weight loss in individuals with prediabetes: analysis of a randomised, placebo-controlled study. Diabetologia. 2014;57(3):455–62. PMID: 24326527. 10.1007/s00125-013-3134-3 24326527
54. Knowler WC, Barrett-Connor E, Fowler SE, . Reduction in the incidence of type 2 diabetes with lifestyle intervention or metformin. N Engl J Med. 2002;346(6):393–403. PMID: 11832527. 10.1056/NEJMoa012512 11832527
  a Ackermann RT, Edelstein SL, Narayan KM, . Changes in health state utilities with changes in body mass in the Diabetes Prevention Program. Obesity (Silver Spring). 2009;17(12):2176–81. PMID: 19390518 10.1038/oby.2009.114 19390518
  b Diabetes Prevention Program Research Group. The Diabetes Prevention Program. Design and methods for a clinical trial in the prevention of type 2 diabetes. Diabetes Care. 1999;22(4):623–34. PMID: 10189543.10189543
  c Diabetes Prevention Program Research Group. Long-term effects of lifestyle intervention or metformin on diabetes development and microvascular complications over 15-year follow-up: the Diabetes Prevention Program Outcomes Study. Lancet Diabetes Endocrinol. 2015;3(11):866–75. PMID: 26377054. 10.1016/S2213-8587(15)00291-0 26377054
  d Diabetes Prevention Program Research Group, Crandall J, Schade D, . The influence of age on the effects of lifestyle modification and metformin in prevention of diabetes. J Gerontol A Biol Sci Med Sci. 2006;61A(10):1075–81. PMID: 17077202 10.1093/gerona/61.10.1075 17077202
  e Diabetes Prevention Program Research Group, Hamman RF, Horton E, . Factors affecting the decline in incidence of diabetes in the Diabetes Prevention Program Outcomes Study (DPPOS). Diabetes. 2015;64(3):989–98. PMID: 25277389. 10.2337/db14-0333 25277389
  f Florez H, Pan Q, Ackermann RT, . Impact of lifestyle intervention and metformin on health-related quality of life: the diabetes prevention program randomized trial. J Gen Intern Med. 2012;27(12):1594–601. PMID: 22692637. 10.1007/s11606-012-2122-5 22692637
  g Fujimoto WY, Jablonski KA, Bray GA, . Body size and shape changes and the risk of diabetes in the diabetes prevention program. Diabetes. 2007;56(6):1680–5. PMID: 17363740. 10.2337/db07-0009 17363740
  h Haffner S, Temprosa M, Crandall J, . Intensive lifestyle intervention or metformin on inflammation and coagulation in participants with impaired glucose tolerance. Diabetes. 2005;54(5):1566–72. PMID: 15855347 10.2337/diabetes.54.5.1566 15855347
  i Orchard TJ, Temprosa M, Goldberg R, . The effect of metformin and intensive lifestyle intervention on the metabolic syndrome: the Diabetes Prevention Program randomized trial. Annals Intern Med. 2005;142(8):611–9. PMID: 15838067 10.7326/0003-4819-142-8-200504190-00009 15838067
  j Perreault L, Ma Y, Dagogo-Jack S, . Sex differences in diabetes risk and the effect of intensive lifestyle modification in the Diabetes Prevention Program. Diabetes Care. 2008;31(7):1416–21. PMID: 18356403. 10.2337/dc07-2390 18356403
  k Ratner R, Goldberg R, Haffner S, . Impact of intensive lifestyle and metformin therapy on cardiovascular disease risk factors in the diabetes prevention program. Diabetes Care. 2005;28(4):888–94. PMID: 15793191. 10.2337/diacare.28.4.888 15793191
  l Rubin RR, Knowler WC, Ma Y, . Depression symptoms and antidepressant medicine use in Diabetes Prevention Program participants. Diabetes Care. 2005;28(4):830–7. PMID: 15793181. 10.2337/diacare.28.4.830 15793181
  m West DS, Prewitt TE, Bursac Z, . Weight loss of black, white, and Hispanic men and women in the diabetes prevention program. Obesity (Silver Spring). 2008;16(6):1413–20. PMID: 18421273 10.1038/oby.2008.224 18421273
  n Wing RR, Hamman RF, Bray GA, . Achieving weight and activity goals among diabetes prevention program lifestyle participants. Obes Res. 2004;12(9):1426–34. PMID: 15483207. 10.1038/oby.2004.179 15483207
55. Krempf M, Louvet JP, Allanic H, . Weight reduction and long-term maintenance after 18 months treatment with orlistat for obesity. Int J Obes Relat Metab Disord. 2003;27(5):591–7. PMID: 12704403. 10.1038/sj.ijo.0802281 12704403
56. Kuller LH, Pettee Gabriel KK, Kinzel LS, . The Women on the Move Through Activity and Nutrition (WOMAN) study: final 48-month results. Obesity. 2012;20(3):636–43. PMID: 21494228. 10.1038/oby.2011.80 21494228
  a Gabriel KK, Conroy MB, Schmid KK, . The impact of weight and fat mass loss and increased physical activity on physical function in overweight, postmenopausal women: results from the Women on the Move Through Activity and Nutrition study. Menopause. 2011;18(7):759–65. PMID: 21705864. 10.1097/gme.0b013e31820acdcc 21705864
  b Kuller LH, Kinzel LS, Pettee KK, . Lifestyle intervention and coronary heart disease risk factor changes over 18 months in postmenopausal women: the Women On the Move through Activity and Nutrition (WOMAN study) clinical trial.[erratum appears in J Womens Health (Larchmt). 2006 Nov;15(9):1101]. J Womens Health (Larchmt). 2006;15(8):962–74. PMID: 17087620. 10.1089/jwh.2006.15.962 17087620
  c Kuller LH, Kriska AM, Kinzel LS, . The clinical trial of Women On the Move through Activity and Nutrition (WOMAN) study. Contemp Clin Trials. 2007;28(4):370–81. PMID: 17113831. 10.1016/j.cct.2006.10.009 17113831
57. Kulzer B, Hermanns N, Gorges D, . Prevention of diabetes self-management program (PREDIAS): effects on weight, metabolic risk factors, and behavioral outcomes. Diabetes Care. 2009;32(7):1143–6. PMID: 19509014 10.2337/dc08-2141 19509014
58. Kumanyika SK, Fassbender JE, Sarwer DB, . One-year results of the Think Health! study of weight management in primary care practices. Obesity. 2012;20(6):1249–57. PMID: 22051940. 10.1038/oby.2011.329 22051940
  a Kumanyika S, Fassbender J, Phipps E, . Design, recruitment and start up of a primary care weight loss trial targeting African American and Hispanic adults. Contemp Clin Trials. 2011;32(2):215–24. PMID: 21062645. 10.1016/j.cct.2010.11.002 21062645
59. Lindgarde F. The effect of orlistat on body weight and coronary heart disease risk profile in obese patients: the Swedish Multimorbidity Study. J Intern Med. 2000;248(3):245–54. PMID: 10971792. 10.1046/j.1365-2796.2000.00720.x 10971792
60. Little P, Stuart B, Hobbs FR, . An internet-based intervention with brief nurse support to manage obesity in primary care (POWeR+): a pragmatic, parallel-group, randomised controlled trial. Lancet Diabetes Endocrinol. 2016;4(10):821–8. 10.1016/S2213-8587(16)30099-7 27474214
  a Little P, Stuart B, Hobbs FR, . Randomised controlled trial and economic analysis of an internet-based weight management programme: POWeR+ (Positive Online Weight Reduction). Health Technol Assess. 2017;21(4):1–62. PMID: 28122658. 10.3310/hta21040 28122658
61. Logue E, Sutton K, Jarjoura D, . Transtheoretical model-chronic disease care for obesity in primary care: a randomized trial. Obesity Research. 2005;13(5):917–27.15919846
62. Luley C, Blaik A, Gotz A, . Weight loss by telemonitoring of nutrition and physical activity in patients with metabolic syndrome for 1 year. J Am Coll Nutr. 2014;33(5):363–74. PMID: 25105874. 10.1080/07315724.2013.875437 25105874
63. Ma J, Yank V, Xiao L, . Translating the Diabetes Prevention Program lifestyle intervention for weight loss into primary care: a randomized trial. JAMA Internal Medicine. 2013;173(2):113–21. PMID: 23229846. 10.1001/2013.jamainternmed.987 23229846
  a Azar KM, Xiao L, Ma J. Baseline obesity status modifies effectiveness of adapted diabetes prevention program lifestyle interventions for weight management in primary care. Biomed Res Int. 2013;2013:191209. PMID: 24369008. 10.1155/2013/191209 24369008
  b Ma J, King AC, Wilson SR, . Evaluation of lifestyle interventions to treat elevated cardiometabolic risk in primary care (E-LITE): a randomized controlled trial. BMC Fam Pract. 2009;10:71. PMID: 19909549. 10.1186/1471-2296-10-71 19909549
  c Xiao L, Yank V, Wilson SR, . Two-year weight-loss maintenance in primary care-based Diabetes Prevention Program lifestyle interventions. Nutr Diabetes. 2013;3:e76. PMID: 23797383. 10.1038/nutd.2013.17 23797383
64. Marrero DG, Palmer KN, Phillips EO, . Comparison of Commercial and Self-Initiated Weight Loss Programs in People With Prediabetes: A Randomized Control Trial. Am J Public Health. 2016;106(5):949–56. PMID: 26890171. 10.2105/AJPH.2015.303035 26890171
65. Martin CK, Redman LM, Zhang J, . Lorcaserin, a 5-HT(2C) receptor agonist, reduces body weight by decreasing energy intake without influencing energy expenditure. J Clin Endocrinol Metab. 2011;96(3):837–45. PMID: 21190985. 10.1210/jc.2010-1848 21190985
66. Martin PD, Dutton GR, Rhode PC, . Weight loss maintenance following a primary care intervention for low-income minority women. Obesity. 2008;16(11):2462–7. PMID: 18787526. 10.1038/oby.2008.399 18787526
  a Martin DP, Rhode PC, Dutton GR, . A primary care weight management intervention for low-income African-American women. Obesity (Silver Spring). 2006;14(8):1412–20. PMID: 16988084 10.1038/oby.2006.160 16988084
67. Mensink M, Corpeleijn E, Feskens EJ, . Study on lifestyle-intervention and impaired glucose tolerance Maastricht (SLIM): design and screening results. Diabetes Res Clin Pract. 2003;61(1):49–58. PMID: 12849923.12849923
68. Mitsui T, Shimaoka K, Tsuzuku S, . Gentle exercise of 40 minutes with dietary counseling is effective in treating metabolic syndrome. Tohoku J Exp Med. 2008;215(4):355–61. PMID: 18679010 10.1620/tjem.215.355 18679010
69. Moore H, Summerbell CD, Greenwood DC, . Improving management of obesity in primary care: cluster randomised trial. BMJ. 2003;327(7423):1085. PMID: 14604931. 10.1136/bmj.327.7423.1085 14604931
  a Moore H, Summerbell C, Vail A, . The design features and practicalities of conducting a pragmatic cluster randomized trial of obesity management in primary care. Stat Med. 2001;20(3):331–40. PMID: 11180304. 10.1002/1097-0258(20010215)20:3<331::AID-SIM795>3.0.CO;2-K 11180304
70. Morgan PJ, Lubans DR, Collins CE, . 12-month outcomes and process evaluation of the SHED-IT RCT: an internet-based weight loss program targeting men. Obesity. 2011;19(1):142–51. PMID: 20523304. 10.1038/oby.2010.119 20523304
  a Blomfield RL, Collins CE, Hutchesson MJ, . Impact of self-help weight loss resources with or without online support on the dietary intake of overweight and obese men: the SHED-IT randomised controlled trial. Obes Res Clin Pract. 2014;8(5):e476–87. PMID: 25263837. 10.1016/j.orcp.2013.09.004 25263837
  b Collins CE, Jensen ME, Young MD, . Improvement in erectile function following weight loss in obese men: the SHED-IT randomized controlled trial. Obes Res Clin Pract. 2013;7(6):e450–4. PMID: 24459689. 10.1016/j.orcp.2013.07.004 24459689
  c Morgan PJ, Lubans DR, Collins CE, . The SHED-IT randomized controlled trial: evaluation of an Internet-based weight-loss program for men. Obesity (Silver Spring). 2009;17(11):2025–32. PMID: 19343018. 10.1038/oby.2009.85 19343018
  d Young M, Collins C, Callister R, . Testing the efficacy of a gender-tailored intervention to prevent weight regain in men: The SHED-IT Weight Loss Maintenance RCT. Journal of science and medicine in sport. 2014;18:e66. PMID: None. 10.1016/j.jsams.2014.11.295
  e Young MD, Collins CE, Callister R, . The SHED-IT weight loss maintenance trial protocol: A randomised controlled trial of a weight loss maintenance program for overweight and obese men. Contemp Clin Trials. 2014;37(1):84–97. PMID: 24246820. 10.1016/j.cct.2013.11.004 24246820
71. Muls E, Kolanowski J, Scheen A, . The effects of orlistat on weight and on serum lipids in obese patients with hypercholesterolemia: a randomized, double-blind, placebo-controlled, multicentre study. Int J Obes Relat Metab Disord. 2001;25(11):1713–21. PMID: 11753595. 10.1038/sj.ijo.0801814 11753595
72. Nakade M, Aiba N, Suda N, . Behavioral change during weight loss program and one-year follow-up: Saku Control Obesity Program (SCOP) in Japan. Asia Pac J Clin Nutr. 2012;21(1):22–34. PMID: 22374557.22374557
73. Nanchahal K, Power T, Holdsworth E, . A pragmatic randomised controlled trial in primary care of the Camden Weight Loss (CAMWEL) programme. BMJ Open. 2012;2(3). PMID: 22561352. 10.1136/bmjopen-2011-000793 22561352
74. Narayan KM, Hoskin M, Kozak D, . Randomized clinical trial of lifestyle interventions in Pima Indians: a pilot study. Diabet Med. 1998;15(1):66–72. PMID: 9472866. 10.1002/(SICI)1096-9136(199801)15:1<66::AID-DIA515>3.0.CO;2-A 9472866
75. Nicklas JM, Zera CA, England LJ, . A web-based lifestyle intervention for women with recent gestational diabetes mellitus: a randomized controlled trial. Obstet Gynecol. 2014;124(3):563–70. PMID: 25162257. 10.1097/AOG.0000000000000420 25162257
76. Nilsen V, Bakke PS, Gallefoss F. Effects of lifestyle intervention in persons at risk for type 2 diabetes mellitus - results from a randomised, controlled trial. BMC public health. 2011;11:893. 10.1186/1471-2458-11-893 22117618
77. O’Brien MJ, Perez A, Scanlan AB, . PREVENT-DM Comparative Effectiveness Trial of Lifestyle Intervention and Metformin. Am J Prev Med. 2017;52(6):788–97. PMID: 28237635. 10.1016/j.amepre.2017.01.008 28237635
78. Ockene IS, Tellez TL, Rosal MC, . Outcomes of a Latino community-based intervention for the prevention of diabetes: the Lawrence Latino Diabetes Prevention Project. Am J Public Health. 2012;102(2):336–42. PMID: 22390448. 10.2105/AJPH.2011.300357 22390448
  a Merriam PA, Tellez TL, Rosal MC, . Methodology of a diabetes prevention translational research project utilizing a community-academic partnership for implementation in an underserved Latino community. BMC Med Res Methodol. 2009;9:20. PMID: 19284663. 10.1186/1471-2288-9-20 19284663
79. Pacanowski CR, Levitsky DA. Frequent Self-Weighing and Visual Feedback for Weight Loss in Overweight Adults. J Obes. 2015;2015:763680. PMID: 26064677. 10.1155/2015/763680 26064677
80. Parikh P, Simon EP, Fei K, . Results of a pilot diabetes prevention intervention in East Harlem, New York City: Project HEED. Am J Public Health. 2010;100: Suppl 1:S232–S9. PMID: 20147680 10.2105/AJPH.2009.170910 20147680
81. Patrick K, Calfas KJ, Norman GJ, . Outcomes of a 12-month web-based intervention for overweight and obese men. Ann Behav Med. 2011;42(3):391–401. PMID: 21822750. 10.1007/s12160-011-9296-7 21822750
82. Pekkarinen T, Kaukua J, Mustajoki P. Long-term weight maintenance after a 17-week weight loss intervention with or without a one-year maintenance program: a randomized controlled trial. J Obes. 2015;2015:651460. PMID: 25918644. 10.1155/2015/651460 25918644
83. Penn L, White M, Oldroyd J, . Prevention of type 2 diabetes in adults with impaired glucose tolerance: the European Diabetes Prevention RCT in Newcastle upon Tyne, UK. BMC Public Health. 2009;9:342. PMID: 19758428. 10.1186/1471-2458-9-342 19758428
84. Perri MG, McAllister DA, Gange JJ, . Effects of four maintenance programs on the long-term management of obesity. J Consult Clin Psychol. 1988;56(4):529–34. PMID: 2848874.2848874
85. Phelan S, Hagobian T, Brannen A, . Effect of an Internet-Based Program on Weight Loss for Low-Income Postpartum Women. JAMA. 2017;317(23):2381–91. PMID: 28632867. 10.1001/jama.2017.7119 28632867
  a Phelan S, Brannen A, Erickson K, . ‘Fit Moms/Mamas Activas’ internet-based weight control program with group support to reduce postpartum weight retention in low-income women: study protocol for a randomized controlled trial. Trials. 2015;16:59. PMID: 25887964. 10.1186/s13063-015-0573-9 25887964
86. Pi-Sunyer X, Astrup A, Fujioka K, . A Randomized, Controlled Trial of 3.0 mg of Liraglutide in Weight Management. N Engl J Med. 2015;373(1):11–22. PMID: 26132939. 10.1056/NEJMoa1411892 26132939
  a Kolotkin RL, Fujioka K, Wolden ML, . Improvements in health-related quality of life with liraglutide 3.0 mg compared with placebo in weight management. Clin Obes. 2016;6(4):233–42. PMID: 27198973. 10.1111/cob.12146 27198973
  b Wilding JP, Overgaard RV, Jacobsen LV, . Exposure-response analyses of liraglutide 3.0 mg for weight management. Diabetes Obes Metab. 2016. PMID: 26833744. 10.1111/dom.12639 26833744
  c le Roux CW, Astrup A, Fujioka K, . 3 years of liraglutide versus placebo for type 2 diabetes risk reduction and weight management in individuals with prediabetes: a randomised, double-blind trial. Lancet. 2017. PMID: 28237263. 10.1016/S0140-6736(17)30069-7 28237263
87. Puhkala J, Kukkonen-Harjula K, Mansikkamaki K, . Lifestyle counseling to reduce body weight and cardiometabolic risk factors among truck and bus drivers-a randomized controlled trial. Scand J Work Environ Health. 2015;41(1):54–64. PMID: 25310464. 10.5271/sjweh.3463 25310464
88. Richelsen B, Tonstad S, Rossner S, . Effect of orlistat on weight regain and cardiovascular risk factors following a very-low-energy diet in abdominally obese patients: a 3-year randomized, placebo-controlled study. Diabetes Care. 2007;30(1):27–32. PMID: 17192328. 10.2337/dc06-0210 17192328
89. Rock CL, Flatt SW, Byers TE, . Results of the Exercise and Nutrition to Enhance Recovery and Good Health for You (ENERGY) Trial: A Behavioral Weight Loss Intervention in Overweight or Obese Breast Cancer Survivors. J Clin Oncol. 2015;33(28):3169–76. PMID: 26282657. 10.1200/JCO.2015.61.1095 26282657
  a Demark-Wahnefried W, Colditz GA, Rock CL, . Quality of life outcomes from the Exercise and Nutrition Enhance Recovery and Good Health for You (ENERGY)-randomized weight loss trial among breast cancer survivors. Breast Cancer Res Treat. 2015;154(2):329–37. PMID: 26518022. 10.1007/s10549-015-3627-5 26518022
  b Rock CL, Byers TE, Colditz GA, . Reducing breast cancer recurrence with weight loss, a vanguard trial: the Exercise and Nutrition to Enhance Recovery and Good Health for You (ENERGY) Trial. Contemp Clin Trials. 2013;34(2):282–95. PMID: 23266440. 10.1016/j.cct.2012.12.003 23266440
  c Sedjo RL, Flatt SW, Byers T, . Impact of a behavioral weight loss intervention on comorbidities in overweight and obese breast cancer survivors. Support Care Cancer. 2016;24(8):3285–93. PMID: 26945570. 10.1007/s00520-016-3141-2 26945570
90. Rock CL, Pakiz B, Flatt SW, . Randomized trial of a multifaceted commercial weight loss program. Obesity. 2007;15(4):939–49. PMID: 17426329. 10.1038/oby.2007.614 17426329
91. Rodriguez-Cristobal JJ, Alonso-Villaverde C, Panisello JM, . Effectiveness of a motivational intervention on overweight/obese patients in the primary healthcare: a cluster randomized trial. BMC Fam Pract. 2017;18(1):74. PMID: 28633627. 10.1186/s12875-017-0644-y 28633627
  a Rodriguez Cristobal JJ, Panisello Royo JM, Alonso-Villaverde Grote C, . Group motivational intervention in overweight/obese patients in primary prevention of cardiovascular disease in the primary healthcare area. BMC Fam Pract. 2010;11:23. 10.1186/1471-2296-11-23 20298557
92. Rosas LG, Thiyagarajan S, Goldstein BA, . The effectiveness of two community-based weight loss strategies among obese, low-income US Latinos. J Acad Nutr Diet. 2015;115(4):537–50.e2. PMID: 25578925. 10.1016/j.jand.2014.10.020 25578925
  a Drieling RL, Ma J, Stafford RS. Evaluating clinic and community-based lifestyle interventions for obesity reduction in a low-income Latino neighborhood: Vivamos Activos Fair Oaks Program. BMC Public Health. 2011;11:98. PMID: 21320331. 10.1186/1471-2458-11-98 21320331
93. Ross R, Lam M, Blair SN, . Trial of prevention and reduction of obesity through active living in clinical settings: a randomized controlled trial. Arch Intern Med. 2012;172(5):414–24. PMID: 22371872. 10.1001/archinternmed.2011.1972 22371872
  a Ross R, Blair S, Godwin M, . Prevention and Reduction of Obesity through Active Living (PROACTIVE): rationale, design and methods. Br J Sports Med. 2009;43(1):57–63. PMID: 19001014. 10.1136/bjsm.2008.053504 19001014
94. Rossner S, Sjostrom L, Noack R, . Weight loss, weight maintenance, and improved cardiovascular risk factors after 2 years treatment with orlistat for obesity. European Orlistat Obesity Study Group. Obes Res. 2000;8(1):49–61. PMID: 10678259. 10.1038/oby.2000.8 10678259
95. Shapiro JR, Koro T, Doran N, . Text4Diet: a randomized controlled study using text messaging for weight loss behaviors. Prev Med. 2012;55(5):412–7. PMID: 22944150. 10.1016/j.ypmed.2012.08.011 22944150
96. Sherwood NE, Crain AL, Martinson BC, . Enhancing long-term weight loss maintenance: 2 year results from the Keep It Off randomized controlled trial. Prev Med. 2013;56(3–4):171–7. PMID: 23276775. 10.1016/j.ypmed.2012.12.014 23276775
  a Sherwood NE, Crain AL, Martinson BC, . Keep it off: a phone-based intervention for long-term weight-loss maintenance. Contemp Clin Trials. 2011;32(4):551–60. PMID: 21453791. 10.1016/j.cct.2011.03.011 21453791
  b Crane MM, Jeffery RW, Sherwood NE. Exploring Gender Differences in a Randomized Trial of Weight Loss Maintenance. Am J Mens Health. 2016. PMID: 27923968. 10.1177/1557988316681221 27923968
97. Silva MN, Vieira PN, Coutinho SR, . Using self-determination theory to promote physical activity and weight control: a randomized controlled trial in women. J Behav Med. 2009. PMID: 20012179. 10.1007/s10865-009-9239-y 20012179
  a Silva MN, Markland D, Carraca EV, . Exercise autonomous motivation predicts 3-yr weight loss in women. Medicine & Science in Sports & Exercise. 2011;43(4):728–37. PMID: 20689448. 10.1249/MSS.0b013e3181f3818f 20689448
  b Silva MN, Markland D, Minderico CS, . A randomized controlled trial to evaluate self-determination theory for exercise adherence and weight control: rationale and intervention description. BMC Public Health. 2008;8:234.:234. PMID: 18613959 10.1186/1471-2458-8-234 18613959
  c Teixeira PJ, Silva MN, Coutinho SR, . Mediators of Weight Loss and Weight Loss Maintenance in Middle-aged Women. Obesity (Silver Spring). 2010;18(4):725–35. PMID: 19696752. 10.1038/oby.2009.281 19696752
98. Simpson SA, McNamara R, Shaw C, . A feasibility randomised controlled trial of a motivational interviewing-based intervention for weight loss maintenance in adults. Health Technol Assess. 2015;19(50):v–vi, xix–xxv, 1–378. PMID: 26168409. 10.3310/hta19500 26168409
99. Sjostrom L, Rissanen A, Andersen T, . Randomised placebo-controlled trial of orlistat for weight loss and prevention of weight regain in obese patients. European Multicentre Orlistat Study Group. Lancet. 1998;352(9123):167–72. PMID: 9683204.9683204
  a Gotfredsen A, Westergren Hendel H, Andersen T. Influence of orlistat on bone turnover and body composition. Int J Obes Relat Metab Disord. 2001;25(8):1154–60. PMID: 11486790.11486790
100. Smith SR, Stenlof KS, Greenway FL, . Orlistat 60 mg reduces visceral adipose tissue: a 24-week randomized, placebo-controlled, multicenter trial. Obesity. 2011;19(9):1796–803. PMID: 21720429. 10.1038/oby.2011.143 21720429
101. Smith SR, Weissman NJ, Anderson CM, . Multicenter, placebo-controlled trial of lorcaserin for weight management. N Engl J Med. 2010;363(3):245–56. PMID: 20647200. 10.1056/NEJMoa0909809 20647200
  a Handelsman Y, Fain R, Wang Z, . Lorcaserin treatment allows for decreased number needed to treat for weight and glycemic parameters in week 12 responders with >5% weight loss. Postgrad Med. 2016;128(8):740–6. PMID: 27659698. 10.1080/00325481.2016.1240591 27659698
  b Nesto R, Fain R, Li Y, . Evaluation of lorcaserin on progression of prediabetes to type 2 diabetes and reversion to euglycemia. Postgrad Med. 2016;128(4):364–70. PMID: 27116910. 10.1080/00325481.2016.1178590 27116910
102. Smith TJ, Crombie A, Sanders LF, . Efficacy of orlistat 60 mg on weight loss and body fat mass in US Army soldiers. J Acad Nutr Diet. 2012;112(4):533–40. PMID: 22717217. 10.1016/j.jada.2011.10.006 22717217
103. Stevens VJ, Corrigan SA, Obarzanek E, . Weight loss intervention in phase 1 of the Trials of Hypertension Prevention. The TOHP Collaborative Research Group. Arch Intern Med. 1993;153(7):849–58. PMID: 8466377.8466377
  a The Trials of Hypertension Prevention Collaborative Research Group. The effects of nonpharmacologic interventions on blood pressure of persons with high normal levels. Results of the Trials of Hypertension Prevention, Phase I. JAMA. 1992;267(9):1213–20. PMID: 1586398. 10.1001/jama.1992.03480090061028 1586398
  b Whelton PK, Hebert PR, Cutler J, . Baseline characteristics of participants in phase I of the Trials of Hypertension Prevention. Ann Epidemiol. 1992;2(3):295–310. PMID: 1342280. 10.1016/1047-2797(92)90062-U 1342280
104. Stevens VJ, Obarzanek E, Cook NR, . Long-term weight loss and changes in blood pressure: results of the Trials of Hypertension Prevention, phase II. Ann Intern Med. 2001;134(1):1–11. PMID: 11187414. 10.7326/0003-4819-134-1-200101020-00007 11187414
  a The Trials of Hypertention Prevention Collaborative Research Group. Effects of weight loss and sodium reduction intervention on blood pressure and hypertension incidence in overweight people with high-normal blood pressure. Arch Intern Med. 1997;157(6):657–67. PMID: 9080920 10.1001/archinte.1997.00440270105009 9080920
  b Hollis JF, Satterfield S, Smith F, . Recruitment for phase II of the Trials of Hypertension Prevention. Effective strategies and predictors of randomization. Trials of Hypertension Prevention (TOHP) Collaborative Research Group. Ann Epidemiol. 1995;5(2):140–8. PMID: 7795832. 10.1016/1047-2797(94)00058-2 7795832
105. Svetkey LP, Batch BC, Lin PH, . Cell phone intervention for you (CITY): A randomized, controlled trial of behavioral weight loss intervention for young adults using mobile technology.[Erratum appears in Obesity (Silver Spring). 2016 Feb;24(2):536; PMID: 26813533]. Obesity. 2015;23(11):2133–41. PMID: 26530929. 10.1002/oby.21226 26530929
  a Batch BC, Tyson C, Bagwell J, . Weight loss intervention for young adults using mobile technology: design and rationale of a randomized controlled trial - Cell Phone Intervention for You (CITY).[Erratum appears in Contemp Clin Trials. 2014 Nov;39(2):351]. Contemp Clin Trials. 2014;37(2):333–41. PMID: 24462568. 10.1016/j.cct.2014.01.003 24462568
  b Lin PH, Intille S, Bennett G, . Adaptive intervention design in mobile health: Intervention design and development in the Cell Phone Intervention for You trial. Clin Trials. 2015;12(6):634–45. PMID: 26229119. 10.1177/1740774515597222 26229119
106. Svetkey LP, Stevens VJ, Brantley PJ, . Comparison of strategies for sustaining weight loss: the weight loss maintenance randomized controlled trial. JAMA. 2008;299(10):1139–48. PMID: 18334689. 10.1001/jama.299.10.1139 18334689
  a Brantley PJ, Stewart DW, Myers VH, . Psychosocial predictors of weight regain in the weight loss maintenance trial. J Behav Med. 2014;37(6):1155–68. PMID: 24722826. 10.1007/s10865-014-9565-6 24722826
  b Champagne CM, Broyles ST, Moran LD, . Dietary intakes associated with successful weight loss and maintenance during the Weight Loss Maintenance trial. J Am Diet Assoc. 2011;111(12):1826–35. PMID: 22117658. 10.1016/j.jada.2011.09.014 22117658
  c Funk KL, Stevens VJ, Appel LJ, . Associations of internet website use with weight change in a long-term weight loss maintenance program. J Med Internet Res. 2010;12:e29. PMID: 20663751. 10.2196/jmir.1504 20663751
  d Svetkey LP, Ard JD, Stevens VJ, . Predictors of long-term weight loss in adults with modest initial weight loss, by sex and race. Obesity. 2012;20(9):1820–8. PMID: 21527896. 10.1038/oby.2011.88 21527896
  e Svetkey LP, Clark JM, Funk K, . Greater weight loss with increasing age in the weight loss maintenance trial. Obesity. 2014;22(1):39–44. PMID: 23640912. 10.1002/oby.20506 23640912
  f Tyson CC, Appel LJ, Vollmer WM, . Impact of 5-year weight change on blood pressure: results from the Weight Loss Maintenance trial. J Clin Hypertens (Greenwich). 2013;15(7):458–64. PMID: 23815533. 10.1111/jch.12108 23815533
  g Weight Loss Maintenance Trial. Weight Loss Maintenance Trial Protocol. http://www.kpchr.org/wlmpublic (Accessed April 28, 2017). Accessed. PMID: None.
  h Coughlin JW, Brantley PJ, Champagne CM, . The impact of continued intervention on weight: Five-year results from the weight loss maintenance trial. Obesity. 2016;24(5):1046–53. PMID: 26991814. 10.1002/oby.21454 26991814
107. Swinburn BA, Carey D, Hills AP, . Effect of orlistat on cardiovascular disease risk in obese adults. Diabetes Obes Metab. 2005;7(3):254–62. PMID: 15811142. 10.1111/j.1463-1326.2004.00467.x 15811142
108. Thomas JG, Raynor HA, Bond DS, . Weight loss in Weight Watchers Online with and without an activity tracking device compared to control: A randomized trial. Obesity. 2017;25(6):1014–21. PMID: 28437597. 10.1002/oby.21846 28437597
109. Torgerson JS, Hauptman J, Boldrin MN, . XENical in the prevention of diabetes in obese subjects (XENDOS) study: a randomized study of orlistat as an adjunct to lifestyle changes for the prevention of type 2 diabetes in obese patients. Diabetes Care. 2004;27(1):155–61. PMID: 14693982. 10.2337/diacare.27.1.155 14693982
  a Torgerson JS, Arlinger K, Kappi M, . Principles for enhanced recruitment of subjects in a large clinical trial. the XENDOS (XENical in the prevention of Diabetes in Obese Subjects) study experience. Controlled Clin Trials. 2001;22(5):515–25. PMID: 11578785 10.1016/S0197-2456(01)00165-9 11578785
110. Tsai AG, Wadden TA, Rogers MA, . A primary care intervention for weight loss: results of a randomized controlled pilot study. Obesity. 2010;18(8):1614–8. PMID: 20019680. 10.1038/oby.2009.457 20019680
111. Tuomilehto J, Lindstrom J, Eriksson JG, . Prevention of type 2 diabetes mellitus by changes in lifestyle among subjects with impaired glucose tolerance. N Engl J Med. 2001;344(18):1343–50. PMID: 11333990. 10.1056/NEJM200105033441801 11333990
  a Eriksson J, Lindstrom J, Valle T, . Prevention of Type II diabetes in subjects with impaired glucose tolerance: the Diabetes Prevention Study (DPS) in Finland. Study design and 1-year interim report on the feasibility of the lifestyle intervention programme. Diabetologia. 1999;42(7):793–801. PMID: 10440120. 10.1007/s001250051229 10440120
  b Lindstrom J, Eriksson JG, Valle TT, . Prevention of diabetes mellitus in subjects with impaired glucose tolerance in the Finnish Diabetes Prevention Study: results from a randomized clinical trial. J Am Soc Nephrol. 2003;14(7 Suppl 2):S108–13. PMID: 12819313. 10.1097/01.ASN.0000070157.96264.13 12819313
  c Lindstrom J, Louheranta A, Mannelin M, . The Finnish Diabetes Prevention Study (DPS): Lifestyle intervention and 3-year results on diet and physical activity. Diabetes Care. 2003;26(12):3230–6. PMID: 14633807. 10.2337/diacare.26.12.3230 14633807
  d Lindstrom J, Peltonen M, Eriksson JG, . Improved lifestyle and decreased diabetes risk over 13 years: Long-term follow-up of the randomised Finnish Diabetes Prevention Study (DPS). Diabetologia. 2013;56(2):284–93. PMID: 23093136. 10.1007/s00125-012-2752-5 23093136
  e Ruusunen A, Voutilainen S, Karhunen L, . How does lifestyle intervention affect depressive symptoms? Results from the Finnish Diabetes Prevention Study. Diabet Med. 2012;29(7):e126–32. PMID: 22313027. 10.1111/j.1464-5491.2012.03602.x 22313027
  f Uusitupa M, Peltonen M, Lindstrom J, . Ten-year mortality and cardiovascular morbidity in the Finnish Diabetes Prevention Study-secondary analysis of the randomized trial. PLoS ONE. 2009;4(5):e5656. PMID: 19479072 10.1371/journal.pone.0005656 19479072
112. Van Gaal LF, Broom JI, Enzi G, . Efficacy and tolerability of orlistat in the treatment of obesity: a 6-month dose-ranging study. Orlistat Dose-Ranging Study Group. Eur J Clin Pharmacol. 1998;54(2):125–32. PMID: 9626916. 10.1007/s002280050433 9626916
113. van Wier MF, Dekkers JC, Hendriksen IJ, . Effectiveness of phone and e-mail lifestyle counseling for long term weight control among overweight employees. J Occup Environ Med. 2011;53(6):680–6. PMID: 21654441. 10.1097/JOM.0b013e31821f2bbb 21654441
114. Voils C, Olsen M, Gierisch J, . Maintenance of Weight Loss After Initiation of Nutrition Training: A Randomized Trial. Annals Intern Med. 2017;166(7):463–71. PMID: 28241185. 10.7326/M16-2160 28241185
115. von Gruenigen V, Frasure H, Kavanagh MB, . Survivors of uterine cancer empowered by exercise and healthy diet (SUCCEED): a randomized controlled trial. Gynecol Oncol. 2012;125(3):699–704. PMID: 22465522. 10.1016/j.ygyno.2012.03.042 22465522
  a McCarroll ML, Armbruster S, Frasure HE, . Self-efficacy, quality of life, and weight loss in overweight/obese endometrial cancer survivors (SUCCEED): a randomized controlled trial. Gynecol Oncol. 2014;132(2):397–402. PMID: 24369301. 10.1016/j.ygyno.2013.12.023 24369301
116. Wadden T, Volger S, Sarwer D, . A two-year randomized trial of obesity treatment in primary care practice. N Engl J Med. 2011;365(21):1969–79. PMID: 22082239 10.1056/NEJMoa1109220 22082239
  b Sarwer DB, Moore RH, Diewald LK, . The impact of a primary care-based weight loss intervention on the quality of life. Int J Obes (Lond). 2013;37: Suppl 1:S25–30. PMID: 23921778. 10.1038/ijo.2013.93 23921778
  c Vetter ML, Wadden TA, Chittams J, . Effect of lifestyle intervention on cardiometabolic risk factors: results of the POWER-UP trial. Int J Obes (Lond). 2013;37: Suppl 1:S19–24. PMID: 23921777. 10.1038/ijo.2013.92 23921777
117. Wadden TA, Foreyt JP, Foster GD, . Weight loss with naltrexone SR/bupropion SR combination therapy as an adjunct to behavior modification: the COR-BMOD trial. Obesity. 2011;19(1):110–20. PMID: 20559296. 10.1038/oby.2010.147 20559296
118. Wadden TA, Hollander P, Klein S, . Weight maintenance and additional weight loss with liraglutide after low-calorie-diet-induced weight loss: the SCALE Maintenance randomized study.[Erratum appears in Int J Obes (Lond). 2015 Jan;39(1):187], [Erratum appears in Int J Obes (Lond). 2013 Nov;37(11):1514], [Erratum appears in Int J Obes (Lond). 2015 Jan;39(1):187; PMID: 25311036]. Int J Obes (Lond). 2013;37(11):1443–51. PMID: 23812094. 10.1038/ijo.2013.120 23812094
  a Ard J, Cannon A, Lewis CE, . The efficacy and safety of liraglutide 3.0 mg for weight management are similar across races: Subgroup analysis across SCALE and phase 2 randomized trials. Diabetes Obes Metab. 2016. PMID: 26744025. 10.1111/dom.12632 26744025
119. Whelton PK, Appel LJ, Espeland MA, . Sodium reduction and weight loss in the treatment of hypertension in older persons: a randomized controlled trial of nonpharmacologic interventions in the elderly (TONE). TONE Collaborative Research Group. JAMA. 1998;279(11):839–46. PMID: 9515998. 10.1001/jama.279.11.839 9515998
  a Appel LJ, Espeland M, Whelton PK, . Trial of Nonpharmacologic Intervention in the Elderly (TONE). Design and rationale of a blood pressure control trial. Ann Epidemiol. 1995;5(2):119–29. PMID: 7795830. 10.1016/1047-2797(94)00056-Y 7795830
  b Kumanyika SK, Espeland MA, Bahnson JL, . Ethnic comparison of weight loss in the Trial of Nonpharmacologic Interventions in the Elderly. Obes Res. 2002;10(2):96–106. PMID: 11836455. 10.1038/oby.2002.16 11836455
120. Wing RR, Tate DF, Gorin AA, . A self-regulation program for maintenance of weight loss. N Engl J Med. 2006;355(15):1563–71. PMID: 17035649. 10.1056/NEJMoa061883 17035649
121. Wing RR, Venditti E, Jakicic JM, . Lifestyle intervention in overweight individuals with a family history of diabetes. Diabetes Care. 1998;21(3):350–9. PMID: 9540015.9540015
122. Wylie-Rosett J, Swencionis C, Ginsberg M, . Computerized weight loss intervention optimizes staff time: the clinical and cost results of a controlled clinical trial conducted in a managed care setting. J Am Diet Assoc. 2001;101(10):1155–62. PMID: 11678486.11678486
  d Swencionis C, Wylie-Rosett J, Lent MR, . Weight change, psychological well-being, and vitality in adults participating in a cognitive-behavioral weight loss program. Health Psychol. 2013;32(4):439–46. PMID: 22888821. 10.1037/a0029186 22888821
123. Yeh MC, Heo M, Suchday S, . Translation of the Diabetes Prevention Program for diabetes risk reduction in Chinese immigrants in New York City. Diabet Med. 2016;33(4):547–51. PMID: 26179569. 10.1111/dme.12848 26179569
124. Young MD, Callister R, Collins CE, . Efficacy of a gender-tailored intervention to prevent weight regain in men over 3 years: A weight loss maintenance RCT. Obesity. 2017;25(1):56–65. PMID: 27925437. 10.1002/oby.21696 27925437