# Appendix C Literature Flow Diagram

Appendix C Figure 1 displays the literature search results and article flow for the review. A total of 15,484 abstracts were screened and 571 full-text articles were assessed for eligibility. 238 articles (124 studies) were included for Key Questions 1 through 3.