# Appendix B Detailed Methods

## Literature Search Strategies

Key:

- / = subject heading
- $ = truncation
- * = truncation
- ab = word in abstract
- adj# = adjacent within x number of words
- fs = floating subheading
- hw = subject heading word
- id = key phrase identifier
- kw = keyword
- md = methodology
- pt = publication type
- ti = word in title

### Cochrane Central Register of Controlled Trials (CENTRAL)

#1 (weight or adipos*):ti or (obesity or obese or overweight or “weight loss”):ti,ab,kw
#2 behavio*:ti,ab,kw
#3 counsel*.ti,ab,kw
#4 cognitive:ti,ab,kw
#5 (orlistat or alli or xenical or lorcaserin or Belviq or (phentermine near/2 topiramate) or Qsymia or (bupropion near/2 naltrexone) or liraglutide or Victoza or Saxenda or contrave):ti,ab,kw
#6 (diet* or nutrition*):ti,ab,kw
#7 (weightwatcher* or (weight next watcher*)):ti,ab,kw
#8 “physical activity”:ti,ab,kw
#9 exercise:ti,ab,kw
#10 (lifestyle or “life style”):ti,ab,kw next (modification* or intervention*):ti,ab,kw
#11 (or #2-#10)
#12 #1 and #11
#13 “weight loss”:ti,ab,kw next (intervention* or program* or trial*):ti,ab,kw
#14 (weight next reduc*):ti,ab,kw next (intervention* or program* or trial*):ti,ab,kw
#15 “weight management”:ti,ab,kw next (intervention* or program* or trial*):ti,ab,kw
#16 “weight control”:ti,ab,kw next (intervention* or program* or trial*):ti,ab,kw
#17 (“weight loss maintenance” next (intervention* or program* or trial*)):ti,ab,kw
#18 (or #12-#17)
#19 (child* or adolescen* or pediatric* or paediatric*)
#20 adult*
#21 (#19 not #20)
#22 (#18 not #21) Publication Year from 2010 to 2016, in Trials

### Ovid Medline [ALL KQ]

1. Obesity/
2. Obesity, Morbid/
3. Overweight/
4. Obesity, Metabolically Benign/
5. Weight loss/
6. obes$.ti.
7. overweight.ti.
8. weight.ti.
9. (adipos$ or body fat).ti.
10. (obes$ or overweight or weight loss).ti,ab.
11. limit 10 to (“in data review” or in process or “pubmed not medline”)
12. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 11
13. Weight Reduction Programs/
14. Behavior Therapy/
15. Cognitive Therapy/
16. Counseling/
17. Directive Counseling/
18. Self-Help Groups/
19. counsel$.ti,ab.
20. (behav$ adj3 (therap$ or program$ or intervention$)).ti,ab.
21. Health Education/
22. Anti-Obesity Agents/
23. orlistat.ti,ab.
24. alli.ti,ab.
25. xenical.ti,ab.
26. lorcaserin.ti,ab.
27. Belviq.ti,ab.
28. (phentermine adj2 topiramate).ti,ab.
29. Qsymia.ti,ab.
30. (bupropion adj2 naltrexone).ti,ab.
31. liraglutide.ti,ab.
32. Victoza.ti,ab.
33. Saxenda.ti,ab.
34. contrave.ti,ab.
35. Diet, Reducing/
36. Diet, Fat-Restricted/
37. Caloric Restriction/
38. Diet Therapy/
39. (diet$ adj counsel$).ti,ab.
40. (diet$ adj education$).ti,ab.
41. (nutrition$ adj counsel$).ti,ab.
42. (nutrition$ adj education$).ti,ab.
43. (nutrition$ adj intervention$).ti,ab.
44. (diet$ adj (modif$ or therapy or intervention$ or strateg$)).ti,ab.
45. ((diet or dieting or slim$) adj (club$ or organi?ation$)).ti,ab.
46. (weight reduc$ adj diet$).ti,ab.
47. (weightwatcher$ or weight watcher$).ti,ab.
48. Exercise/
49. Exercise Therapy/
50. Motor Activity/
51. Physical Conditioning, Human/
52. Physical Fitness/
53. physical activity.ti,ab.
54. (exercise adj3 (therap$ or program$ or intervention$)).ti,ab.
55. ((lifestyle or life style) adj (modification$ or intervention$)).ti,ab.
56. 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34 or 35 or 36 or 37 or 38 or 39 or 40 or 41 or 42 or 43 or 44 or 45 or 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55
57. 12 and 56
58. Obesity/dh, th, dt, rh [Diet Therapy, Therapy, Drug Therapy, Rehabilitation]
59. Obesity, Morbid/dh, th, dt, rh
60. Overweight/dh, th, dt, rh
61. (weight loss adj (intervention$ or program$ or trial$)).ti,ab.
62. (weight reduc$ adj (intervention$ or program$ or trial$)).ti,ab.
63. (weight management adj (intervention$ or program$ or trial$)).ti,ab.
64. (weight control adj (intervention$ or program$ or trial$)).ti,ab.
65. (weight loss maintenance adj (intervention$ or program$ or trial$)).ti,ab.
66. 57 or 58 or 59 or 60 or 61 or 62 or 63 or 64 or 65
67. limit 66 to “all child (0 to 18 years)”
68. limit 66 to “all adult (19 plus years)”
69. 67 not 68
70. 66 not 69
71. limit 70 to animals
72. limit 70 to humans
73. 71 not 72
74. 70 not 73
75. clinical trials as topic/ or controlled clinical trials as topic/ or randomized controlled trials as topic/ or meta-analysis as topic/
76. (clinical trial or controlled clinical trial or meta analysis or randomized controlled trial).pt.
77. Random$.ti,ab.
78. control groups/ or double-blind method/ or single-blind method/
79. clinical trial$.ti,ab.
80. controlled trial$.ti,ab.
81. meta analy$.ti,ab.
82. 75 or 76 or 77 or 78 or 79 or 80 or 81
83. 74 and 82
84. Mortality/
85. Morbidity/
86. Death/
87. “Drug-Related Side Effects and Adverse Reactions”/
88. safety.ti,ab.
89. harm$.ti,ab.
90. mortality.ti,ab.
91. toxicity.ti,ab.
92. complication$.ti,ab.
93. (adverse adj2 (interaction$ or response$ or effect$ or event$ or reaction$ or outcome$)).ti,ab.
94. adverse effects.fs.
95. toxicity.fs.
96. mortality.fs.
97. (risky behavior$ or risky behaviour$).ti,ab.
98. weight cycling.ti,ab.
99. Athletic injuries/
100. Malnutrition/
101. nutritional defici$.ti,ab.
102. Arrhythmias, Cardiac/
103. Arrhythmia$.ti,ab.
104. Bone Density/
105. (bone adj3 loss).ti,ab.
106. Bone Resorption/
107. (death or deaths).ti,ab.
108. suicide/
109. Suicide, Attempted/
110. suicid$.ti,ab.
111. 84 or 85 or 86 or 87 or 88 or 89 or 90 or 91 or 92 or 93 or 94 or 95 or 96 or 97 or 98 or 99 or 100 or 101 or 102 or 103 or 104 or 105 or 106 or 107 or 108 or 109 or 110
112. 74 and 111
113. case-control studies/ or cohort studies/ or longitudinal studies/ or follow-up studies/ or prospective studies/
114. Questionnaires/
115. case control$.ti,ab.
116. cohort.ti,ab.
117. longitudinal.ti,ab.
118. (follow-up or followup).ti,ab.
119. prospective.ti,ab.
120. (comparison group$ or control group$).ti,ab.
121. observational.ti,ab.
122. retrospective studies/
123. retrospective$.ti,ab.
124. database$.ti,ab.
125. nonrandomi$.ti,ab.
126. 113 or 114 or 115 or 116 or 117 or 118 or 119 or 120 or 121 or 122 or 123 or 124 or 125
127. 112 and 126
128. 83 or 127
129. limit 128 to english language
130. limit 129 to yr="2010 -Current"

### PsycInfo

1. obesity.ti,id,hw.
2. obese.ti,id,hw.
3. overweight.ti,id,hw.
4. weight loss.ti,id,hw.
5. 1 or 2 or 3 or 4
6. weight control/
7. behavior therapy/
8. cognitive behavior therapy/
9. cognitive therapy/
10. Cognitive Techniques/
11. Behavior Modification/
12. Behavior Change/
13. Motivational Interviewing/
14. counseling/
15. counseling.id.
16. counselling.id.
17. orlistat.ti,ab,id,hw.
18. alli.ti,ab,id,hw.
19. xenical.ti,ab,id,hw.
20. lorcaserin.ti,ab,id,hw.
21. Belviq.ti,ab,id,hw.
22. (phentermine adj2 topiramate).ti,ab,id,hw.
23. Qsymia.ti,ab,id,hw.
24. (bupropion adj2 naltrexone).ti,ab,id,hw.
25. liraglutide.ti,ab,id,hw.
26. Victoza.ti,ab,id,hw.
27. Saxenda.ti,ab,id,hw.
28. contrave.ti,ab,id,hw.
29. Diets/
30. Dietary Restraint/
31. Exercise/
32. Physical Activity/
33. Aerobic Exercise/
34. Walking/
35. 6 or 7 or 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17 or 18 or 19 or 20 or 21 or 22 or 23 or 24 or 25 or 26 or 27 or 28 or 29 or 30 or 31 or 32 or 33 or 34
36. 5 and 35
37. random$.ti,ab,id,hw.
38. placebo$.ti,ab,hw,id.
39. controlled trial$.ti,ab,id,hw.
40. clinical trial$.ti,ab,id,hw.
41. meta analy$.ti,ab,hw,id.
42. metaanaly$.ti,ab,hw,id.
43. treatment outcome clinical trial.md.
44. 37 or 38 or 39 or 40 or 41 or 43
45. 36 and 44
46. safety.ti,ab,id,hw.
47. (harm or harms or harmful or harmed).ti,ab,id,hw.
48. “side effects (drug)”/
49. toxicity.ti,ab,id,hw.
50. complication$.ti,ab,id,hw.
51. (adverse adj2 (interaction$ or response$ or effect$ or event$ or reaction$ or outcome)).ti,ab,id,hw. (26219)
52. (risky behavior$ or risky behaviour$).ti,ab,id,hw.
53. mortality.ti,ab,id,hw.
54. morbidity.ti,ab,id,hw.
55. death.ti,ab,id,hw.
56. Nutritional Defici$.ti,ab,id,hw.
57. arrhythmia$.ti,ab,id,hw.
58. (bone adj3 loss).ti,ab,id,hw.
59. bone resorption.ti,ab,id,hw.
60. injur$.ti,ab,id,hw.
61. suicid$.ti,ab,id,hw.
62. 46 or 47 or 48 or 49 or 50 or 51 or 52 or 53 or 54 or 55 or 56 or 57 or 58 or 59 or 60 or 61
63. 36 and 62
64. 45 or 63
65. limit 64 to (100 childhood <birth to age 12 yrs> or 120 neonatal <birth to age 1 mo> or 140 infancy <2 to 23 mo> or 160 preschool age <age 2 to 5 yrs> or 180 school age <age 6 to 12 yrs> or 200 adolescence <age 13 to 17 yrs>)
66. limit 64 to (“300 adulthood <age 18 yrs and older>" or 320 young adulthood <age 18 to 29 yrs> or 340 thirties <age 30 to 39 yrs> or 360 middle age <age 40 to 64 yrs> or “380 aged <age 65 yrs and older>” or “390 very old <age 85 yrs and older>”)
67. 65 not 66
68. 64 not 67
69. limit 68 to (english language and yr="2010 -Current")

### Pubmed, publisher-supplied records

#44 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search (((#43) AND publisher[sb]) AND English[Language]) AND (“2010/01/01"[Date - Publication]: “3000”[Date - Publication])
#43 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search #39 NOT #42
#42 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search #40 NOT #41
#41 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search adult*[tiab]
#40 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search (child*[tiab] OR adolescen*[tiab])
#39 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search #23 OR #38
#38 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search #18 AND #37
#37 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search #24 OR #25 OR #26 OR #27 OR #28 OR #29 OR #30 OR #31 OR #32 OR #33 OR #34 OR #35 OR #36
#36 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search suicid*[tiab]
#35 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search death[tiab] OR deaths[tiab]
#34 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search bone[tiab] AND loss[tiab]
#33 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search arrhythmia*[tiab]
#32 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search nutritional[tiab] AND (deficient*[tiab] OR deficienc*[tiab])
#31 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search weight cycling[tiab]
#30 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search risky[tiab] AND (behavior*[tiab] OR behaviour*[tiab])
#29 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search (adverse[tiab] AND (interaction*[tiab] OR response*[tiab] OR effect*[tiab] OR event*[tiab] OR reaction*[tiab] OR outcome*[tiab]))
#28 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search complication*[tiab]
#27 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search toxicity[tiab]
#26 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search mortality[tiab]
#25 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search (harm[tiab] OR harms[tiab] OR harmful[tiab] OR harmed[tiab])
#24 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search safety[tiab]
#23 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search #18 AND #22
#22 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search #19 OR #20 OR #21
#21 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search (control[tiab] OR controls[tiab] OR controlled[tiab] OR controled[tiab]) AND (trial[tiab] OR trials[tiab])
#20 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search “clinical trial”[tiab] OR “clinical trials”[tiab] OR random*[tiab]
#19 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search systematic review[sb] OR metaanaly*[tiab] OR meta analysis[tiab]
#18 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search #1 AND #17
#17 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search #2 OR #3 OR #4 OR #5 OR #6 OR #7 OR #8 OR #9 OR #10 OR #11 OR #12 OR #13 OR #14 OR #15 OR #16
#16 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search (lifestyle[tiab] OR “life style”[tiab]) AND (modification*[tiab] OR intervention*[tiab])
#15 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search exercise[tiab] AND (therap*[tiab] OR intervention*[tiab] OR program[tiab] OR programs[tiab])
#14 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search “physical activity”[tiab]
#13 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search weightwatcher*[tiab] OR (weight[tiab] AND watcher*[tiab])
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search (diet[tiab] OR dieting[tiab] OR slim*[tiab]) AND (club*[tiab] OR organization*[tiab] OR organisation*[tiab])
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search (diet[tiab] OR diets[tiab] OR dietary[tiab]) AND (intervention*[tiab])
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search (nutrition*[tiab]) AND (intervention*[tiab])
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search (nutrition*[tiab]) AND (education*[tiab])
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search (nutrition*[tiab]) AND (counsel*[tiab])
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search (diet[tiab] OR diets[tiab] OR dietary[tiab]) AND (counsel*[tiab])
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search (diet[tiab] OR diets[tiab] OR dietary[tiab]) AND (education*[tiab])
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search orlistat[tiab] OR alli[tiab] OR xenical[tiab] OR lorcaserin[tiab] OR Belviq[tiab] OR(phentermine[tiab] AND topiramate[tiab]) OR Qsymia[tiab] OR (bupropion[tiab] AND naltrexone[tiab]) OR liraglutide[tiab] OR Victoza[tiab] OR Saxenda[tiab] OR contrave[tiab]
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search cognitive[tiab]
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search (behavio*[tiab] AND (therap*[tiab] OR program*[tiab] OR intervention*[tiab]))
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search counsel*[tiab]
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) Search obese[title] OR obesity[title] OR overweight[title] OR weight[title] OR “body fat”[title] OR adipos*[title]

Appendix B Table 1 Inclusion and Exclusion Criteria

| Include | Exclude
Study aim | Weight loss or weight loss maintenance | - Primary prevention of overweight or obesity; - Treatment of cardiovascular disease; - Management of diabetes*; - Treatment of cancer
Condition definition | Overweight or obesity as defined by BMI or other weight-related measurement
Population | - Adults age ≥18 years who are candidates for weight loss/maintenance interventions and selected based on an above normal BMI (e.g., ≥25 kg/m^2^) or other weight-related measure (e.g., waist circumference); - Patients may or may not have additional risk factors, including hypertension, dyslipidemia, impaired glucose tolerance, or impaired fasting glucose (i.e., prediabetes) | Studies limited to:; - Populations not selected based on a weight-related measure (i.e., BMI, waist circumference, weight); - Adults with secondary causes of obesity, such as steroid use; - Adults with a chronic disease for which weight loss/maintenance is part of disease management (e.g., osteoarthritis, known cardiovascular disease, diabetes mellitus, polycystic ovary syndrome, sleep apnea); - Adults with a known chronic disease not generalizable to the primary care population (e.g., eating disorder, cancer, chronic kidney disease, severe mental illness, cognitive impairment); - Children and adolescents; - Parents (if intended behavior change is directed toward children); - Pregnant women; - Adults in institutions
Setting | - Studies conducted in or recruited from primary care or a health care system or that could feasibly be implemented in or referred from primary care; - In order for an intervention to be feasible for primary care referral, it would need to be conducted as part of a health care setting or be widely available in the community at a national level (e.g., commercial weight loss programs, technology interventions) | Studies conducted in or recruited from settings not generalizable to primary care (e.g., worksites, university classrooms, institutional settings), in a population with pre-existing social ties (e.g., from the same worksite or church), or in a setting where the intervention could not be reproduced in primary care or within a broader health system
Interventions | Interventions focusing on weight loss/maintenance, including the following:; - Behavioral counseling intervention, either alone or as part of a larger multicomponent intervention on healthful diet and nutrition, physical activity, sedentary behavior, or a combination thereof, including but not limited to: assessment with feedback, advice, collaborative goal-setting, assistance, exercise prescriptions (referral to exercise facility or program), arranging further contacts, or provider training; - Pharmacologic interventions that are approved by the U.S. Food and Drug Administration as first-line, long-term weight loss/management medications:; ○ Orlistat; ○ Lorcaserin hydrochloride; ○ Phentermine-topiramate extended release; ○ Naltrexone hydrochloride and bupropion hydrochloride; ○ Liraglutuide (Saxenda); - Combination of these interventions; - Interventions may be delivered via face-to-face contact, telephone, print materials, or technology (e.g., computer-based, text messages), and can be delivered by numerous potential interventionists, including but not limited to: physicians, nurses, exercise specialists, dietitians, nutritionists, and behavioral health specialists | - Surgical procedures (laparoscopic adjustable gastric banding, Roux-en-Y gastric bypass, biliopancreatic diversion with duodenal switch, sleeve gastrectomy); - Nonsurgical devices and procedures (balloon system, vagus nerve stimulation); - Medications that are not approved by the U.S. Food and Drug Administration as long-term weight loss agents, including new agents currently under evaluation (e.g., leptin, peptide YY, oxyntomodulin, melanocortin-4 receptor agonists), agents taken off the market (e.g., fenfluramine, dexfenfluramine, sibutramine), and agents only approved for short-term weight loss (e.g., diethylpropion, phentermine, benzphetamine, phendimetrazine); - Medications only indicated for the treatment of type 2 diabetes (e.g., metformin, pramlintide, empagliflozin, albiglutide, dulaglutide, alogliptin, exenatide); - Complementary and alternative treatments (e.g., acupuncture, mindfulness); - Dietary supplements intended for weight loss (e.g., chitosan, guar gum, chromium, ginseng, glucomannan, green tea, hydroxycitric acid, L-carnitine, psyllium, pyruvate supplements, St. John’s wort, conjugated linoleic acid); - Broader community-based programs (e.g., mass media, social marketing, changes to the community built environment, legislation)
Comparisons | For studies of behavioral interventions:; - No treatment (e.g., wait-list control, usual care); - Attention control (e.g., similar format and intensity to intervention but different content area); - Minimal intervention comparable to usual care (including the use of generic printed/electronic communications); For studies of pharmacologic interventions:; - Placebo; - Two groups must participate in identical behavioral intervention component | For studies of behavioral interventions:; - Active comparators without a control (as defined in the inclusion criteria); For studies of pharmacologic interventions:; - Comparison of different pharmacologic interventions
Outcomes | KQ 1: Health outcomes:; - Mortality; - Morbidity (e.g., diabetic amputation, hypertensive nephrosclerosis); - Depression; - Emotional functioning as measured by mental subscales of quality of life instruments; - Physical functioning as measured by physical subscales of quality of life measures; - Disability measures (global measures only, such as activities of daily living); KQ 2: Weight outcomes (required for inclusion) and incidence or prevalence of related conditions:; - Measured weight (e.g., kilograms, pounds); - Relative weight (e.g., BMI, percent with overweight, percent with obesity); - Total adiposity (e.g., dual-energy x-ray absorptiometry, underwater weighing); - Central adiposity (e.g., waist circumference, waist-to-hip circumference ratio); - Weight maintenance; - Incidence or prevalence of obesity-related conditions (e.g., diabetes mellitus, hypertension, dyslipidemia, cardiovascular disease, sleep apnea); - Proportion of individuals taking medication for an obesity-related condition; KQ 3: Adverse outcomes:; - Treatment-related harms at any time point after intervention begins (e.g., death, medical issue requiring hospitalization or urgent medical treatment, inducement of eating disorder, nausea or other gastrointestinal effects, reduced bone mineral density, vitamin deficiency); - Discontinuation of medication due to adverse effects; - Psychological adverse events related to counseling or medication | KQ 1:; - Functioning (except as enumerated under health outcomes); - Cost-effectiveness; - Behavioral changes (e.g., physical activity, diet, smoking); KQ 2: Cardiometabolic measures (e.g., glucose level, blood pressure, lipid levels)
Timing of outcome assessment | KQs 1, 2: ≥12 months after start of intervention or baseline assessment (if the intervention start cannot be determined) KQ 3: No minimum followup | KQs 1, 2: <12 months after baseline
Country | Studies conducted in economically developed countries, defined as member countries of the Organisation for Economic Co-Operation and Development (2015): Australia, Austria, Belgium, Canada, Chile, Czech Republic, Denmark, Estonia, Finland, France, Germany, Greece, Hungary, Iceland, Ireland, Israel, Italy, Japan, Korea, Luxembourg, Mexico, Netherlands, New Zealand, Norway, Poland, Portugal, Slovak Republic, Slovenia, Spain, Sweden, Switzerland, Turkey, United Kingdom, United States | - Studies conducted in countries with populations not similar to the United States; - Studies conducted in countries that are not a member of the Organisation for Economic Co-Operation and Development
Study design | KQs 1, 2: Randomized or controlled clinical trials, including cluster randomized trials KQ 3:; - Systematic reviews, including meta-analyses, of randomized or controlled clinical trials or cohort studies; - Randomized or controlled clinical trials, including cluster randomized trials; - Large cohort studies or case-control studies reporting serious adverse effects related to weight loss interventions | KQs 1, 2: Any observational studies, ecological studies, case reports, case series, or other noncomparative reviews; letters to the editor KQ 3: Ecological studies, case-series, and case reports
Publication language | English | Non-English
Study quality | Fair or good (according to design-specific USPSTF criteria) | Poor (according to design-specific USPSTF criteria)

## Detailed Data Analysis Methods

We ran random effects meta-analyses using the DerSimonian and Laird method to calculate the pooled differences in means for weight-related outcomes (weight in kilograms, body mass index, percent weight change, and waist circumference) and pooled risk ratios for the proportion of participants losing at least 5 or 10 percent of their baseline weight. We used the between-group differences for each outcome as reported by each respective study and favored adjusted effect estimates over unadjusted. If a between group effect estimate and variance were not provided, we calculated a crude effect estimate.

We converted values in conventional units (pounds, inches) to International System of Units/Système International (SI) values (kilograms, centimeters) for consistency.^388^

In cases where a cluster randomized trial was used but the analysis did not account for the nested nature of the data (as was the case in three trials^231,^ ^232,^ ^269^), we adjusted for the clustering effect by applying a design effect, which was based on an estimated average cluster size (the total number of randomized participants divided by the total number of clusters) and multiplied by an estimated intraclass correlation. We estimated the intraclass correlation to be 0.02 for weight and waist circumference.^389^

Within the pooled analyses, we grouped 12 to 18 month followup data together and 24 month data separately. If a trial reported both 12- and 18-month data, we chose 12 month data to pool. If a trial had more than one active intervention arm, we plotted the most intensive arm or the arm that was the most similar with other interventions included in that respective analysis. We conducted a sensitivity analysis for weight loss at 12-18 months in which we combined data for all active intervention arms to create a single pair-wise comparison to investigate whether choosing one intervention arm altered the effect estimate. The pooled result, including the precision of the estimate, was nearly identical when arms were combined. Thus, we presented the results of the pooled analyses where we choose the most applicable intervention arm from each study. WebPlotDigitizer© version 3.10 was used to extract estimates of within-group means and 95% confidence intervals from figures when tabular or in-text results were not provided.

If the trial did not report some kind of data substitution for missing followup data (e.g., last observation carried forward, baseline observation carried forward) or an analysis that used all observations (e.g., random effects models, general estimating equations), then we used the number of participants with followup in each group for the n’s in the meta-analysis. If not available, we used the n randomized.

We used standard calculations to convert standard errors and 95% confidence intervals to standard deviations:

SD_mean_ = SE_mean_ * sqrt(n) or SD_mean_ = (CI_upper_ - CI_lower_ ) * sqrt(n) / 3.92

If sample size was not large (i.e., less than 60), the calculation of standard deviation from a 95% confidence interval was calculated with the following denominator (based on the t-distribution with degrees of freedom equal to group sample size minus 1):

SD_mean_ = ((CI_upper_ - CI_lower_) * sqrt (n)) / (2 * (intvail ( n - 1,0.025 ))) invttail(), a function in Stata application

If reported, within-group change from baseline was used for analysis. Where change scores were not available, they were calculated from baseline and followup measures if possible, using an outcome-specific correlation (0.90). This correlation was used to estimate the standard deviation in the following formula:^208^

SD_change_ = Sqrt (SD^2^ base + SD^2^ post − ( 2 * SD_base_ * SD_post_ * r_base,post_ ) )

In one study,^274^ results were presented separately for males and females. We used the following formula to calculate a combined mean and standard deviation by group:^208^

Mean_combined_ = N_1_ M_1_ + N_2_ M_2_ / N_1_ + N_2_ SD_combined_ = sqrt((( N_1_ − 1 ) S D_1_ 2 + ( N_2_ − 1 ) S D_2_ 2 + (N_1_ N_2_)/(N_1_ + N_2_) ( M_1_ 2 + M_2_ 2 − 2 M_1_ M_2_ ))/(N_1_ + N_2_ − 1))

The only non-continuous outcomes for which we performed meta-analysis were the proportion of participants losing at least 5 percent and 10 percent of their baseline body weight. We used study-reported adjusted risk ratios as reported; when not reported, we calculated unadjusted risk ratios and 95% confidence intervals using the raw numbers of participants meeting these goals at followup. We calculated the number needed to treat (NNT) for the proportion of participants losing at least 5 percent of their body weight based on the pooled RR and an assumed control risk (ACR) of 14 percent (median proportion in the control groups) using the following formula:^208^

NNT= | (1)/(ACR × (1 − RR)) |

We ran sensitivity analyses for weight loss at 12-18 months using a restricted maximum likelihood model with the Knapp-Hartung modification (using the metareg command in Stata), which is a more conservative approach than the DerSimonian and Laird method when there is substantial heterogeneity or the number of studies is small.^390,^ ^391^ All statistically significant results remained within the restricted maximum likelihood model, so we show results using the DerSimonian and Laird method.^204^

We generated funnel plots to evaluate small-study effects (a possible indication of publication bias) and ran the Egger’s test^209^ (for continuous data) and Peters’ test^210^ (for binary data) to assess statistical significance of imbalance in study size and findings that suggest a pattern.

We investigated whether variability among the results was associated with any pre-specified study, population, or intervention characteristics first qualitatively, using visual displays and tables grouped and sorted by these potentially important characteristics and second, through a series of meta-regressions. Specifically, we examined study quality (good versus fair), country (US versus non-US), link to primary care (conducted in or recruited from primary care versus not), whether the population at elevated cardiovascular risk (increased CV risk, increased subclinical CV risk, and elevated cancer risk versus low risk/unselected), participant selection (self-selected or not reported versus directly recruited), baseline mean body mass index, obesity class (overweight versus class 1 and class 2 obesity; overweight and class 1 obesity versus class 2 obesity), intervention intensity (as continuous number of sessions in the first 12 months and as the continuous number of contacts in the first 12 months), intervention duration (continuous months), main mode of the intervention (mixed, group, individual, or technology-based), whether the intervention included group sessions (yes/no), individual sessions (yes/no), or technology-based components (yes/no), and whether the intervention included self-monitoring (yes/no). Due to concerns about type I errors, we limited exploration of heterogeneity to a single outcome – weight loss in kilograms. Continuous variables were left as continuous variables, and categorical variables were converted to one or more dummy variables. There was some evidence that risk status of the population was correlated with the effect estimates; therefore, we controlled for this variable in all other models.

We used Stata version 13.1 (Stata Corp LP, College Station, TX) for all quantitative analyses. All significance testing was two-sided and results were considered statistically significant if the p-value was 0.05 or less.