# Appendix A Contextual Questions

## Contextual Question 1: Relationship between BMI and disease/mortality

The association between BMI and mortality can be described as a J-shaped curve with progressively greater mortality as BMI increases above 25 to 30 kg/m^2^. Obesity (BMI≥30 kg/m^2^) has been associated with an increased risk of death, especially in adults under the age of 65 years.^70,^ ^71^ According to a 2014 NHANES report, obesity advanced death in the United States by 1.6 years for those with BMIs between 30 and 34.9 kg/m^2^ (Class I) and by 3.7 years for those with BMIs of 35 kg/m^2^ and above (Class II and III obesity).^71^ The burden of obesity was greatest among adults aged 45 to 64 and among women.^71^ Ischemic heart disease, diabetes, cancer (especially liver, kidney, breast, gallbladder, pancreas, endometrial, prostate, and colon cancers), and renal, hepatic, and respiratory diseases are leading causes of death in those who have obesity.^72,^ ^73^

Whether being overweight (BMI 25 to 29.9 kg/m^2^) is associated with an increased mortality risk has been the subject of considerable public health debate.^74^ Some,^73,^ ^75-80^ but not all,^29,^ ^70,^ ^81,^ ^82^ studies have found an increased risk of death in those who are overweight. A 2013 systematic review of 97 studies (2.88 million individuals) found that being overweight was associated with a decreased risk of death.^70^ On the other hand, in an even larger pooled analysis of 239 studies from four continents, the Global BMI Mortality Collaboration reported that after excluding the first 5 years of followup (to control for potential bias from weight change due to occult disease and reverse causation), those who were overweight did have an increased risk of death (OR, 1.07 [95% CI, 1.07 to 1.08] for BMI 25­ to <27.5 kg/m^2^; OR, 1.20 [95% CI, 1.18 to 1.22] BMI 27.5 to <30 kg/m^2^).^79^ However, whether excluding early mortality (2 to 5 years after BMI measurement) reduces or increases bias is controversial.^386^ The difficulty in conducting these studies is that conditions leading to death may cause lower BMI rather than lower BMI causing death (reverse causation bias). A recent analysis of the Nurses’ Health Study (NHS) I and II and the Health Professionals Follow-Up Study (HPFS) attempted to avoid this problem by looking at maximum BMI over 16 years of prospective weight history. Maximum BMI in overweight, Class I obesity, and Class II obesity categories were all associated with a statistically significant increased risk for all-cause death (increased risk of 6%, 24%, and 73%, respectively). The nadir for risk for all-cause death was 22.5 to 24.9 kg/m^2^ among all participants.^80^ In addition, those who were overweight at baseline and remained so during followup did not have an increased risk of death compared with those who were normal weight during the entire observation period. In contrast, those who had obesity throughout the study (at baseline and during followup) had an increased risk of death compared with those without overweight or obesity at all time points.^80^

Being overweight or having obesity has been associated with an increased risk of coronary heart disease (CHD), even after adjustment for established risk factors.^38-41^ The risk of type 2 diabetes has been strongly associated with being overweight or having obesity.^42^ Increasing BMI has been associated with an increased risk of multiple cancers including uterine, gallbladder, kidney, cervical, thyroid, leukemia, multiple myeloma, liver, colon, ovarian, esophagus, pancreas, and postmenopausal breast cancers.^43-47^ For example, based on a 2014 population-based cohort study of 5.24 million U.K. adults, a 1 kg/m^2^ population wide increase in BMI was estimated to result in 3790 additional annual U.K. patients developing one of the cancers positively associated with BMI.^46^ According to a 2017 umbrella review of systematic reviews and meta-analyses, for every 5 kg/m^2^ increase in body mass index, cancer risk increases ranged from 9 percent (RR 1.09, 95% CI 1.06 to 1.13) for rectal cancer among men to 56 percent (RR 1.56, 95% CI 1.34 to 1.81) for biliary tract system cancer.^47^

Other diseases that have been associated with obesity include ischemic stroke,^11,^ ^48,^ ^49^ heart failure,^41^ atrial fibrillation/flutter,^50,^ ^51^ venous thrombosis,^52^ gallstones,^53-55^ gastroesophageal reflux disease,^56^ renal disease,^57,^ ^58^ and sleep apnea.^59^ Midlife obesity has been associated with later-in-life dementia.^60,^ ^61^ Obesity also increases the risk of developing osteoarthritis^62,^ ^63^ and is associated with functional disability.^64^ Some observational studies suggest that individuals with obesity, even those without comorbid diseases, can have a decreased quality of life compared to normal-weight individuals.^65-67^ As a result of the increased morbidity, there is increased use of health care services and costs among individuals with obesity.^68,^ ^69^

Studies may have found different associations between BMI and risk of mortality and morbidity due to underlying population differences. For example, age, ethnicity, health conditions, and/or physical fitness level may influence the association between BMI and health outcomes. As part of CQ1, we examined whether the predictive value of BMI for future mortality and health risks differed by specific population subgroups.

The relationship between BMI and mortality appears to be less reliable in older adults^80^ due to the central fat redistribution, decreased muscle mass, and decreased stature that occurs with aging.^85-88^ The 2013 AHA/ACC/TOS report on the Management of Overweight and Obesity in Adults concluded there was insufficient evidence to address the adequacy of existing BMI cut-points in adults above the age of 65.^3^ However, five pooled analyses, three published since that report, suggest that in community-dwelling adults, optimal BMI changes with aging. While the shape of the curve still appears to be J-shaped, with higher and lower BMIs being associated with increased mortality, the nadir of the curve appears to be shifted upward. While most studies found that those in the overweight range have the lowest mortality,^70,^ ^85,^ ^86,^ ^89^ the Global BMI Mortality Collaboration^79^ found the nadir BMI was 24 kg/m² for baseline ages 70 to 89 years (compared with 22-23 kg/m² in younger age groups). Whether those with Class 1 obesity (BMI 30-35 kg/m²) have an increased mortality risk is less clear, but several of the reviews noted that BMIs in the lower obesity range (i.e.., 30-35 range) may not be associated with increased mortality risk in older-aged people.^70,^ ^85,^ ^89^ Most evidence suggests that those with Class II and III obesity (BMIs>35 kg/m²) have an increased mortality risk.^31,^ ^70,^ ^85,^ ^89^ Obesity has been associated with higher rates of physical and functional disability and functional decline in older populations;^31,^ ^90-92^ however, whether overweight is associated with physical decline is less clear.^31,^ ^90^

The relationship between percent body fat and BMI differs among ethnic groups. For example, for the same BMI, non-Hispanic blacks have the lowest percentage of body fat, followed next by non-Hispanic whites; Mexican Americans and Asians have the greatest percentage of body fat for a given BMI.^4,^ ^5^ Such differences have raised concerns about the appropriateness of current BMI cut-offs for all ethnic groups. However, the BMI thresholds have generally been based on morbidity and mortality outcomes and not the BMI-adiposity relationship.^4^ All ethnic and racial groups have increased mortality, cardiovascular disease risk, and type 2 diabetes risk with increasing BMI, but there may be group-specific differences in absolute risk, the level of BMI at which increased risk occurs, and the strength of the relationship.^6-20^

In Asians, the BMI associated with increased diabetes risk^14,^ ^21-23^ and mortality^24-27^ is lower than in Caucasians, consistent with their higher body fat at a given BMI level; therefore, WHO suggested that countries consider setting lower potential BMI action points for Asians (along the BMI continuum from 23.0 to 27.5 kg/m^2^).^18^ The evidence on whether current BMI cutoffs are appropriate for non-Hispanic blacks and Hispanics is mixed. In 2013, the National Institute of Health and Care Excellence (NICE) in the United Kingdom concluded that blacks and other minority ethnic groups in the United Kingdom are at an equivalent risk of diabetes, other health conditions or mortality at a lower BMI than the white European population.^23^ However, the evidence was not considered sufficient to make recommendations on the use of new BMI thresholds for classifying whether member of these groups have overweight or obesity. In contrast, several studies of U.S. cohorts that were not included in the NICE report have found that obesity is less strongly associated with risk of death among blacks,^28^ especially among black women, and that the BMI associated with the lowest mortality risk may be higher in blacks than whites.^6,^ ^20,^ ^29,^ ^30^ We identified only one study examining Hispanic/Latina women, and it found that those who had obesity at baseline had higher risks of developing a major chronic disease by 85 years of age compared with white women with obesity.^31^ Given the complexity of the relationship between BMI and ethnicity, and the limited, conflicting data, the AHA/ACC/TOS did not recommend changing the BMI thresholds for blacks, Hispanics, or other ethnic groups.^3^ The AHA/ACC/TOS panel noted a “critical” lack of studies on racial-ethnic differences in Western countries to determine whether different cut-points for racial and ethnic subgroups might be appropriate.

The association between being overweight and mortality risk may also be influenced by environmental and person-specific factors such as disease history, diet, and physical activity. For example, in one pooled analysis, individuals with overweight but without cardiovascular risk factors, often termed “metabolically healthy,” did not have a statistically significant increased risk of mortality over 10 years compared with metabolically healthy, normal-weight individuals.^93^ In other studies, fitness level has been a mediating factor in whether overweight individuals have an increased risk of mortality.^94-97^

## Contextual Question 2: Relationship between central adiposity and disease/mortality

Patients with abdominal obesity (also called central adiposity, visceral, android, or male-type obesity) are at increased risk for heart disease, cancer, diabetes, and death.^129-134^ Multiple ways of measuring central adiposity have been proposed, including waist circumference, waist-to-hip ratio,^135^ waist-to-height ratio,^136,^ ^137^ the body shape index (ABSI,^138-140^ derived from weight, height and waist circumference), and anthropometric risk index (ARI,^141^ derived from height, BMI, and ABSI). Waist circumference, which can be measured in clinical settings with a flexible tape placed on a horizontal plane at the level of the iliac crest as seen from the anterior view, is used most frequently by clinicians and is recommended for inclusion as part of the routine obesity evaluation by several organizations including the American Heart Association (AHA), the American College of Cardiology (ACC), The Obesity Society (TOS), the National Institute of Health (NIH), and the Canadian Task Force on Preventive Health Care.

The 2013 AHA/ACC/TOS report on The Management of Overweight and Obesity in Adults concluded that there was a consistent, continuous relationship between increasing waist circumference and increased risk of cardiovascular disease, diabetes, and all-cause mortality.^3^ Due to insufficient evidence, the panel was unable to formulate an evidence statement on specific waist circumference cut-points and recommended more research on this issue. In the absence of evidence, the panel recommended continuing with use of the current cut-points until further evidence became available.^3^ The 1998 Obesity Clinical Practice Guidelines recommended that waist circumference be considered elevated when ≥40 in (102 cm) for men and ≥35 in (88 cm) for women.^147^ However, the WHO Expert Consultation concluded that these levels were associated with substantially increased risk and recommended also using lower cut-points (>94 cm in men, >80 cm in women) to identify increased risk.^148^ The International Diabetes Federation suggested different cut-points for South Asian, Chinese, and Japanese men and women (>90 cm in men, >80 cm in women).^149,^ ^150^

The AHA report suggested future research on the independent and combined effects of BMI and waist circumference to determine whether waist circumference would add to the prediction of chronic disease incidence and mortality by BMI. Since the 2013 AHA/ACC/TOS report, there have been two large pooled analyses, both of which have concluded that waist circumference is associated with mortality risk independent of BMI and that combining waist circumference with BMI may more accurately assess obesity-related mortality risk.^145,^ ^146^

Waist circumference measurements may be particularly useful among elderly populations due to the fat redistribution that occurs with aging.^85^ A pooled analysis of over 58,000 people aged 65 to 74 years old found that waist circumference was associated with mortality after adjusting for BMI. Those with an elevated waist circumference (≥102 cm in men and ≥88 cm in women) had an elevated risk of all-cause mortality across all BMI categories (healthy weight, overweight, and obesity) compared to those with a healthy weight and small waist circumference (<94 cm in men and <80 cm in women). Of particular interest, the relative risk of mortality in older people with a healthy weight combined with a large waist was generally higher than for those with overweight and a small waist.^151^

Whether adding waist circumference to obesity screening in non-white groups improves the prediction of further health outcomes is unclear. Waist circumference has been independently associated with health risk in many higher-risk populations, such as South Asians or Mexicans, who appear to have a higher prevalence of obesity-associated morbidities such as diabetes.^15,^ ^152^ Whether waist circumference can improve the predictive ability of obesity screening for health outcomes has been most closely examined in blacks, but the evidence is conflicting.^28,^ ^131,^ ^153-155^

## Contextual Question 3: Health benefits of weight loss

The epidemiological literature related to the effects of weight loss on long-term health outcomes has several important limitations. First, many studies do not describe whether the weight loss was intentional or unintentional. This is a key distinction as unintentional weight loss is associated with important confounders such as illness, depression, smoking, and heavy drinking.^387^ Another important consideration is the baseline BMI of the population. Whether weight loss has benefits for health may differ among those who have normal, overweight, or obesity, and many studies do not stratify for baseline weight. Also, those who intentionally lost weight often had a higher BMI than those who did not attempt weight loss, even within the same BMI category. Finally, many studies relied on recall to determine the amount of weight loss, dates of weight loss, and whether the loss was intentional. Whether weight loss was sustained was usually not reported. In order to improve applicability of this CQ to the AO report, we limited our review to cohort studies of intentional weight loss among those who were overweight or had obesity at baseline. We included studies that relied on participant recall because there were few studies that used objectively measured weight.

In studies of populations of individuals who are overweight, intentional weight loss was either not associated with long-term mortality^349,^ ^350^ or associated with an increased risk of mortality.^352,^ ^353^ In studies of people with higher BMIs (into the high overweight and obesity category), intentional weight loss was generally associated with a small, decreased risk of mortality, although results varied among subgroups. In the prospective Cancer Prevention Cohort, women with obesity-related illness who intentionally lost any amount of weight had an approximately 20 percent decreased risk of mortality (95% CI, 68 to 94%);^354^ the risk reduction was strongest in women who lost the weight within 1 year. Women without obesity-related illness and men in this same cohort did not have a decreased mortality risk with intentional weight loss.^351^ In contrast, in the British regional heart study cohort, men with BMIs ≥28 kg/m^2^ who lost weight for personal reasons had a lower risk of dying (23% reduction [95% CI, 6 to 95%]).^355^ In men and women in the National Health Survey who had intentional weight loss (mean baseline BMI 30.4 kg/m^2^), mortality risk was lowered by almost 30 percent (71% reduction [95% CI, 55 to 92%). Of interest, those who attempted weight loss had lower mortality rates independent of actual weight loss amount.^356^

Among U.S. women who are overweight, intentional weight loss was not associated with decreased risk of overall cancer, but was associated with a borderline decreased risk of obesity-related cancers (RR, 1.22 [95% CI, 1.00 to 1.50]).^357^ A recent study used data from the Nurses’ Health Study to estimate the 26-year risk of CHD under several hypothetical weight loss strategies. A 5 to 10 percent weight loss among those with a baseline BMI greater than 25 kg/m^2^ was not associated with a decreased risk of cardiovascular disease but was associated with a decreased risk of type 2 diabetes.^358^ Although this study included both intentional and unintentional weight loss, sensitivity analyses including an intentionality question from one questionnaire did not change their findings.

In people who undergo bariatric surgery, there are significant improvements in diabetes,^359,^ ^360^ sleep apnea,^360,^ ^361^ quality of life,^362^ depression,^363^ and pain and physical function.^364^ Data on long-term health outcomes such as mortality, cardiovascular disease, and cancer are still lacking. However, the amount of weight loss that occurs with weight loss surgery is much greater than what can usually be achieved with behavior-based weight loss interventions and only people with severe obesity or obesity with comorbidities are candidates for bariatric surgery. In addition, there are metabolic changes that occur after surgery, independent of weight loss, which could contribute to improvements in health outcomes among those who undergo surgery.

In conclusion, there is little evidence to suggest that intentional weight loss among those who are overweight, especially those with BMIs <28, is associated with decreased mortality. Intentional weight loss among those who have obesity may lead to a small decrease in mortality risk, but the literature is conflicting, especially for men and those without obesity-related comorbidities. The literature is scant and limited on the effects of intentional weight loss on other outcomes such as cardiovascular disease and cancer