# References

1 Cooper JM, Sanchez PJ. Congenital syphilis. Semin Perinatol. 2018;42(3):176–184.29627075
2 Centers for Disease Control and Prevention. Sexually Transmitted Disease Surveillance 2016. Atlanta: U.S. Department of Health and Human Services;2017.
3 Bowen V, Su J, Torrone E, Kidd S, Weinstock H. Increase in incidence of congenital syphilis - United States, 2012-2014. MMWR Morb Mortal Wkly Rep. 2015;64(44):1241–1245.26562206
4 Centers for Disease Control and Prevention (CDC). Sexually Transmitted Diseases Treatment Guidelines, 2015. 2015;64:137.
5 Gomez GB, Kamb ML, Newman LM, Mark J, Broutet N, Hawkes SJ. Untreated maternal syphilis and adverse outcomes of pregnancy: a systematic review and meta-analysis. Bulletin of the World Health Organization. 2013;91(3):217–226.23476094
6 Qin J, Yang T, Xiao S, Tan H, Feng T, Fu H. Reported estimates of adverse pregnancy outcomes among women with and without syphilis: a systematic review and meta-analysis. PloS one. 2014;9(7):e102203.25025232
7 Kingston M, French P, Higgins S, UK national guidelines on the management of syphilis 2015. International journal of STD & AIDS. 2016;27(6):421–446.26721608
8 Hawkes SJ, Gomez GB, Broutet N. Early antenatal care: does it make a difference to outcomes of pregnancy associated with syphilis? A systematic review and meta-analysis. PloS one. 2013;8(2):e56713.23468875
9 Morshed MG, Singh AE. Recent trends in the serologic diagnosis of syphilis. Clinical and Vaccine Immunology. 2015;22(2):137–147.25428245
10 Alexander JM, Sheffield JS, Sanchez PJ, Mayfield J, Wendel GD, Jr. Efficacy of treatment for syphilis in pregnancy. Obstetrics and gynecology. 1999;93(1):5–8.9916946
11 Macy E. Penicillin skin testing in pregnant women with a history of penicillin allergy and group B streptococcus colonization. Ann Allergy Asthma Immunol. 2006;97(2):164–168.16937745
12 Rac MW, Revell PA, Eppes CS. Syphilis during pregnancy: a preventable threat to maternal-fetal health. Am J Obstet Gynecol. 2017;216(4):352–363.27956203
13 Galvao TF, Silva MT, Serruya SJ, Safety of benzathine penicillin for preventing congenital syphilis: a systematic review. PloS one. 2013;8(2):e56463.23437138
14 Warren HP, Cramer R, Kidd S, Leichliter J. State Prenatal Syphilis Screening Policies in the United States, 2016 Matern Child Health J. 2018.
15 Ross CE, Tao G, Patton M, Hoover KW. Screening for human immunodeficiency virus and other sexually transmitted diseases among U.S. women with prenatal care. Obstetrics & Gynecology. 2015;125(5):1211–1216.25932850
16 Schrag SJ, Arnold KE, Mohle-Boetani JC, Prenatal screening for infectious diseases and opportunities for prevention. Obstetrics and gynecology. 2003;102(4):753–760.14551005
17 Neblett Fanfair R, Tao G, Owusu-Edusei K, Gift TL, Bernstein KT. Suboptimal Prenatal Syphilis Testing Among Commercially Insured Women in the United States, 2013. Sexually transmitted diseases. 2017;44(4):219–221.28282647
18 Koumans EH, Rosen J, van Dyke MK, Prevention of mother-to-child transmission of infections during pregnancy: implementation of recommended interventions, United States, 2003-2004. Am J Obstet Gynecol. 2012;206(2):158.e151–158.e111.22030318
19 Adams EK, Gavin NI, Raskind-Hood C, Tao G. Explaining racial differences in prenatal care initiation and syphilis screening among Medicaid-covered pregnant women. J Health Care Poor Underserved. 2009;20(1):177–193.19202256
20 Fowler CI, Gavin NI, Adams EK, Tao G, Chireau M. Racial and ethnic disparities in prenatal syphilis screening among women with Medicaid-covered deliveries in Florida. Matern Child Health J. 2008;12(3):378–393.17636459
21 Sheikh LA, Sarnquist C, Grieb EM, Sullivan B, Maldonado YA. Prenatal screening for infectious diseases: an analysis of disparities and adherence to policy in California. Matern Child Health J. 2009;13(2):260–267.18446431
22 U.S. Preventive Services Task Force (USPSTF). Screening for Syphilis Infection in Pregnancy: U.S. Preventive Services Task Force Reaffirmation Recommendation Statement Annals of Internal Medicine Vol 1502009.
23 Wolff T, Shelton E, Sessions C, Miller T. Screening for syphilis infection in pregnant women: evidence for the U.S. Preventive Services Task Force reaffirmation recommendation statement. Annals of Internal Medicine. 2009;150(10):710–716.19451578
24 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD: U.S. Preventive Services Task Force; Dec 2015.
25 Patnode C, Eder M, Walsh E, Viswanathan M, Lin J. The Use of Rapid Review Methods for the U.S. Preventive Services Task Force. American Journal of Preventive Medicine. In press.
26 Wallace BC, Small K, Brodley CE, Lau J, Trikalinos TA. Deploying an interactive machine learning system in an evidence-based practice center: abstrackr. Proceedings of the 2nd ACM SIGHIT International Health Informatics Symposium. 2012:819–824.
27 Qin JB, Feng TJ, Yang TB, Synthesized prevention and control of one decade for mother-to-child transmission of syphilis and determinants associated with congenital syphilis and adverse pregnancy outcomes in Shenzhen, South China. Eur J Clin Microbiol Infect Dis. 2014;33(12):2183–2198.24973132
28 Boonchaoy A, Wongchampa P, Hirankarn N, Chaithongwongwatthana S. Performance of Chemiluminescent Microparticle Immunoassay in Screening for Syphilis in Pregnant Women from Low-Prevalence, Resource-Limited Setting. J Med Assoc Thai. 2016;99(2):119–124.27249890
29 Wang KD, Xu DJ, Su JR. Preferable procedure for the screening of syphilis in clinical laboratories in China. Infect Dis (Lond). 2016;48(1):26–31.26313112
30 Mmeje O, Chow JM, Davidson L, Shieh J, Schapiro JM, Park IU. Discordant Syphilis Immunoassays in Pregnancy: Perinatal Outcomes and Implications for Clinical Management. Clinical Infectious Diseases. 2015;61(7):1049–1053.26063719
31 Henrich TJ, Yawetz S. Impact of age, gender, and pregnancy on syphilis screening using the Captia Syphilis-G assay. Sexually transmitted diseases. 2011;38(12):1126–1130.22082723
32 Wellinghausen N, Dietenberger H. Evaluation of two automated chemiluminescence immunoassays, the LIAISON Treponema Screen and the ARCHITECT Syphilis TP, and the Treponema pallidum particle agglutination test for laboratory diagnosis of syphilis. Clin Chem Lab Med. 2011;49(8):1375–1377.21619473
33 Liu LL, Lin LR, Tong ML, Incidence and risk factors for the prozone phenomenon in serologic testing for syphilis in a large cohort. Clinical Infectious Diseases. 2014;59(3):384–389.24803377
34 U. S. Preventive Services Task Force. Screening for Syphilis Infection in Nonpregnant Adults and Adolescents: US Preventive Services Task Force Recommendation Statement. Jama. 2016;315(21):2321–2327.27272583
35 AAP Committee on Fetus and Newborn and ACOG Committee on Obstetric Practice. Guidelines for Perinatal Care, 8th Edition. 2017.
36 Coles FB, Muse AG, Hipp SS. Impact of a mandatory syphilis delivery test on reported cases of congenital syphilis in Upstate New York. J Public Health Manag Pract. 1998;4(3):50–56.10186742
37 Shiber L, Todia WJ. Cost and clinical utility of repeated syphilis screening in the third trimester in a high-risk population. Am J Obstet Gynecol. 2014;210(3):267.e261–265.24333235
38 Albright CM, Emerson JB, Werner EF, Hughes BL. Third-Trimester Prenatal Syphilis Screening: A Cost-Effectiveness Analysis. Obstetrics & Gynecology. 2015;126(3):479–485.26244531
39 American Academy of Family Physicians. Clinical Preventive Service Recommendation: Syphilis, Pregnant Women. 2009; http://www.aafp.org/patient-care/clinical-recommendations/all/syphilis.html Accessed 09/21/2017.
40 Akkerman D, Cleland L, Croft G, Routine Prenatal Care. Institute for Clinical Systems Improvement. 2012.
41 National Institute for Care and Excellence (NICE). Antenatal care for uncomplicated pregnancies. London (UK): National lnstitute for Health and Care Excellence 2008.