# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Tina Fan, MD, MPH, at AHRQ; members of the U.S. Preventive Services Task Force who contributed to topic deliberations; Robert Phillips Heine, MD, Jeanne S. Sheffield, MD, Gail Bolan, MD, Benedict I. Truman, MD, and Naomi K. Tepper, MD, MPH, who provided expert review of the draft report; Peter Miksovsky, MD, who served as a clinical consultant during the review process; Smyth Lai, MLS, who conducted literature searches; and Katherine Essick, BS, who provided editorial assistance.