# Chapter 4 Discussion

## Summary of Evidence

Our brief evidence update findings support the understanding that screening for syphilis early in pregnancy reduces congenital syphilis and the need for reflexive testing to investigate initial EIA/CIA positive testing in reverse sequence screening (Table 5). Screening for syphilis in pregnancy at the first prenatal visit to prevent congenital syphilis is standard of care and legally mandated in most places in the United States. Observational evidence not included in this review supports the effectiveness of identification and treatment of syphilis in pregnancy to avoid adverse outcomes of pregnancy, and specifically support identification and treatment as early as possible in pregnancy (as opposed to in the third trimester or at delivery).^5,8,27^ Our update includes longer-term follow-up from an observational study evaluating the implementation of syphilis screening in over 2 million pregnant women in Shenzhen, China, demonstrating an approximate 11-fold decrease in the incidence of congenital syphilis over 10 years. Screening for syphilis utilizing both treponemal and nontreponemal tests in combination are feasible for mass screening and provide a presumptive laboratory diagnosis of syphilis with high accuracy and reliability. Due to the false-positive test results with initial treponemal testing (i.e., CIA or EIA) and a negative RPR and TPPA in low-risk patients or low prevalence populations, clinician education on the reverse sequencing algorithm and interpretation and limitations of syphilis serologic test results in general is critical to avoid over or under diagnosis and treatment errors. Evidence from this review confirms concern for false positives with treponemal-specific screening tests in low-risk pregnant females when the RPR is negative and the prozone phenomenon has been ruled out, supporting the rationale for treponemal reflexive testing. Penicillin G is effective and safe. Observational data support the effectiveness of benzathine penicillin G in preventing congenital syphilis when the mother is treated early in pregnancy and serious harms are uncommon;^5,6^ however, we lack good-quality evidence in pregnant women.^13^ The Jarisch-Herxheimer reaction, which can induce early labor or cause fetal distress in pregnant women, albeit rarely, is more common in primary and secondary syphilis during pregnancy and cannot be mitigated with a different choice of antibiotic.

Table 5 Snapshot of the Evidence

| Rationale and Foundational Evidence | New Evidence Findings | Limitations of New Evidence | Consistency of New Evidence With Foundational Evidence and Current Understanding
Benefits | Screening: Observational studies demonstrate the association of lower adverse outcomes of pregnancy in women with syphilis infection treated in pregnancy vs. those not treated. Treatment: Parenteral penicillin G is highly effective in treating maternal syphilis and preventing congenital syphilis. | Screening: One observational study evaluating the implementation of screening for syphilis in more than 2 million pregnant women in Shenzhen, China demonstrated an 11-fold decrease in congenital syphilis over 10 years. Treatment: Not readdressed. | Included observational study has significant methodologic limitations (i.e., with the use of historical and geographic comparators), as well as significant concerns around external validity of findings (e.g., national data from China suggest a syphilis epidemic). The magnitude of benefit in U.S. practice will depend on underlying rates of syphilis in local practice settings. | Included observational study is consistent with the understanding that universal screening for syphilis early in pregnancy can prevent congenital syphilis.
Harms | Screening: No severe adverse outcomes as screening only requires blood testing (widely available), and these tests (treponemal and nontreponemal) in combination detect syphilis with high accuracy and reliability. Treatment: Parenteral penicillin G is generally accepted as safe; however, evidence is limited in pregnant women. | Screening: Five studies demonstrated that false positives with CIA or EIA in pregnancy are common. One study demonstrated that undiluted serum with high titers of nontreponemal antibodies can result in false-negative RPR testing. Treatment: No new studies examining harms of treatment in pregnant women were identified. | Included diagnostic accuracy studies only report on the test inaccuracy of initial treponemal or nontreponemal test and not the inaccuracy of the entire testing sequence. Different CIA and EIA may have varying test (in)accuracy. | Included studies confirm that CIA and EIA should be used in combination with reflexive testing to screen for syphilis because false positives are common in pregnancy (as well as cannot distinguish between old and current infection).

Abbreviations: RPR = rapid plasma reagin; CIA = chemiluminescent immunoassay; EIA = enzyme immunoassay.

## Repeat Testing in Third Trimester and at Delivery

The CDC and the joint guidelines from the American Academy of Pediatrics and American College of Obstetricians and Gynecologists both recommend repeat screening in the third trimester (at 28-32 weeks) and at delivery in selected women at increased risk for syphilis (Table 3). Only 17 states have mandatory third trimester testing, 12 of which require the test in all women and 5 in women at high risk.^14^ Women at increased risk for infection of syphilis include those living with human immunodeficiency virus, those who are incarcerated or exchange sex for drugs, and those living in a geographic area with high rates of syphilis.^34^ Other risk factors can include those diagnosed with a sexually transmitted infection in pregnancy (not limited to syphilis), those with multiple partners, those with substance use disorders, and those with limited prenatal care.^2,4,35^

One study by Coles and colleagues, which was included in a prior evidence update to support the 2004 USPSTF recommendation on screening for syphilis in pregnancy, evaluated the impact of implementing mandatory syphilis screening at the time of delivery, comparing congenital syphilis detected during the 4 years after implementation to the 1 year before.^36^ This study in upstate New York demonstrated a decrease in the proportion of infants with clinical manifestations of syphilis and an increase in the proportion of infants with positive serology (from increased testing) but without symptoms. This suggests that early detection of the infection led to effective treatment prior to clinical manifestation of disease.

We found no new studies that examined the effectiveness of repeated testing in the third trimester and/or at delivery. Two recent cost-effectiveness analyses modeled the benefit of repeat screening for syphilis in the third trimester. One analysis concluded that an approximate 18-fold increase in syphilis prevalence (about 3.5 percent of deliveries) would be required for the cost of rescreening all women in the third trimester to be equivalent to the money saved by detecting maternal seroconversion and preventing resultant cases of congenital syphilis.^37^ In this study, 113 new cases of syphilis occurred during a 17 year period (193 cases per 100,000 deliveries) in the Cleveland, Ohio metropolitan area. Among these cases there were 17 detected seroconversions in pregnancy, and 7 of these women had repeat testing in the third trimester of pregnancy. A chart review of the 10 women who could have potentially benefitted by implementing universal repeat testing in the third trimester or at delivery found that their newborns were asymptomatic at birth and received a 10-day hospital course of penicillin with no adverse events or unexpected sequelae due to or following treatment. In addition, the authors state that each of these 10 women had specific risk factors which could/should have led to repeat testing (i.e., illicit drug use, incarceration, infection with other sexually transmitted infection, and limited prenatal care). The other analysis evaluated universal syphilis rescreening in the third trimester versus no rescreening;^38^ this model assumed 100 percent of women had screening for syphilis early in pregnancy and a 0.012 percent seroconversion in pregnancy (seroconversion in the previously described study in a high-risk prenatal population in the Cleveland area^37^). This study demonstrated that approximately 66,000 pregnant women would need to be rescreened to prevent one case of congenital syphilis, approximately 570,000 rescreened to prevent one fetal loss, and approximately 950,000 rescreened to prevent one neonatal death from maternal syphilis.

## Limitations

Our review was intended to support the USPSTF reaffirmation process and thus includes only the interval evidence accrued since the last recommendation in 2009. Our review was scoped to identify evidence that could result in a change in this recommendation and therefore has some notable exclusions listed here. It did not include studies addressing the effectiveness of screening or early prenatal care in low- or middle-income countries, as these studies were less applicable to prenatal care in the United States. Likewise, our review did not include the benefits and harms of point-of-care rapid syphilis testing in these settings. Our review did not address the comparative screening accuracy of traditional versus reverse sequence algorithm testing; however, at the time of drafting this report, we were unaware of any studies comparing these two testing algorithms in prenatal care. The benefit of penicillin G for the treatment of syphilis is well established, so new evidence for this question was not included. Because our review was primarily focused on screening, we did not address the efficacy of alternative antibiotic treatments (e.g., ceftriaxone) in pregnant women (with or without penicillin allergies).

## Conclusion

The prevention and early treatment of congenital syphilis is dependent on screening for syphilis in early pregnancy. Our brief evidence update includes one long-term follow-up of an observational study that supports a larger body of evidence that screening for syphilis in pregnancy reduces congenital syphilis. Syphilis in pregnancy is easily identified with recommended screening protocols and effectively treated with penicillin G. Our update includes several diagnostic accuracy studies that confirm the occurrence of false-positive results with treponemal-specific testing in pregnancy, supporting the need for reflexive testing to investigate discordant EIA/CIA positive/RPR negative testing in reverse sequence screening algorithms. We found no studies addressing serious harms of screening for or treatment of syphilis in pregnancy; specifically, we found no studies evaluating the harms of penicillin G in pregnant women with a documented allergy to penicillin.