# Chapter 3 Results

## Literature Search

Our literature search yielded 453 unique citations. From these citations, we accepted 34 articles for review based on titles and abstracts (Appendix B Figure 1). After reviewing the full-text articles and conducting critical appraisal, we included seven studies reported in eight publications. We found one study (two articles) for KQ1, six studies (six articles) for KQ2, and no studies for KQ3. Appendix C contains a list of all full-text articles and their reasons for exclusion.

## Results of Included Studies

### KQ1 Does Screening for Syphilis in Pregnant Women Reduce the Incidence of Congenital Syphilis in Newborns?

We identified only one study that met our inclusion criteria for KQ1.^27^ This study was included in the last evidence update to support the 2009 recommendation statement; however, longer-term follow-up has since been published. This fair-quality observational study, which used both a historical and geographical comparator, was designed to evaluate the implementation of free syphilis screening (with follow-up and treatment) for all pregnant women living in the region of Shenzhen, China.^27^ All pregnant women from January 2002 to December 2012 in 90 hospitals in Shenzhen (n=2,441,237) were offered syphilis and HIV screening. Screening for syphilis was conducted using a nontreponemal test (TRUST) with reflex to treponemal (TPPA) testing if positive. The diagnosis was based on TRUST and TPPA testing in accordance with then-current CDC treatment guidelines. Women testing positive for syphilis by serology were given follow-up visits and treatment (including health education), and their sexual partner(s) was notified. They were also given the opportunity to terminate their pregnancy. Women who chose to continue their pregnancies were treated with three injections of 2.4 million units IM penicillin G at weekly intervals. For those allergic to penicillin, erythromycin was given or patients were advised to terminate their pregnancy. Infants born to mothers treated for syphilis were screened for congenital syphilis at birth, and all cases of congenital syphilis were treated and followed according to CDC treatment guidelines. Maternal and infant outcomes included syphilis testing coverage and positivity rates in pregnant women, follow-up rates among women with infection, incidence of congenital syphilis, and other adverse pregnancy outcomes.

From 2002 to 2012, 8,455 of the 2,441,237 pregnant women screened tested positive for syphilis.^27^ The timing of screening pregnant women was not reported; however, the mean gestational week of treatment was 26.5 weeks (SD 11.2 weeks, range 3 to 43 weeks). The trend over the 10 years of observation of the timing of screening and/or treatment was not reported (e.g., if screening and/or treatment occurred earlier in pregnancy in later years). From 2002 to 2012, screening for syphilis in all pregnant women increased from 89.8 percent to 97.2 percent, and the incidence of congenital syphilis decreased from 109.3 to 9.4 cases per 100,000 live births. During this same period, in pregnant women infected with syphilis, the incidence of all adverse outcomes declined from 42.7 percent to 19.2 percent; congenital syphilis declined from 11.7 percent to 3.2 percent; and stillbirth or fetal loss declined from 19.0 percent to 3.3 percent. While this study does not include a true historical comparator (i.e., a time point before implementation of the screening program) since the screening program was initiated in 2001 and screening commenced in 2002, the authors also report the incidence of congenital syphilis in Shenzhen compared with the national incidence. No further details of national incidence data were reported (i.e., unclear if national data excludes Shenzhen). From 2002 to 2012, the incidence of congenital syphilis in China increased from 5.9 to 97.4 cases per 100,000 live births in China, while incidence of congenital syphilis specifically in Shenzhen decreased from 109.3 to 9.4 cases per 100,000 live births. No p-values are reported for any of these comparisons or trends of outcomes. Despite the limitations with both the historical and geographical comparisons, this study provides observational evidence that screening for, coupled with treatment of, syphilis in pregnancy is associated with a decrease in congenital syphilis and adverse outcomes in pregnancy.

### KQ2 What Are the Harms of Screening for Syphilis in Pregnant Women?

We found five studies in pregnant women that reported on false positives of treponemal tests,^28–32^ one of which also reported on false negatives,^32^ and one study that reported on false negatives of non-treponemal testing (Table 4).^33^ We found no studies addressing other potential harms of screening for syphilis in pregnant women. Four large, fair-quality retrospective studies evaluated the proportion of false positives using CIA (ARCHITECT or LIAISON) or EIA (Captia Syph-G) in screening pregnant women for syphilis.^28–31^ All of these tests are cleared for use in the United States by the FDA. Two of these studies were conducted in the United States.^30^ Three of these studies used reflex testing with RPR and TPPA,^28,30,31^ and one study used reflex testing with TPPA and an immunoblot for confirmation of discordant samples (CIA positive/TPPA negative).^29^ Details on the study populations (e.g., age, race/ethnicity, risk, gestational age at time of screening) were generally not reported. These studies found that false positives with EIA or CIA were common (46.5-88.2 percent), therefore warranting reflexive testing for all CIA or EIA test positives. None of the studies reported confidence intervals for false positives. As well, none performed follow-up testing on CIA or EIA negative tests and therefore could not determine false negatives.

Table 4 Harms of Screening for Syphilis in Pregnant Women

Author, Year | Quality Study Design | Country Years Patient Selection | N Pregnant Women Screened | Test Evaluated Cutoff | Testing Strategy | Test Positivity (%) | Harm
Reported Harm: False-Positive Results
Chemiluminescent Immunoassay (CIA)
Boonchaoy, 2016^28^ | Fair Retrospective | Thailand 2011–2013 Pregnant women only | 11,640 | ARCHITECT S/CO value ≥1.00 | Reflex testing with RPR and TPPA | 65/11,640 (0.56%) | 35/65 (53.8%) false positives
Wang, 2016^29^ | Fair Retrospective | China 2013 General population, including pregnant women | 9,600 | ARCHITECT S/CO value >1.00 | Reflex testing with TPPA; immunoblot used for confirmation of discordant samples | 34/9,600 (0.35%) | 30/34 (88.2%) false positives
Mmeje, 2015^30^ | Fair Retrospective | US 2007–2010 Pregnant women only | NR^*^ | LIAISON NR | Reflex testing with RPR and TPPA | NR | 156/194^†^ (80.4%) false positives
Wellinghausen, 2011^32^ | Fair Prospective | Germany 2010 General population, including pregnant women | 318 | ARCHITECT, LIAISON ARCHITECT: Index ≥1.0; LIAISON: Index ≥0.9 | Reflex testing with FTA-Abs; immunoblot used for confirmation of discordant samples | ARCHITECT: 0/318 (0%) LIAISON: 1/318 (0.31%) | ARCHITECT: NA LIAISON: 0/1 (0%) false positives
Enzyme Immunoassay (EIA)
Henrich, 2011^31^ | Fair Retrospective | US 2004–2007 General population, including pregnant women | NR^‡^ | Captia Syph-G NR | Reflex testing with RPR and TPPA | NR | 20/43^§^ (46.5%) false positives
Treponema pallidum particle agglutination (TPPA)
Wellinghausen, 2011^32^ | Fair Prospective | Germany 2010 General population, including pregnant women | 318 | TPPA Titer ≥1:80 | Reflex testing with FTA-Abs; recombinant IgG and IgM immunoblot used for confirmation of discordant samples | 2/318 (0.63%) | 1/2 (50%) false positives
Reported Harm: False-Negative Results
Rapid Plasma Reagin (RPR)
Liu, 2014^33^ | Fair Retrospective | China 2010–2013 General population, including pregnant women | NR | RPR, TPPA RPR: Reactive at dilution of 1:1 TPPA: Titer ≥1:80 | RPR test repeated for RPR-, TPPA+ samples using serum diluted to 1:32 Reflex testing of TPPA+ samples with CIA | NR | 4/139 (2.9%) false negatives (prozone phenomenon)
Chemiluminescent Immunoassay (CIA)
Wellinghausen, 2011^32^ | Fair Prospective | Germany 2010 General population, including pregnant women | 318 | ARCHITECT, LIAISON ARCHITECT: Index ≥1.0; LIAISON: Index ≥0.9 | Reflex testing with FTA-Abs; immunoblot used for confirmation of discordant samples | ARCHITECT: 0/318 (0%) LIAISON: 1/318 (0.31%) | ARCHITECT: 0/317 (0%) false negatives LIAISON: 0/317 (0%) false negatives
Treponema pallidum particle agglutination (TPPA)
Wellinghausen, 2011^32^ | Fair Prospective | Germany 2010 General population, including pregnant women | 318 | TPPA Titer ≥1:80 | Reflex testing with FTA-Abs; recombinant IgG and IgM immunoblot used for confirmation of discordant samples | 2/318 (0.63%) | 0/316 (0%) false negatives

* All pregnant women tested with reverse sequence algorithm at Kaiser Permanente Northern California.

† 194 women with CIA+, RPR- serology.

‡ All pregnant women screened with IgG EIA at first prenatal visit.

§ 43 pregnant women with positive EIA.

Abbreviations: S/CO = sample/cutoff; RPR = rapid plasma reagin; TPPA = Treponema pallidum particle agglutination; WB = Western blotting; NR = not reported; CIA = chemiluminescent immunoassay; FTA-ABS = fluorescent treponemal antibody absorption test; Ig = immunoglobulin; NA = not applicable; EIA = enzyme immunoassay.

One fair-quality prospective study evaluated the diagnostic accuracy of CIA (ARCHITECT and LIAISON) and TPPA in 318 pregnant women using reflex testing with FTA-Abs and an immunoblot for confirmation of discordant samples (CIA or TPPA positive/FTA-Abs negative).^32^ This study had only one test positive for CIA testing and two test positives for TPPA testing and therefore could not provide robust estimates of false positives. This study found no false negatives for any of the three tests.

One fair-quality retrospective study evaluated the prozone phenomenon using RPR testing.^33^ The prozone phenomenon occurs when undiluted serum containing a high titer of nonspecific antibody (as may occur in secondary syphilis) produces a false negative due to a large quantity of antibodies occupying all the antigen sites (preventing flocculation).^9^ This study repeated RPR testing in discordant samples (RPR negative/TPPA positive) using diluted serum, and found that 2.9 percent of discordant samples had a false-negative RPR test due to the prozone phenomenon.

### KQ3 What Are the Harms of Treatment of Syphilis With Penicillin During Pregnancy to Pregnant Women or Newborns?

We found no studies directly examining the harms of penicillin when used in pregnancy. We found no studies that addressed the risk of the Jarisch-Herxheimer reaction or serious adverse events in women with a history of penicillin allergy.