# Chapter 2 Methods

## Scope and Purpose

The USPSTF will use this evidence update to update its 2009 recommendation on screening pregnant women for syphilis infection.^22,23^ Topics that represent well-established, evidence-based standards of practice that are within the scope of the USPSTF and remain a USPSTF priority (i.e., the USPSTF has a reason to keep the recommendations active) undergo an updating process known as “reaffirmation”.^24^ Systematic review methods for reaffirmation evidence updates are described in detail elsewhere.^25^ The aim for evidence updates supporting the reaffirmation process is to identify “new and substantial evidence sufficient enough to change the prior recommendation”.^24,25^ As such, only targeted key questions included in the previous review on screening for syphilis in pregnancy are updated; we did not update the evidence on the effectiveness of treatment of syphilis in pregnancy with penicillin. In consultation with members of the USPSTF, we developed an analytic framework (Figure 2) and three Key Questions (KQs) to guide our evidence update.

Figure 2 Analytic Framework

Figure 2 is the analytic framework that depicts the three Key Questions addressed in the systematic review. The figure illustrates the overarching question addressing the effectiveness of screening for syphilis in pregnant women (KQ1) and its relationship to the two additional questions addressing the harms of screening for syphilis in pregnant women (KQ2) and the harms of treatment of syphilis with penicillin during pregnancy (KQ3).

1. Does screening for syphilis in pregnant women reduce the incidence of congenital syphilis in newborns?
2. What are the harms of screening for syphilis in pregnant women?
3. What are the harms of treatment of syphilis with penicillin during pregnancy to pregnant women or newborns?

## Data Sources and Searches

We conducted a literature search of MEDLINE, PubMed Publisher-Supplied Records, and the Cochrane Central Register of Controlled Trials (CENTRAL) from January 1, 2008 to June 2, 2017. We worked with a research librarian to develop our search strategy, which was peer-reviewed by a second research librarian (Appendix B). We supplemented these searches by reviewing reference lists of recent reviews and primary studies. We limited our searches to articles published in English. We managed literature search results using Endnote® version X7 (Thomson Reuters, New York, NY).

## Study Selection

We developed specific inclusion criteria to guide study selection (Appendix B Table 1). Two reviewers independently reviewed the title and abstracts of all identified articles using Abstrackr.^26^ Two reviewers then independently evaluated the full text of all potentially relevant articles. We resolved differences in the abstract or full-text review by discussion. For all KQs, we included studies conducted in primary care and primary care-referable settings in countries categorized as “high” or “very high” on the Human Development Index. We excluded editorials, narrative reviews, and case studies.

For evidence on the benefits of screening for syphilis in pregnancy (KQ1), we included randomized or non-randomized controlled trials and large before-after or ecologic studies reporting the effect of implementing a widespread screening program on the incidence of congenital syphilis and other adverse outcomes in pregnant women with syphilis. For evidence on the harms of screening (KQ2), we included studies in pregnant women reporting psychosocial harms, stigma, and screening test inaccuracy (i.e., false-positive or false-negative results). For KQs 1 and 2, we selected studies of screening for syphilis in asymptomatic pregnant women using either traditional or reverse sequence algorithms. We excluded studies of screening tests not currently used in United States primary care settings and studies of women living with HIV. For evidence on the harms of treatment (KQ3), we included studies of penicillin treatment for syphilis in pregnant women that reported any maternal or neonatal harms.

## Quality Assessment and Data Abstraction and Synthesis

Two reviewers independently assessed the methodological quality of each included study using predefined criteria (Appendix B Table 2); disagreements were resolved by discussion. We extracted important study and participant characteristics and outcomes, and synthesized the evidence from included studies in a narrative format, with an accompanying summary table for KQ2.

## Expert Review and Public Comment

A draft Research Plan for this review was available for public comment from June 8 to July 5, 2017. Based on these comments, no substantive changes to the key questions or inclusion criteria were made. The draft version of this report was reviewed by content experts and USPSTF Federal Partners from the CDC. Additionally, a draft of the full report was posted on the USPSTF Web site from February 6, 2018 to March 5, 2018. Based on expert and public comments, revisions were made to update the report and help with clarity of the contextual information (report introduction and discussion); however, no changes made to the results or interpretation of the evidence.

## USPSTF Involvement

This reaffirmation evidence update was funded by AHRQ under contract to support the USPSTF. We consulted with USPSTF members at the development of the research plan (i.e., KQs, analytic framework, and inclusion criteria). An AHRQ Medical Officer provided project oversight, reviewed the draft and final versions of the evidence update, and assisted with public comment on the research plan and draft report. The USPSTF and AHRQ had no role in the study selection, quality assessment, or writing of the evidence update.