# Chapter 1 Introduction

## Condition Background

### Condition Definition

Syphilis is an infectious disease caused by Treponema pallidum (T. pallidum) via sexual or vertical transmission. The disease is divided into three clinical stages (i.e., primary, secondary, and tertiary) depending on the duration of the infection and signs/symptoms. Syphilis can also lack any clinical manifestations (i.e., latent infections). Congenital syphilis is the infection of the fetus, which occurs through vertical transmission during pregnancy from the infected mother (i.e., transmitted to the fetus via the placenta). Vertical transmission of syphilis can occur in all stages of syphilis and in every trimester of pregnancy. Congenital syphilis can result in fetal or perinatal death as well as morbidity in surviving newborns.^1^

### Disease Incidence and Burden of Disease

While the incidence of primary and secondary syphilis infection in the United States were at historic lows in 2000, new infections have since increased and continue to increase over time. In 2016, the rate of reported primary or secondary syphilis in the United States was 8.7 cases per 100,000 individuals (both men and women), up from 4.5 cases per 100,000 individuals in 2011. In 2016, this rate was 1.9 cases per 100,000 women, with considerable racial/ethnic variation: from 6.3 cases per 100,000 Black women to 0.9 per 100,000 White women and 0.4 cases per 100,000 Asian women (Table 1).^2^ National rates of syphilis in pregnant women are not available. Likewise, the rates of congenital syphilis have increased over time. In the United States, the rate of reported congenital syphilis was 15.7 cases per 100,000 live births in 2016, the highest rate reported since 1998.^2,3^ Again, there was considerable variation in congenital syphilis by race/ethnicity, mirroring the disparities seen in primary and secondary syphilis, from 43.1 cases per 100,000 live births in Black women to 5.3 cases per 100,000 live births in White women in 2016 (Table 1).^2^ In 2016, rates for both syphilis and congenital syphilis were highest in the South and West, as compared to the Northeast and Midwest regions of the United States (Table 2).

Table 1 Rates of Reported Syphilis Cases by Race/Ethnicity and Age Group, United States, 2016^2^

Age | White | Black | Asian | Native Hawaiian/Other Pacific Islander | American Indian/Alaska Native | Hispanic | Total
Primary and Secondary Syphilis Among Women, Rates per 100,000 Population
15-19 | 1.1 | 13.6 | 0.4 | 10.2 | 3.4 | 2.2 | 3.3
20-24 | 3.0 | 21.9 | 1.3 | 8.7 | 8.2 | 6.0 | 6.7
25-29 | 3.0 | 18.2 | 0.8 | 0.0 | 14.4 | 4.8 | 5.6
30-34 | 2.6 | 11.3 | 0.9 | 0.0 | 12.2 | 4.9 | 4.3
35-39 | 2.1 | 7.3 | 1.2 | 14.4 | 8.1 | 2.5 | 3.0
40-44 | 1.3 | 3.8 | 0.7 | 0.0 | 4.1 | 2.0 | 1.9
All ages | 0.9 | 6.3 | 0.4 | 2.5 | 3.7 | 1.9 | 1.9
Congenital Syphilis, Rates per 100,000 Live Births
| 5.3 | 43.1 | NA | NA | 31.6 | 20.5 | 15.7

Table 2 Rates of Reported Syphilis Cases by Region, United States, 2016^2^

Northeast | Midwest | South | West | Total
Primary and Secondary Syphilis Among Women, Rates per 100,000 Population
0.9 | 1.2 | 2.2 | 2.7 | 1.9
Congenital Syphilis, Rates per 100,000 Live Births
5.4 | 8.4 | 17.8 | 25.6 | 15.7

Untreated syphilis in pregnancy carries significant risk of infant morbidity and mortality, commonly referred to as adverse pregnancy outcomes of syphilis. These outcomes include stillbirth or fetal loss and premature birth, low birthweight, congenital syphilis, and neonatal death in live-born infants. The risk for fetal infection or congenital syphilis at delivery is related to the stage of untreated syphilis during pregnancy. The highest risk occurs with primary and secondary syphilis, although fetal infection can also occur with latent syphilis, including if low titers in pregnant women.^4^ In a 2013 systematic review of six case-control studies on adverse outcomes in pregnancy from untreated maternal syphilis, the estimated absolute difference for pregnant women with untreated syphilis versus those without syphilis was 21 percent for stillbirth or fetal loss, 9 percent for neonatal death, and 5 percent for prematurity or low birthweight. Signs and symptoms of syphilis were found in 15 percent of infants born to untreated women.^5^ Most of these studies were conducted in times and places in which penicillin was not widely available. A 2014 systematic review of 54 observational studies (the majority of which were conducted in China) compared adverse pregnancy outcomes of untreated women with syphilis versus treated women with syphilis versus women without syphilis. The pooled estimate of the incidence of congenital syphilis was 36.0% for untreated women with syphilis and 14.0% for treated women with syphilis. This review also demonstrated dramatically better outcomes in terms of incidence of preterm birth, low birthweight, stillbirth, and neonatal death in women without syphilis and women treated for syphilis, compared with untreated women with syphilis. This review also found that the absolute difference for stillbirth or fetal loss was only slightly less in women treated in the third trimester (17.6 percent) versus untreated women with syphilis (22.7 percent), when compared to women without syphilis.^6^

Around two-thirds of infants with congenital syphilis will be asymptomatic at birth, but most will develop signs in the first several weeks.^7^ Forty to 60 percent of infants with congenital syphilis will have one of the following: rash, hemorrhagic rhinitis, lymphadenopathy, hepatosplenomegaly, and skeletal abnormalities.^7^

### Screening

Prevention and detection of congenital syphilis depend primarily on the identification of syphilis in pregnant women. Multiple observational studies have demonstrated that the greatest association with reductions in adverse infant and pregnancy outcomes are observed when penicillin is administered early in pregnancy, which supports the rationale for screening for syphilis in the early stages of gestation.^6,8^ Repeat screening for syphilis near term (i.e., at the beginning of the third trimester) or at delivery serves primarily to detect congenital cases and allow for early treatment, as opposed to preventing incident cases of congenital syphilis.

Nontreponemal tests measure antibodies not specific to T. pallidum and therefore are not specific to syphilis. Nontreponemal tests include rapid plasma reagin (RPR), venereal disease research laboratory (VDRL), and toluidine red unheated serum (TRUST). Nontreponemal tests can be qualitative or quantitative (measure titers). Treponemal tests detect antibodies directed against T. pallidum proteins. Treponemal tests include fluorescent treponemal antibody absorbed (FTA-ABS), T. pallidum particle agglutination (TPPA), enzyme immunoassays (EIA), chemiluminescence immunoassays (CIA), and microbead immunoassays (MBIA). Treponemal tests are qualitative and generally remain positive after treatment. Serologic laboratory diagnosis of syphilis always requires detection of two types of antibodies: a treponemal test and a quantitative nontreponemal test. Direct detection methods (i.e., darkfield microscopy, PCR, and direct fluorescent antibody test) are used as diagnostic (not screening) tests for symptomatic persons with signs of primary or secondary syphilis and are not widely available.

Two screening protocols are commonly used in pregnant women: 1) the traditional screening algorithm (i.e., nontreponemal testing with reflex to treponemal testing), and 2) the reverse sequence screening algorithm (i.e., treponemal testing with reflex to nontreponemal testing) (Figure 1).^9^ In the traditional algorithm, because the initial nontreponemal testing can have a high rate of false positives, confirmation with a treponemal test (TPPA preferred) is required. Easier automation with less subjective test results, and lower cost in high-volume settings has resulted in the adoption of the reverse sequence algorithm in many clinical settings in the United States. Typically, EIA or CIA tests are used at the initial test. These tests cannot distinguish between active, untreated, and old treated infections; so if the initial test is positive, reflexive testing to a quantitative nontreponemal test (RPR preferred) is required. If the tests are discordant (EIA or CIA positive/nontreponemal test negative), a different treponemal test (TPPA preferred) should be performed (ideally on the same specimen) to confirm the results of the initial EIA or CIA test. If the second treponemal test is negative, the initial EIA or CIA positive test may be a false-positive result in low-risk individuals or populations. In pregnant women at high risk for infection with an initial positive EIA/CIA screening test and negative RPR and TPPA, syphilis is possible as the EIA/CIA could be a true positive so either presumptive treatment (if follow-up is unlikely), or a repeat RPR in one month can be considered. If the second treponemal test is positive, women with known previous treatment of syphilis require no further management unless a careful sexual history suggests likelihood of re-exposure. Those with previous inadequate treatment or without a known prior history of treatment should be offered treatment.^4^

Figure 1 Syphilis Serologic Screening Algorithms*

* Adapted from: Centers for Disease Control and Prevention (CDC). Discordant results from reverse sequence syphilis screening – five laboratories, United States, 2006-2010. MMWR Morb Mortal Wkly Rep. 2011;60(5):133-7.

Figure 1 is a flow diagram adapted from the CDC that depicts the two serologic screening algorithms for syphilis. The traditional screening algorithm uses an initial nontreponemal test with reflex to treponemal testing for initial test positivity. The reverse sequence screening algorithm uses an initial treponemal specific test with reflex to nontreponemal testing for initial test positivity. In the reverse sequence screening algorithm, discordant testing (i.e., initial treponemal test positive, nontreponemal test negative) is confirmed using a second treponemal specific test.

Several treponemal-specific point-of-care tests (POCT) are widely available in low- and middle-income countries to expand the range of settings in which early diagnosis and rapid access to treatment can be applied.^9^ These POCT (i.e., immunochromatographic strip [ICS] tests, particle agglutination tests [PAT]) are generally not used for antenatal screening for syphilis in the United States.

### Treatment

The effectiveness of benzathine penicillin G for the treatment of syphilis is well established. Parenteral long-acting benzathine penicillin G (IM) is the recommended antibiotic for preventing maternal transmission of syphilis to the fetus and treating fetal syphilis infection; therefore, the Centers for Disease Control and Prevention (CDC) recommends that pregnant women should be treated with the benzathine penicillin G regimen appropriate for their stage of infection.^4^ Studies suggest the efficacy of benzathine penicillin G to treat maternal infection approximates 100 percent, and about 98 percent for preventing congenital syphilis.^10^ The CDC recommends that pregnant women with a known penicillin allergy should be desensitized and treated with penicillin.^4^ If penicillin allergy testing is available, it can be performed to confirm the need for desensitization, as approximately 5 percent of pregnant women reporting a penicillin allergy are truly allergic.^11^ Antibiotics with efficacy against syphilis (that are not contraindicated in pregnancy) are not currently recommended as alternatives due primarily to the pharmacologic data indicating that these drugs do not cross the placenta to reach the fetus. In addition, there is azithromycin resistance of T. pallidum and its efficacy has not been established in pregnant women. Therefore, neither macrolide (azithromycin or erythromycin) is recommended to treat maternal infection or fetal syphilis infections.^4^ Although promising, ceftriaxone has very limited evidence of its efficacy for all stages of syphilis and in each trimester of pregnancy and therefore the CDC does not currently recommend it as an alternative.^4,12^

Penicillin is also safe, with rarely documented serious adverse outcomes (e.g., anaphylaxis).^13^ The Jarisch-Herxheimer reaction may induce early labor or cause fetal distress in pregnant women.^4^ It is an acute febrile reaction that can occur within the first 24 hours after initiation of any antimicrobial therapy for syphilis in women with high bacterial burdens, although it is more common with penicillin therapy.^12^ The reaction is not infrequent during treatment of primary/secondary infections in pregnancy, but is unusual in latent infections and is not a reason to defer treatment. A 2013 systematic review of the safety of penicillin for preventing congenital syphilis found no serious adverse reactions reported among 1,244 pregnant women (5 studies) treated in low- or middle-income countries, albeit from very low-quality evidence.^13^

## Previous USPSTF Recommendation and Current Clinical Practice in the United States

The original 1996 A recommendation to screen all pregnant women for syphilis was based on the rationale that existing screening tests are feasible for mass screening and detect syphilis with high accuracy and reliability, available treatments are effective and rarely harmful, and prenatal antibiotic therapy is effective in preventing congenital syphilis when the mother is treated early in pregnancy. In 2004 and again in 2009, the USPSTF reaffirmed this recommendation using brief evidence updates. The CDC, American Academy of Pediatrics, American College of Obstetricians and Gynecologists, and American Academy of Family Physicians also recommend screening for syphilis in pregnant women (Table 3). Their guidelines explicitly recommend screening as early as possible in pregnancy (i.e., first prenatal visit), with repeat screening in the third trimester and at delivery in women at increased risk for syphilis. In addition, of the 50 U.S. states and the District of Columbia, 45 states have laws mandating prenatal syphilis screening. Sixty-two percent of these states require only one test, and 84 percent specify that the test should be performed at the first prenatal visit.^14^

Table 3 Recommendations for Screening for Syphilis in Pregnancy

Organization Year | Recommendation | Screening Test(s) | Screening Interval
U.S. Preventive Services Task Force^22^ 2009 | Screen all pregnant women for syphilis infection (A recommendation) | [underlined: Nontreponemal tests commonly used for initial screening]: Venereal Disease Research Laboratory (VDRL) Rapid plasma reagin (RPR) [underlined: Confirmatory tests]: Fluorescent treponemal antibody absorbed (FTA-ABS) Treponema pallidum particle agglutination (TPPA) | First prenatal visit
American Academy of Family Physicians^39^ 2009 | Screen all pregnant women for syphilis infection (derived from USPSTF recommendation) | [underlined: Nontreponemal tests commonly used for initial screening]: Venereal Disease Research Laboratory (VDRL) Rapid plasma reagin (RPR) [underlined: Confirmatory tests]: Fluorescent treponemal antibody absorbed (FTA-ABS) Treponema pallidum particle agglutination (TPPA) | First prenatal visit
Centers for Disease Control and Prevention^4^ 2015 | Screen all pregnant women for syphilis infection | Serologic test RPR at the time pregnancy is confirmed if access to prenatal care is not optimal | First prenatal visit Additional screening early in third trimester (≈28 weeks’ gestation) and at delivery for women at high risk for syphilis or who live in areas of high syphilis morbidity
Institute for Clinical Systems Improvement^40^ 2012 | Screen all pregnant women for syphilis infection | Serologic test (RPR or VDRL) Treponemal tests should not be used as initial screening tests in asymptomatic patients due to increased expense and the persistent positive test in previously treated patients | First prenatal visit Preconception visit for all high-risk women
American Academy of Pediatrics and American College of Obstetricians and Gynecologists^35^ 2017 | Screen all pregnant women for syphilis infection | Nontreponemal test (VDRL/RPR) followed by treponemal test to confirm the diagnosis of syphilis in persons with a reactive VDRL/RDR result | First prenatal visit/as early as possible Additional screening early in third trimester (28 to 32 weeks’ gestation), at delivery, and after exposure to an infected partner for communities and populations with a high prevalence
National Institute for Health and Care Excellence^41^ 2008 | Screening for syphilis infection should be offered to all pregnant women | Not specified, but notes that enzyme immunoassay (EIA) tests are being used more frequently in the United Kingdom. | At an early stage in antenatal care

Despite consistent recommendations and legal mandates, screening for syphilis in pregnancy continues to be suboptimal in certain populations. While administrative data from a survey from 2009 to 2010 suggest that prenatal screening for syphilis in Medicaid and commercially insured women is nearly universal,^15^ other studies have found lower screening uptake.^16^ For example, in 2013, only 85 percent of a sample of commercially insured women had at least one syphilis test during pregnancy.^17^ In addition, recent data suggest that while screening rates for syphilis are generally high, the proportion of those screened earlier in pregnancy remains low (e.g., 80 percent screened before hospital admission for delivery) and varies geographically (e.g., 68 percent in the District of Columbia to 93 percent in Connecticut).^18^ Older studies demonstrate differential uptake of screening for syphilis by race/ethnicity;^19,20^ however, these disparities appear to be attributable to other factors (e.g., lack of insurance, inadequate access to prenatal care, geography).^21^