# Appendix C Excluded Studies

1. Study Aim: Not applicable/relevant to key question
E2. Setting:; a. Not in a high or very high human development index country; b. Screening and/or intervention not conducted in primary care, primary care-feasible, or widely available for primary care-referral
E3. Population:; a. Women who are known to have syphilis infection, have symptoms, or are not pregnant; studies in women living with HIV, for whom syphilis testing is considered disease management rather than a screening intervention; results for pregnant women not reported separately (KQ1, KQ2); b. Studies of penicillin treatment in nonpregnant women or men; studies of penicillin treatment for any condition other than syphilis (KQ3); c. Otherwise out of scope (e.g., selected population not normally seen in primary care)
E4. Outcome: Cost-effectiveness or cost-related outcomes; no relevant outcomes
E5. Intervention; a. Screening tests not currently used in U.S. primary care settings (KQ1, KQ2); b. Other types of treatment of syphilis; treatment of syphilis with penicillin outside of pregnancy (KQ3)
E6. Comparator: Alternate screening strategy or no comparator (KQ1)
E7. Study Design: Narrative reviews, editorials, case reports, systematic review checked for relevant studies; studies that use pregnant women as controls
E8. Study Quality: Poor
E9. Publication type: Abstract only, Non-English publication, main results published prior to review start date

1 Bala M, Toor A, Malhotra M, Evaluation of the usefulness of Treponema pallidum hemagglutination test in the diagnosis of syphilis in weak reactive Venereal Disease Research Laboratory sera. Indian J Sex Transm Dis. 2012;33(2):102–6. PMID: 23188934. KQ1E2a, KQ2E2a, KQ3E2a.23188934
2 Blencowe H, Cousens S, Kamb M, Lives Saved Tool supplement detection and treatment of syphilis in pregnancy to reduce syphilis related stillbirths and neonatal mortality. BMC Public Health. 2011;11 Suppl 3:S9. PMID: 21501460. KQ1E7, KQ2E1, KQ3E1.21501460
3 Bosshard PP. Usefulness of IgM-specific enzyme immunoassays for serodiagnosis of syphilis: comparative evaluation of three different assays. J Infect. 2013;67(1):35–42. PMID: 23542782. KQ1E1, KQ2E7, KQ3E1.23542782
4 Buffolano W, Agnese M, Pizzuti R. Secular trend on congenital infections: insights from Campania region register for perinatal infection, southern Italy. Journal of Maternal-Fetal & Neonatal Medicine. 2011;24 Suppl 1:94–6. PMID: 21942602. KQ1E1, KQ2E1, KQ3E1.21942602
5 Busse C, Navid MH, Strubel A, Evaluation of a new recombinant antigen-based Virotech Treponema pallidum screen ELISA for diagnosis of syphilis. Clin Lab. 2013;59(5–6):523–9. PMID: 23865350. KQ1E1, KQ3E1, KQ2E3a.23865350
6 Cerda R, Perez F, Domingues RM, Prenatal Transmission of Syphilis and Human Immunodeficiency Virus in Brazil: Achieving Regional Targets for Elimination. Open forum infect. 2015;2(2):ofv073. PMID: 26180825. KQ1E1, KQ2E1, KQ3E1.26180825
7 de Jongh T, Gurol-Urganci I, Allen E, Integration of antenatal care services with health programmes: Systematic review. International journal of gynaecology and obstetrics. 2016;131:E363–e4. PMID: None. KQ1E7, KQ2E1, KQ3E1.
8 Donkers A, Levy HR, Letens-van Vliet A. Syphilis detection using the Siemens ADVIA Centaur Syphilis treponemal assay. Clin Chim Acta. 2014;433:84–7. PMID: 24513542. KQ1E1, KQ3E1, KQ2E3a24513542
9 Enders M, Hunjet A, Gleich M, Performance evaluation of the Elecsys syphilis assay for the detection of total antibodies to Treponema pallidum. Clin Vaccine Immunol. 2015;22(1):17–26. PMID: 25355799. KQ1E1, KQ3E1, KQ2E3a.25355799
10 Gu WM, Yang Y, Wang QZ, Comparing the performance of traditional non-treponemal tests on syphilis and non-syphilis serum samples. International journal of STD & AIDS. 2013;24(12):919–25. PMID: 23970626. KQ1E1, KQ3E1, KQ2E7.23970626
11 Hawkes S, Matin N, Broutet N, Effectiveness of interventions to improve screening for syphilis in pregnancy: a systematic review and meta-analysis. Lancet Infect Dis. 2011;11(9):684–91. PMID: 21683653. KQ1E7, KQ2E1, KQ3E1.21683653
12 Hong FC, Wu XB, Yang F, Risk of congenital syphilis following treatment of maternal syphilis: results of a congenital syphilis control program in China. Clinical infectious diseases: an official publication of the Infectious Diseases Society of America. 2017. PMID: 28444157. KQ1E1, KQ2E1, KQ3E4.28444157
13 Knight CS, Crum MA, Hardy RW. Evaluation of the LIAISON chemiluminescence immunoassay for diagnosis of syphilis. Clin Vaccine Immunol. 2007;14(6):710–3. PMID: 17460119. KQ1E1, KQ2E9, KQ3E1.17460119
14 Lee JH, Lim CS, Lee MG, Evaluation of a Rapid Immunochromatographic Treponemal Antibody Test Comparing the Treponema Pallidum Particle Agglutination Assay. J Clin Lab Anal. 2015;29(5):383–6. PMID: 25385043. KQ1E1, KQ3E1, KQ2E7.25385043
15 Liu JB, Hong FC, Pan P, A risk model for congenital syphilis in infants born to mothers with syphilis treated in gestation: a prospective cohort study. Sexually transmitted infections. 2010;86(4):292–6. PMID: 20460262. KQ1E1, KQ2E1, KQ3E1.20460262
16 Marangoni A, Moroni A, Accardo S, Laboratory diagnosis of syphilis with automated immunoassays. J Clin Lab Anal. 2009;23(1):1–6. PMID: 19140205. KQ1E1, KQ2E7, KQ3E1.19140205
17 Marangoni A, Moroni A, Tridapalli E, Antenatal syphilis serology in pregnant women and follow-up of their infants in northern Italy. Clin Microbiol Infect. 2008;14(11):1065–8. PMID: 18834451. KQ1E1, KQ2E1, KQ3E1.18834451
18 Marangoni A, Nardini P, Foschi C, Evaluation of the BioPlex 2200 syphilis system as a first-line method of reverse-sequence screening for syphilis diagnosis. Clin Vaccine Immunol. 2013;20(7):1084–8. PMID: 23697575. KQ1E1, KQ3E1, KQ2E7.23697575
19 McGettrick P, Ferguson W, Jackson V, Syphilis serology in pregnancy: an eight-year study (2005-2012) in a large teaching maternity hospital in Dublin, Ireland. International journal of STD & AIDS. 2016;27(3):226–30. PMID: 25829517. KQ1E1, KQ2E1, KQ3E1.25829517
20 Munkhuu B, Liabsuetrakul T, Chongsuvivatwong V, One-stop service for antenatal syphilis screening and prevention of congenital syphilis in Ulaanbaatar, Mongolia: a cluster randomized trial. Sexually transmitted diseases. 2009;36(11):714–20. PMID: 19773681. KQ1E6, KQ2E4, KQ3E4.19773681
21 Oliveira LR, Costa Mda C, Barreto FR, Evaluation of preventative and control measures for congenital syphilis in State of Mato Grosso. Rev Soc Bras Med Trop. 2014;47(3):334–40. PMID: 25075485. KQ1E1, KQ2E1, KQ3E1.25075485
22 Op de Coul EL, Hahne S, van Weert YW, Antenatal screening for HIV, hepatitis B and syphilis in the Netherlands is effective. BMC infectious diseases. 2011;11:185. PMID: 21718466. KQ1E6, KQ2E1, KQ3E1.21718466
23 Qin JB, Feng TJ, Yang TB, Maternal and paternal factors associated with congenital syphilis in Shenzhen, China: a prospective cohort study. Eur J Clin Microbiol Infect Dis. 2014;33(2):221–32. PMID: 23948753. KQ1E1, KQ2E1, KQ3E1.23948753
24 Sia VM, Romero C, Sia DC, Epidemiology of congenital syphilis in a South Bronx population: a follow-up study. J Perinat Med. 2011;39(1):71–5. PMID: 20979448. KQ1E6, KQ2E1, KQ3E1.20979448
25 Tao C, Wang L, Hao X, Evaluation of the elecsys syphilis assay for the detection of treponema pallidum in routine samples from the Chinese population compared with local market competitors. Vox Sanguinis Conference: 34th International Congress of the International Society of Blood Transfusion United Arab Emirates Conference Start: 20160903 Conference End: 20160908. 2016;111:174. PMID: None. KQ1E1, KQ3E1, KQ2E9.
26 Zhu L, Qin M, Du L, Maternal and congenital syphilis in Shanghai, China, 2002 to 2006. Int J Infect Dis. 2010;14 Suppl 3:e45–8. PMID: 20137991. KQ1E1, KQ2E1, KQ3E1.20137991