# Appendix B Detailed Methods

## Literature Search Strategies

### Screening

Database: Ovid MEDLINE(R) Epub Ahead of Print, In-Process & Other Non-Indexed Citations, Ovid MEDLINE(R) Daily and Ovid MEDLINE(R) <1946 to Present>

Search Strategy:

------------------------------------------------------------

1. Syphilis/
2. Syphilis, Congenital/
3. syphilis.ti,ab.
4. treponema pallidum.ti,ab.
5. or/1-4
6. Mass screening/
7. screen$.ti,ab.
8. 6 or 7
9. 5 and 8
10. Syphilis Serodiagnosis/
11. ((nontreponemal or treponemal) adj (test$ or immunoassay$)).ti,ab.
12. venereal disease research laboratory.ti,ab.
13. VDRL.ti,ab.
14. Rapid plasma reagin.ti,ab.
15. Fluorescent treponemal antibody absorbed.ti,ab.
16. Treponema pallidum particle agglutination.ti,ab.
17. or/10-16
18. 9 or 17
19. Pregnancy/
20. Pregnancy Trimester, First/
21. Pregnancy Trimester, Second/
22. Pregnancy Trimester, Third/
23. Pregnant women/
24. Prenatal Care/
25. Prenatal Diagnosis/
26. Pregnancy Outcome/
27. Pregnancy Complications, Infectious/
28. Infectious Disease Transmission, Vertical/
29. (pregnan$ or prenatal or pre natal or perinatal or peri natal or antenatal or ante natal or antepartum or ante partum).ti,ab.
30. ((vertical or maternal or mother or fetomaternal) adj3 transmission).ti,ab.
31. or/19-30
32. 18 and 31
33. limit 32 to (english language and yr=“2008 -Current”)
34. remove duplicates from 33

### Treatment

Database: Ovid MEDLINE(R) Epub Ahead of Print, In-Process & Other Non-Indexed Citations, Ovid MEDLINE(R) Daily and Ovid MEDLINE(R) <1946 to Present>

Search Strategy:

------------------------------------------------------------

1. Syphilis/
2. Syphilis, Congenital/
3. syphilis.ti,ab.
4. treponema pallidum.ti,ab.
5. or/1-4
6. exp Anti-Bacterial Agents/
7. (antibiotic$ or Penicillin or Benzylpenicillin or Amoxicillin or Ampicillin or Carbenicillin or Sulbenicillin).ti,ab.
8. 6 or 7
9. Pregnancy/
10. Pregnancy Trimester, First/
11. Pregnancy Trimester, Second/
12. Pregnancy Trimester, Third/
13. Pregnant women/
14. Prenatal Care/
15. Pregnancy Outcome/
16. (pregnan$ or prenatal or pre natal or perinatal or peri natal or antenatal or ante natal or antepartum or ante partum).ti,ab.
17. Infant/
18. Infant, newborn/
19. Fetus/
20. (fetal or foetal or fetus$ or foetus$ or neonat$ or infant$ or newborn$).ti,ab.
21. exp Pregnancy Complications/
22. Infectious Disease Transmission, Vertical/
23. ((vertical or maternal or mother or fetomaternal) adj3 transmission).ti,ab.
24. Congenital Abnormalities/
25. Abnormalities, Drug-Induced/
26. fetal mortality/
27. infant mortality/
28. perinatal mortality/
29. maternal mortality/
30. or/9-29
31. 5 and 8 and 30
32. limit 31 to (english language and yr=“2008 -Current”)
33. remove duplicates from 32

### Pubmed, publisher-supplied [search run on 6.2.2017]

Search | Query
#6 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #5 AND (“2008/01/01”[Date - Publication]: “3000”[Date - Publication]) AND English[Language]
#5 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #4 AND publisher[sb]
#4 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #1 AND (#2 OR #3)
#3 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (vertical[tiab] OR maternal[tiab] OR mother[tiab] OR fetomaternal[tiab]) AND transmission[tiab]
#2 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search pregnan*[tiab] OR prenatal[tiab] OR “pre natal”[tiab] OR perinatal[tiab] OR “peri natal”[tiab] OR antenatal[tiab] OR “ante natal”[tiab] OR antepartum[tiab] OR “ante partum”[tiab] OR fetal[tiab] OR foetal[tiab] OR fetus*[tiab] OR foetus*[tiab] OR neonat*[tiab] OR infant*[tiab] OR newborn*[tiab]
#1 (https://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search syphilis[tiab] OR “treponema pallidum”[tiab]

### Cochrane Central Register of Controlled Trials: Issue 5 of 12, May 2017

#1 syphilis:ti,ab,kw
#2 “treponema pallidum”:ti,ab,kw
#3 #1 or #2
#4 (pregnan* or prenatal or pre natal or perinatal or peri natal or antenatal or ante natal or antepartum or ante partum):ti,ab,kw
#5 (fetal or foetal or fetus* or foetus* or neonat* or infant* or newborn*):ti,ab,kw
#6 ((vertical or maternal or mother or fetomaternal) near/3 transmission):ti,ab,kw
#7 #4 or #5 or #6
#8 #3 and #7 Publication Year from 2008 to 2017 in Trials

Appendix B Figure 1 Literature Flow Diagram

This figure is a flow chart that summarizes the search and selection of articles in the review. There were 477 citations identified through literature databases. An additional 9 citations were identified from outside sources such as reference lists and suggestions from peer reviewers. After duplicates were removed, 453 unique citations were screened at the title/abstract stage. The full text of 34 citations were examined for inclusion for one or more of the Key Questions. The following number of studies were included for Key Question 1 (k=1), Key Question 2 (k=6), and Key Question 3 (k=0).

Appendix B Table 1 Inclusion and Exclusion Criteria

Category | Include | Exclude
Populations | KQs 1, 2: Asymptomatic pregnant adolescents or adult women, at any time during pregnancy, who are not known to have syphilis infection KQ 3: Studies of penicillin treatment in pregnant women with syphilis infection | KQs 1, 2: Women who are known to have syphilis infection, have symptoms, or are not pregnant; studies in women living with HIV KQ 3: Studies of penicillin treatment in nonpregnant women or men; studies of penicillin treatment for any condition other than syphilis
Interventions | KQs 1, 2: Two-step screening for syphilis with a nontreponemal and treponemal test (traditional or reverse sequence algorithms) KQ 3: Treatment of syphilis with penicillin started during pregnancy | KQs 1, 2: Screening tests not currently used in U.S. primary care settings KQ 3: Other types of treatment of syphilis; treatment of syphilis with penicillin outside of pregnancy
Comparisons | KQ 1: No screening KQ 2: No comparator necessary for studies on psychosocial harms; studies on screening test in accuracy must define their criteria for false-positive and false-negative results KQ 3: No comparator necessary | KQ 1: Alternate screening strategy or no comparator
Outcomes | KQ 1: Vertical transmission of syphilis (incidence of congenital syphilis); prevalence of congenital syphilis after implementation of a screening program; stillbirth; maternal or infant morbidity and mortality KQ 2: Harms of screening (e.g., false-positive and false-negative results, stigma, psychosocial harms) KQ 3: Harms of treatment of syphilis with penicillin during pregnancy (e.g., allergic reaction, premature labor, Jarish-Herxheimer reaction, fetal harms, other maternal harms) | Cost-effectiveness or cost-related outcomes
Setting | Primary care and primary care–referable settings (e.g., obstetrics/gynecology clinics, prenatal clinics, ambulatory care, family planning clinics, correctional facilities, sexually transmitted infection clinics)
Country | Studies conducted in countries categorized as “high” or “very high” on the Human Development Index (as defined by the United Nations Development Programme)
Study design | KQ 1: Randomized, controlled trials; before-after and ecologic studies reporting effect of implementing a widespread screening program with historical or geographic comparator; systematic reviews and meta-analyses (of included study designs) KQs 2, 3: Randomized, controlled trials; cohort studies; case-control studies; diagnostic accuracy studies; large case series; systematic reviews and meta-analyses (of included study designs) | Narrative reviews, editorials, and case reports
Publication Language | English-language only | Languages other than English
Study quality | Fair- or good-quality studies | Poor-quality studies

Appendix B. Table 2 Quality Assessment Criteria

Study Design | Criteria
Randomized and nonrandomized controlled trials, adapted from the U.S. Preventive Services Task Force methods^1^ | - Was there valid random assignment? (NA for non-randomized controlled trials); - Was allocation concealed?; - Was eligibility criteria specified?; - Were groups similar at baseline?; - Were outcome assessors blinded?; - Were measurements equal, valid and reliable?; - Was there adequate adherence to the intervention?; - Were the statistical methods acceptable?; - Was the handling of missing data appropriate?; - Was there acceptable followup?; - Was there evidence of selective reporting of outcomes?; - Was there risk of contamination?
Cohort studies, adapted from the Newcastle-Ottawa Scale^2^ | - Was the exposed cohort(s) representative of the general population?; - Was the non-exposed cohort selected from the same community as exposed cohort?; - How was “exposure” ascertained?; - Was it demonstrated that the outcome of interest was not present at the start of the study?; - Were the cohorts comparable on the basis of the design or analysis?; - Were outcome assessors blind?; - Was followup long enough for outcomes to occur?; - Was there adequate of followup of cohorts?
National Heart, Lung, and Blood Institute tool for before-after (pre-post) studies with no control group^3^ | - Was the study question or objective clearly stated?; - Were eligibility/selection criteria prespecified and clearly described?; - Were the participants representative of the general population?; - Were all eligible participants enrolled?; - Was the sample size sufficiently large?; - Was the test/service/intervention clearly described and delivered consistently?; - Were the outcome measures prespecified, clearly defined, valid, reliable, and assessed consistently?; - Were outcome assessors blind?; - Was loss to followup ≤20% and those lost to follow-up accounted for in analysis?; - Did statistical methods examine changes in outcome measures from before to after the intervention? Were p values provided?; - Were outcome measures taken multiple times before and after the intervention?; - If a group-level intervention, did statistical analysis take into account the use of individual-level data to determine group-level effects?

1 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD: U.S. Preventive Services Task Force; Dec 2015.

2 Wells G, Shea B, O’Connell D, et al. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomized studies in meta-analyses. http://www.ohri.ca/programs/clinical_epidemiology/oxford.htm. Accessed 9/12/2017.

3 National Heart Lung and Blood Institute. Quality Assessment Tool for Before-After (Pre-Post) Studies with No Control Group. https://www.nhlbi.nih.gov/health-pro/guidelines/in-develop/cardiovascular-risk-reduction/tools/before-after. Accessed 9/12/2017.