# Appendix A Abbreviations

AAFP =: American Academy of Family Physicians
AAP =: American Academy of Pediatrics
ACOG =: American College of Obstetricians and Gynecologists
AHRQ =: Agency for Healthcare Research and Quality
CENTRAL =: Cochrane Central Register of Controlled Trials
CDC =: Centers for Disease Control and Prevention
CIA =: chemiluminescence immunoassay
EIA =: enzyme immunoassay
FDA =: U.S. Food and Drug Administration
FTA-ABS =: fluorescent treponemal antibody absorbed test
GRADE =: Grading of Recommendations Assessment, Development, and Evaluation
HIV =: human immunodeficiency virus
ICS =: immunochromatographic strip tests
IM =: intramuscular
KQ =: key question
MBIA =: microbead immunoassay
MTC =: mother-to-child
PAT =: particle agglutination test
PCR =: polymerase chain reaction
POCT =: point-of-care test
RPR =: rapid plasma reagin
STD =: sexually transmitted disease
STI =: sexually transmitted infection
T. pallidum =: Treponema pallidum
TPPA =: Treponema pallidum article agglutination
TRUST =: toluidine red unheated serum test
USPSTF =: U.S. Preventive Services Task Force
VDRL =: Venereal Disease Research Laboratory