# References

1 World Health Organization. Global Atlas on Cardiovascular Disease Prevention and Control. Geneva: World Health Organization; 2011.
2 World Health Organization. International Statistical Classfication of Diseases and Related Health Problems, 10th Revision (ICD-10). Geneva: WHO; 1992. PMID.
3 Benjamin EJ, Blaha MJ, Chiuve SE, . Heart Disease and Stroke Statistics-2017 Update: A Report From the American Heart Association. Circulation. 2017;135(10):e146-e603. PMID: 28122885. https://doi.org/10.1161/CIR.0000000000000485 28122885
4 Fang J, Shaw KM, Keenan NL. Prevalence of coronary heart disease--United States, 2006-2010. MMWR Morb Mortal Wkly Rep. 2011;60(40). PMID: 21993341.21993341
5 Fang J, Shaw KM, George M. Prevalence of Stroke - United States, 2006-2010. MMWR Morb Mortal Wkly Rep. 2012;61(20). PMID: 22622094.22622094
6 Mozaffarian D, Benjamin EJ, Go AS, . Heart disease and stroke statistics-2015 update: a report from the american heart association. Circulation. 2015;131(4):e29-e322. PMID: 25520374. https://doi.org/10.1161/CIR.0000000000000152 25520374
7 Goff DC, Jr., Lloyd-Jones DM, Bennett G, . 2013 ACC/AHA guideline on the assessment of cardiovascular risk: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines. J Am Coll Cardiol. 2014;63(25 Pt B):2935-59. PMID: 24239921. https://doi.org/10.1016/j.jacc.2013.11.005 24998130
8 Karmali KN, Persell SD, Lloyd-Jones DM, . Risk scoring for the primary prevention of cardiovascular disease. John Wiley & Sons, Ltd; 2015.
9 Sheridan SL, Viera AJ, Krantz MJ, . The effect of giving global coronary risk information to adults: a systematic review. Arch Intern Med. 2010;170(3):230-9. PMID: 20142567. https://doi.org/10.1001/archinternmed.2009.516 20142567
10 Mamudu HM, Paul TK, Veeranki SP, . The effects of coronary artery calcium screening on behavioral modification, risk perception, and medication adherence among asymptomatic adults: a systematic review. Atherosclerosis. 2014;236(2):338-50. PMID: 25128971. http://dx.doi.org/10.1016/j.atherosclerosis.2014.07.022 25128971
11 Rozanski A, Gransar H, Shaw LJ, . Impact of coronary artery calcium scanning on coronary risk factors and downstream testing the EISNER (Early Identification of Subclinical Atherosclerosis by Noninvasive Imaging Research) prospective randomized trial. J Am Coll Cardiol. 2011;57(15):1622-32. PMID: 21439754. https://doi.org/10.1016/j.jacc.2011.01.019 21439754
12 Schwartz J, Allison MA, Rifkin DE, . Influence of patients’ coronary artery calcium on subsequent medication use patterns. Am J Health Behav. 2012;36(5):628-38. PMID: 22584090. https://doi.org/10.5993/AJHB.36.5.5 22584090
13 Damen JA, Hooft L, Schuit E, . Prediction models for cardiovascular disease risk in the general population: systematic review. BMJ. 2016;353:i2416. PMID: 27184143. https://doi.org/10.1136/bmj.i2416 27184143
14 Mosca L, Benjamin EJ, Berra K, . Effectiveness-based guidelines for the prevention of cardiovascular disease in women--2011 update: a guideline from the american heart association. Circulation. 2011;123(11):1243-62. PMID: 21325087. https://doi.org/10.1161/CIR.0b013e31820faaf8 21325087
15 Ridker PM, Buring JE, Rifai N, . Development and validation of improved algorithms for the assessment of global cardiovascular risk in women: the Reynolds Risk Score. JAMA. 2007;297(6):611-9. PMID: 17299196. https://doi.org/10.1001/jama.297.6.611 17299196
16 Anderson KM, Odell PM, Wilson PW, . Cardiovascular disease risk profiles. Am Heart J. 1991;121(1 Pt 2):293-8. PMID: 1985385.1985385
17 Anderson KM, Wilson PW, Odell PM, . An updated coronary risk profile. A statement for health professionals. Circulation. 1991;83(1):356-62. PMID: 1984895. https://doi.org/10.1161/01.CIR.83.1.356 1984895
18 Wilson PW, D’Agostino RB, Levy D, . Prediction of coronary heart disease using risk factor categories. Circulation. 1998;97(18):1837-47. PMID: 9603539. https://doi.org/10.1161/01.CIR.97.18.1837 9603539
19 National Cholesterol Education Program. Third Report of the National Cholesterol Education Program (NCEP) Expert Panel on Detection, Evaluation, and Treatment of High Blood Cholesterol in Adults (Adult Treatment Panel III) final report. Circulation. 2002;106(25):3143-421. PMID: 1248596612485966.
20 D’Agostino RB, Sr., Vasan RS, Pencina MJ, . General cardiovascular risk profile for use in primary care: the Framingham Heart Study. Circulation. 2008;117(6):743-53. PMID: 18212285. https://doi.org/10.1161/CIRCULATIONAHA.107.699579 18212285
21 National Heart Lung and Blood Institute. 2013 Report on the Assessment of Cardiovascular Risk: Full Work Group Report Supplement. National Heart, Lung, and Blood Institute; 2013.
22 Anderson TJ, Gregoire J, Hegele RA, . 2012 update of the Canadian Cardiovascular Society guidelines for the diagnosis and treatment of dyslipidemia for the prevention of cardiovascular disease in the adult. Can J Cardiol. 2013;29(2):151-67. PMID: 23351925. https://doi.org/10.1016/j.cjca.2012.11.032 23351925
23 Dehmer SP, Maciosek MV, Flottemesch TJ. Aspirin Use to Prevent Cardiovascular Disease and Colorectal Cancer: A Decision Analysis: Technical Report. Rockville (MD), 2015.
24 Diamond GA. What price perfection? Calibration and discrimination of clinical prediction models. J Clin Epidemiol. 1992;45(1):85-9. PMID: 1738016. https://doi.org/10.1016/0895-4356(92)90192-P 1738016
25 Karmali KN, Persell SD, Perel P, . Risk scoring for the primary prevention of cardiovascular disease. Cochrane Database Syst Rev. 2017;3:CD006887. PMID: 28290160. https://doi.org/10.1002/14651858.CD006887.pub4 28290160
26 Whelton SP, Nasir K, Blaha MJ, . Coronary artery calcium and primary prevention risk assessment: what is the evidence? An updated meta-analysis on patient and physician behavior. Circ Cardiovasc Qual Outcomes. 2012;5(4):601-7. PMID: 22811506. https://doi.org/10.1161/CIRCOUTCOMES.112.965566 22811506
27 Helfand M, Buckley D, Fleming C, . Screening for Intermediate Risk Factors for Coronary Heart Disease. Rockville (MD): Agency for Healthcare Research and Quality (US); 2009.
28 Chambless LE, Folsom AR, Sharrett AR, . Coronary heart disease risk prediction in the Atherosclerosis Risk in Communities (ARIC) study. J Clin Epidemiol. 2003;56(9):880-90. PMID: 14505774. https://doi.org/10.1016/S0895-4356(03)00055-6 14505774
29 James PA, Oparil S, Carter BL, . 2014 evidence-based guideline for the management of high blood pressure in adults: report from the panel members appointed to the Eighth Joint National Committee (JNC 8). JAMA. 2014;311(5):507-20. PMID: 24352797. https://doi.org/10.1001/jama.2013.284427 24352797
30 Antithrombotic Trialists C, Baigent C, Blackwell L, . Aspirin in the primary and secondary prevention of vascular disease: collaborative meta-analysis of individual participant data from randomised trials. Lancet. 2009;373(9678):1849-60. PMID: 19482214. https://doi.org/10.1016/S0140-6736(09)60503-1 19482214
31 Seshasai SR, Wijesuriya S, Sivakumaran R, . Effect of aspirin on vascular and nonvascular outcomes: meta-analysis of randomized controlled trials. Arch Intern Med. 2012;172(3):209-16. PMID: 22231610. https://doi.org/10.1001/archinternmed.2011.628 22231610
32 Lin JS, O’Connor E, Evans CV, . Behavioral counseling to promote a healthy lifestyle in persons with cardiovascular risk factors: a systematic review for the U.S. Preventive Services Task Force. Ann Intern Med. 2014;161(8):568-78. PMID: 25155549. https://doi.org/10.7326/M14-0130 25155549
33 Stone NJ, Robinson JG, Lichtenstein AH, . 2013 ACC/AHA guideline on the treatment of blood cholesterol to reduce atherosclerotic cardiovascular risk in adults: a report of the American College of Cardiology/American Heart Association Task Force on Practice Guidelines. J Am Coll Cardiol. 2014;63(25 Pt B):2889-934. PMID: 24239923. https://doi.org/10.1016/j.jacc.2013.11.002 24998130
34 U. S. Preventive Services Task Force, Bibbins-Domingo K, Grossman DC, . Statin Use for the Primary Prevention of Cardiovascular Disease in Adults: US Preventive Services Task Force Recommendation Statement. JAMA. 2016;316(19):1997-2007. PMID: 27838723. https://doi.org/10.1001/jama.2016.15450 27838723
35 Ridker PM, Cook NR. Statins: new American guidelines for prevention of cardiovascular disease. Lancet. 2013;382(9907):1762-5. PMID: 24268611. https://doi.org/10.1016/S0140-6736(13)62388-0 24268611
36 National Institute for Health and Care Excellence. Lipid Modification: cardiovascular risk assessment and the modification of blood lipids for the primary and secondary prevention of cardiovascular disease. United Kingdom: National Institute for Health and Care Excellence; 2014.
37 Bibbins-Domingo K, U. S. Preventive Services Task Force. Aspirin Use for the Primary Prevention of Cardiovascular Disease and Colorectal Cancer: U.S. Preventive Services Task Force Recommendation Statement. Ann Intern Med. 2016;164(12):836-45. PMID: 27064677. https://doi.org/10.7326/M16-0577 27064677
38 LeFevre ML, U. S. Preventive Services Task Force. Behavioral counseling to promote a healthful diet and physical activity for cardiovascular disease prevention in adults with cardiovascular risk factors: U.S. Preventive Services Task Force Recommendation Statement. Ann Intern Med. 2014;161(8):587-93. PMID: 25155419. https://doi.org/10.7326/M14-1796 25155419
39 Siu AL, Force USPST. Screening for high blood pressure in adults: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2015;163(10):778-86. PMID: 26458123. https://doi.org/10.7326/M15-2223 26458123
40 Navar-Boggan AM, Pencina MJ, Williams K, . Proportion of US adults potentially affected by the 2014 hypertension guideline. JAMA. 2014;311(14):1424-9. PMID: 24682242. https://doi.org/10.1001/jama.2014.2531 24682242
41 National Institute for Health and Clinical Excellence. Hypertension: the clinical management of primary hypertension in adults. London, England: 2011.
42 Scottish Intercollegiate Guidelines Network. Risk estimation and the prevention of cardiovascular disease: a national clinical guideline. Edinburgh: Scottish Intercollegiate Guidelines Network; 2007.
43 Shillinglaw B, Viera AJ, Edwards T, . Use of global coronary heart disease risk assessment in practice: a cross-sectional survey of a sample of U.S. physicians. BMC Health Serv Res. 2012;12:20. PMID: 22273080. https://doi.org/10.1186/1472-6963-1220 22273080
44 Schmieder RE, Goebel M, Bramlage P. Barriers to cardiovascular risk prevention and management in Germany--an analysis of the EURIKA study. Vasc Health Risk Manag. 2012;8:177-86. PMID: 22536072. https://doi.org/10.2147/VHRM.S29915 22536072
45 U.S. Preventive Services Task Force. Using nontraditional risk factors in coronary heart disease risk assessment: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2009;151(7):474-82. PMID: 19805770. http://doi.org/10.7326/00034819-151-7-200910060-00008 19805770
46 Moyer VA, U. S. Preventive Services Task Force. Screening for peripheral artery disease and cardiovascular disease risk assessment with the ankle-brachial index in adults: U.S. Preventive Services Task Force recommendation statement. Ann Intern Med. 2013;159(5):342-8. PMID: 24026320. https://doi.org/10.7326/0003-4819-159-5201309030-00008 24026320
47 Buckley DI, Fu R, Freeman M, . C-reactive protein as a risk factor for coronary heart disease: a systematic review and meta-analyses for the U.S. Preventive Services Task Force. Ann Intern Med. 2009;151(7):483-95. PMID: 19805771. http://doi.org/10.7326/0003-4819-151-7-200910060-00009 19805771
48 Helfand M, Buckley DI, Freeman M, . Emerging risk factors for coronary heart disease: a summary of systematic reviews conducted for the U.S. Preventive Services Task Force. Ann Intern Med. 2009;151(7):496-507. PMID: 19805772. http://doi.org/10.7326/0003-4819-151-7-200910060-00010 19805772
49 Lin JS, Olson CM, Johnson ES, . The ankle-brachial index for peripheral artery disease screening and cardiovascular disease prediction among asymptomatic adults: a systematic evidence review for the U.S. Preventive Services Task Force. Ann Intern Med. 2013;159(5):333-41. PMID: 24026319. https://doi.org/10.7326/0003-4819-159-5201309030-00007 24026319
50 Ridker PM, Paynter NP, Rifai N, . C-reactive protein and parental history improve global cardiovascular risk prediction: the Reynolds Risk Score for men. Circulation. 2008;118(22):2243-51, 4p following 51. PMID: 18997194. https://doi.org/10.1161/CIRCULATIONAHA.108.814251 18997194
51 U.S. Preventive Services Task Force. U.S. Preventive Services Task Force Procedure Manual. Rockville, MD: U.S. Preventive Services Task Force; 2015.
52 Wells GA, Shea B, O’Connell D, . The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp. Accessed: April 8, 2015.
53 Moons KG, de Groot JA, Bouwmeester W, . Critical appraisal and data extraction for systematic reviews of prediction modelling studies: the CHARMS checklist. PLoS Med. 2014;11(10):e1001744. PMID: 25314315. https://doi.org/10.1371/journal.pmed.1001744 25314315
54 Tierney JF, Vale C, Riley R, . Individual Participant Data (IPD) Meta-analyses of Randomised Controlled Trials: Guidance on Their Use. PLoS Med. 2015;12(7):e1001855. PMID: 26196287. https://doi.org/10.1371/journal.pmed.1001855 26196287
55 Raggi P, Cooil B, Callister TQ. Use of electron beam tomography data to develop models for prediction of hard coronary events. Am Heart J. 2001;141(3):375-82. PMID: 11231434. https://doi.org/10.1067/mhj.2001.113220 11231434
56 Kondos GT, Hoff JA, Sevrukov A, . Electron-beam tomography coronary artery calcium and cardiac events: a 37-month follow-up of 5635 initially asymptomatic low- to intermediate-risk adults. Circulation. 2003;107(20):2571-6. PMID: 12743005. https://doi.org/10.1161/01.CIR.0000068341.61180.55 12743005
57 Steyerberg EW, Vickers AJ, Cook NR, . Assessing the performance of prediction models: a framework for traditional and novel measures. Epidemiology. 2010;21(1):128-38. PMID: 20010215. https://doi.org/10.1097/EDE.0b013e3181c30fb2 20010215
58 Cook NR. Statistical evaluation of prognostic versus diagnostic models: beyond the ROC curve. Clin Chem. 2008;54(1):17-23. PMID: 18024533. https://doi.org/10.1373/clinchem.2007.096529 18024533
59 Moons KG, Altman DG, Reitsma JB, . Transparent Reporting of a multivariable prediction model for Individual Prognosis or Diagnosis (TRIPOD): explanation and elaboration. Ann Intern Med. 2015;162(1):W1-73. PMID: 25560730. https://doi.org/10.7326/M14-0698 25560730
60 Demler OV, Paynter NP, Cook NR. Tests of calibration and goodness-of-fit in the survival setting. Stat Med. 2015;34(10):1659-80. PMID: 25684707. https://doi.org/10.1002/sim.6428 25684707
61 Steyerberg EW, Vergouwe Y. Towards better clinical prediction models: seven steps for development and an ABCD for validation. Eur Heart J. 2014;35(29):1925-31. PMID: 24898551. https://doi.org/10.1093/eurheartj/ehu207 24898551
62 Xanthakis V, Sullivan LM, Vasan RS, . Assessing the incremental predictive performance of novel biomarkers over standard predictors. Statistics in Medicine. 2014;33(15):2577-84. PMID: 24719270. http://dx.doi.org/10.1002/sim.6165 24719270
63 Collins GS, Ogundimu EO, Cook JA, . Quantifying the impact of different approaches for handling continuous predictors on the performance of a prognostic model. Stat Med. 2016;35(23):4124-35. PMID: 27193918. https://doi.org/10.1002/sim.6986 27193918
64 Collins GS, Ogundimu EO, Altman DG. Sample size considerations for the external validation of a multivariable prognostic model: a resampling study. Stat Med. 2016;35(2):214-26. PMID: 26553135. https://doi.org/10.1002/sim.6787 26553135
65 Emerging Risk Factors Collaboration, Kaptoge S, Di Angelantonio E, . C-reactive protein, fibrinogen, and cardiovascular disease prediction. N Engl J Med. 2012;367(14):1310-20. PMID: 23034020. https://doi.org/10.1056/NEJMoa1107477 23034020
66 Fowkes FG, Murray GD, Butcher I, . Development and validation of an ankle brachial index risk model for the prediction of cardiovascular events. Eur J Prev Cardiol. 2014;21(3):310-20. PMID: 24367001. https://doi.org/10.1177/2047487313516564 24367001
67 Kerr KF, Wang Z, Janes H, . Net reclassification indices for evaluating risk prediction instruments: a critical review. Epidemiology. 2014;25(1):114-21. PMID: 24240655. https://doi.org/10.1097/EDE.0000000000000018 24240655
68 Apfel CC, Kranke P, Greim CA, . What can be expected from risk scores for predicting postoperative nausea and vomiting? Br J Anaesth. 2001;86(6):822-7.11573590
69 Pencina MJ, D’Agostino RB, Sr., D’Agostino RB, Jr., . Evaluating the added predictive ability of a new marker: from area under the ROC curve to reclassification and beyond. Stat Med. 2008;27(2):157-72; discussion 207-12. PMID: 17569110. https://doi.org/10.1002/sim.2929 17569110
70 Paynter NP, Cook NR. A bias-corrected net reclassification improvement for clinical subgroups. Med Decis Making. 2013;33(2):154-62. PMID: 23042826. https://doi.org/10.1177/0272989X12461856 23042826
71 Paynter NP, Cook NR. Adding tests to risk based guidelines: evaluating improvements in prediction for an intermediate risk group. BMJ. 2016;354:i4450. PMID: 27604897. https://doi.org/10.1136/bmj.i4450 27604897
72 Berkman N, Lohr K, Ansari M, . Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)EHC063-EF. Rockville, MD: Agency for Healthcare Research and Quality; 2014. p. 314-49.
73 Atkins D, Eccles M, Flottorp S, . Systems for grading the quality of evidence and the strength of recommendations I: critical appraisal of existing approaches The GRADE Working Group. BMC Health Serv Res. 2004;4(1):38. PMID: 15615589. http://dx.doi.org/10.1186/1472-6963-4-38 15615589
74 Erbel R, Mohlenkamp S, Moebus S, . Coronary risk stratification, discrimination, and reclassification improvement based on quantification of subclinical coronary atherosclerosis: the Heinz Nixdorf Recall study. J Am Coll Cardiol. 2010;56(17):1397-406. PMID: 20946997. https://doi.org/10.1016/j.jacc.2010.06.030 20946997
75 Yeboah J, McClelland RL, Polonsky TS, . Comparison of novel risk markers for improvement in cardiovascular risk assessment in intermediate-risk individuals. JAMA. 2012;308(8):788-95. PMID: 22910756. https://doi.org/10.1001/jama.2012.9624 22910756
76 Elias-Smale SE, Proenca RV, Koller MT, . Coronary calcium score improves classification of coronary heart disease risk in the elderly: the Rotterdam study. J Am Coll Cardiol. 2010;56(17):1407-14. PMID: 20946998. https://doi.org/10.1016/j.jacc.2010.06.029 20946998
77 Polonsky TS, McClelland RL, Jorgensen NW, . Coronary artery calcium score and risk classification for coronary heart disease prediction. JAMA. 2010;303(16):1610-6. PMID: 20424251. https://doi.org/10.1001/jama.2010.461 20424251
78 Shah T, Casas JP, Cooper JA, . Critical appraisal of CRP measurement for the prediction of coronary heart disease events: new data and systematic review of 31 prospective cohorts. Int J Epidemiol. 2009;38(1):217-31. PMID: 18930961. https://doi.org/10.1093/ije/dyn217 18930961
79 Murphy TP, Dhangana R, Pencina MJ, . Ankle-brachial index and cardiovascular risk prediction: an analysis of 11,594 individuals with 10-year follow-up. Atherosclerosis. 2012;220(1):160-7. PMID: 22099055. https://doi.org/10.1016/j.atherosclerosis.2011.10.037 22099055
80 Price JF, Tzoulaki I, Lee AJ, . Ankle brachial index and intima media thickness predict cardiovascular events similarly and increased prediction when combined. J Clin Epidemiol. 2007;60(10):1067-75. PMID: 17884603. https://doi.org/10.1016/j.jclinepi.2007.01.011 17884603
81 Rodondi N, Marques-Vidal P, Butler J, . Markers of atherosclerosis and inflammation for prediction of coronary heart disease in older adults. Am J Epidemiol. 2010;171(5):540-9. PMID: 20110287. https://doi.org/10.1093/aje/kwp428 20110287
82 Kavousi M, Elias-Smale S, Rutten JH, . Evaluation of newer risk markers for coronary heart disease risk classification: a cohort study. Ann Intern Med. 2012;156(6):438-44. PMID: 22431676. https://doi.org/10.7326/0003-4819-156-6201203200-00006 22431676
83 Cook NR, Buring JE, Ridker PM. The effect of including C-reactive protein in cardiovascular risk prediction models for women. Ann Intern Med. 2006;145(1):21-9. PMID: 16818925. http://doi.org/10.7326/0003-4819-145-1-200607040-00128 16818925
84 Koenig W, Lowel H, Baumert J, . C-reactive protein modulates risk prediction based on the Framingham Score: implications for future risk assessment: results from a large cohort study in southern Germany. Circulation. 2004;109(11):1349-53. PMID: 15023871. https://doi.org/10.1161/01.CIR.0000120707.98922.E3 15023871
85 Wilson PW, Nam BH, Pencina M, . C-reactive protein and risk of cardiovascular disease in men and women from the Framingham Heart Study. Arch Intern Med. 2005;165(21):2473-8. PMID: 16314543. https://doi.org/10.1001/archinte.165.21.2473 16314543
86 Greenland P, LaBree L, Azen SP, . Coronary artery calcium score combined with Framingham score for risk prediction in asymptomatic individuals. JAMA. 2004;291(2):210-5. PMID: 14722147. https://doi.org/10.1001/jama.291.2.210 14722147
87 Danesh J, Wheeler JG, Hirschfield GM, . C-reactive protein and other circulating markers of inflammation in the prediction of coronary heart disease. N Engl J Med. 2004;350(14):1387-97. PMID: 15070788. https://doi.org/10.1056/NEJMoa032804 15070788
88 Hoffmann U, Massaro JM, D’Agostino RB, Sr., . Cardiovascular Event Prediction and Risk Reclassification by Coronary, Aortic, and Valvular Calcification in the Framingham Heart Study. J Am Heart Assoc. 2016;5(2). PMID: 26903006. http://dx.doi.org/10.1161/JAHA.115.003144 26903006
89 Bos D, Leening MJ, Kavousi M, . Comparison of Atherosclerotic Calcification in Major Vessel Beds on the Risk of All-Cause and Cause-Specific Mortality: The Rotterdam Study. Circ Cardiovasc Imaging. 2015;8(12). PMID: 26659376. http://dx.doi.org/10.1161/CIRCIMAGING.115.003843 26659376
90 Yeboah J, Young R, McClelland RL, . Utility of Nontraditional Risk Markers in Atherosclerotic Cardiovascular Disease Risk Assessment. J Am Coll Cardiol. 2016;67(2):139-47. PMID: 26791059. http://dx.doi.org/10.1016/j.jacc.2015.10.058 26791059
91 Velescu A, Clara A, Penafiel J, . Adding low ankle brachial index to classical risk factors improves the prediction of major cardiovascular events. The REGICOR study. Atherosclerosis. 2015;241(2):357-63. PMID: 26071658. http://dx.doi.org/10.1016/j.atherosclerosis.2015.05.017 26071658
92 Seven E, Husemoen LL, Sehested TS, . Adipocytokines, C-reactive protein, and cardiovascular disease: a population-based prospective study. PLoS ONE. 2015;10(6):e0128987. PMID: 26035431. http://dx.doi.org/10.1371/journal.pone.0128987 26035431
93 Chang SM, Nabi F, Xu J, . Value of CACS compared with ETT and myocardial perfusion imaging for predicting long-term cardiac outcome in asymptomatic and symptomatic patients at low risk for coronary disease: clinical implications in a multimodality imaging world. JACC Cardiovasc Imaging. 2015;8(2):134-44. PMID: 25677886. http://dx.doi.org/10.1016/j.jcmg.2014.11.008 25677886
94 Yeboah J, Erbel R, Delaney JC, . Development of a new diabetes risk prediction tool for incident coronary heart disease events: the Multi-Ethnic Study of Atherosclerosis and the Heinz Nixdorf Recall Study. Atherosclerosis. 2014;236(2):411-7. PMID: 25150939. http://dx.doi.org/10.1016/j.atherosclerosis.2014.07.035 25150939
95 Holewijn S, den Heijer M, Kiemeney LA, . Combining risk markers improves cardiovascular risk prediction in women. Clinical Science. 2014;126(2):139-46. PMID: 23879211. http://dx.doi.org/10.1042/CS20130178 23879211
96 Lyngbaek S, Marott JL, Sehestedt T, . Cardiovascular risk prediction in the general population with use of suPAR, CRP, and Framingham Risk Score. Int J Cardiol. 2013;167(6):2904-11. PMID: 22909410. http://dx.doi.org/10.1016/j.ijcard.2012.07.018 22909410
97 Zhou QM, Zheng Y, Cai T. Subgroup specific incremental value of new markers for risk prediction. Lifetime Data Anal. 2013;19(2):142-69. PMID: 23263882. http://dx.doi.org/10.1007/s10985-012-9235-3 23263882
98 Welsh P, Doolin O, Willeit P, . N-terminal pro-B-type natriuretic peptide and the prediction of primary cardiovascular events: results from 15-year follow-up of WOSCOPS. Eur Heart J. 2013;34(6):443-50. PMID: 22942340. http://dx.doi.org/10.1093/eurheartj/ehs239 22942340
99 Rana JS, Gransar H, Wong ND, . Comparative value of coronary artery calcium and multiple blood biomarkers for prognostication of cardiovascular events. Am J Cardiol. 2012;109(10):1449-53. PMID: 22425333. http://dx.doi.org/10.1016/j.amjcard.2012.01.358 22425333
100 Schneider HJ, Wallaschofski H, Volzke H, . Incremental effects of endocrine and metabolic biomarkers and abdominal obesity on cardiovascular mortality prediction. PLoS ONE. 2012;7(3):e33084. PMID: 22438892. http://dx.doi.org/10.1371/journal.pone.0033084 22438892
101 Malik S, Budoff MJ, Katz R, . Impact of subclinical atherosclerosis on cardiovascular disease events in individuals with metabolic syndrome and diabetes: the multi-ethnic study of atherosclerosis. Diabetes Care. 2011;34(10):2285-90. PMID: 21844289. http://dx.doi.org/10.2337/dc11-0816 21844289
102 Wannamethee SG, Welsh P, Lowe GD, . N-terminal pro-brain natriuretic Peptide is a more useful predictor of cardiovascular disease risk than C-reactive protein in older men with and without pre-existing cardiovascular disease. J Am Coll Cardiol. 2011;58(1):56-64. PMID: 21700090. http://dx.doi.org/10.1016/j.jacc.2011.02.041 21700090
103 Mohlenkamp S, Lehmann N, Moebus S, . Quantification of coronary atherosclerosis and inflammation to predict coronary events and all-cause mortality. J Am Coll Cardiol. 2011;57(13):1455-64. PMID: 21435514. http://dx.doi.org/10.1016/j.jacc.2010.10.043 21435514
104 Rana JS, Cote M, Despres JP, . Inflammatory biomarkers and the prediction of coronary events among people at intermediate risk: the EPIC-Norfolk prospective population study. Heart. 2009;95(20):1682-7. PMID: 19587389. http://dx.doi.org/10.1136/hrt.2009.170134 19587389
105 Hamer M, Chida Y, Stamatakis E. Utility of C-reactive protein for cardiovascular risk stratification across three age groups in subjects without existing cardiovascular diseases. Am J Cardiol. 2009;104(4):538-42. PMID: 19660608. http://dx.doi.org/10.1016/j.amjcard.2009.04.020 19660608
106 Wong ND, Gransar H, Shaw L, . Thoracic aortic calcium versus coronary artery calcium for the prediction of coronary heart disease and cardiovascular disease events. JACC Cardiovasc Imaging. 2009;2(3):319-26. PMID: 19356578. http://dx.doi.org/10.1016/j.jcmg.2008.12.010 19356578
107 Wilson PW, Pencina M, Jacques P, . C-reactive protein and reclassification of cardiovascular risk in the Framingham Heart Study. Circ Cardiovasc Qual Outcomes. 2008;1(2):92-7. PMID: 20031795. http://dx.doi.org/10.1161/CIRCOUTCOMES.108.831198 20031795
108 Sattar N, Murray HM, McConnachie A, . C-reactive protein and prediction of coronary heart disease and global vascular events in the Prospective Study of Pravastatin in the Elderly at Risk (PROSPER). Circulation. 2007;115(8):981-9. PMID: 17283264 https://doi.org/10.1161/CIRCULATIONAHA.106.643114 17283264
109 Salim A, Tai ES, Tan VY, . C-reactive protein and serum creatinine, but not haemoglobin A1c, are independent predictors of coronary heart disease risk in nondiabetic Chinese. Eur J Prev Cardiol. 2016;12:1339-49. PMID: 26780920 https://doi.org/10.1177/2047487315626547 26780920
110 Folsom AR, Chambless LE, Ballantyne CM, . An assessment of incremental coronary risk prediction using C-reactive protein and other novel risk markers: the atherosclerosis risk in communities study. Arch Intern Med. 2006;166(13):1368-73. PMID: 16832001. https://doi.org/10.1001/archinte.166.13.1368 16832001
111 Kavousi M, Desai CS, Ayers C, . Prevalence and Prognostic Implications of Coronary Artery Calcification in Low-Risk Women: A Meta-analysis. JAMA. 2016;316(20):2126-34. PMID: 27846641. https://dx.doi.org/10.1001/jama.2016.17020 27846641
112 Fudim M, Zalawadiya S, Patel DK, . Data on coronary artery calcium score performance and cardiovascular risk reclassification across gender and ethnicities. Data Brief. 2016;6:578-81. PMID: 26909370. https://dx.doi.org/10.1016/j.dib.2016.01.002 26909370
113 Polak JF, Szklo M, O’Leary DH. Carotid Intima-Media Thickness Score, Positive Coronary Artery Calcium Score, and Incident Coronary Heart Disease: The Multi-Ethnic Study of Atherosclerosis. J Am Heart Assoc. 2017;6(1):21. PMID: 28110311. https://dx.doi.org/10.1161/JAHA.116.004612 28110311
114 Geisel MH, Bauer M, Hennig F, . Comparison of coronary artery calcification, carotid intima-media thickness and ankle-brachial index for predicting 10-year incident cardiovascular events in the general population. Eur Heart J. 2017. PMID: 28379333. http://doi.org/10.1093/eurheartj/ehx120 28379333
115 Messenger B, Li D, Nasir K, . Coronary calcium scans and radiation exposure in the multi-ethnic study of atherosclerosis. Int J Cardiovasc Imaging. 2016;32(3):525-9. PMID: 26515964. http://dx.doi.org/10.1007/s10554-015-0799-3 26515964
116 Chi WC, Sylwestrzak G, Barron J, . Does CAC testing alter downstream treatment patterns for cardiovascular disease? Am J Manag Care. 2014;20(8):e330-9. PMID: 25295796.25295796
117 Shreibati JB, Baker LC, McConnell MV, . Outcomes after coronary artery calcium and other cardiovascular biomarker testing among asymptomatic medicare beneficiaries. Circ Cardiovasc Imaging. 2014;7(4):655-62. PMID: 24777939. http://dx.doi.org/10.1161/CIRCIMAGING.113.001869 24777939
118 Nielsen AD, Videbech P, Gerke O, . Population screening for coronary artery calcification does not increase mental distress and the use of psychoactive medication. J Thorac Imaging. 2012;27(3):202-6. PMID: 22336666. http://dx.doi.org/10.1097/RTI.0b013e31824752bd 22336666
119 O’Malley PG, Feuerstein IM, Taylor AJ. Impact of electron beam tomography, with or without case management, on motivation, behavioral change, and cardiovascular risk profile: a randomized controlled trial. JAMA. 2003;289(17):2215-23. PMID: 12734132. https://doi.org/10.1001/jama.289.17.2215 12734132
120 Ridker PM, Danielson E, Fonseca FA, . Rosuvastatin to prevent vascular events in men and women with elevated C-reactive protein. N Engl J Med. 2008;359(21):2195-207. PMID: 18997196. https://doi.org/10.1056/NEJMoa0807646 18997196
121 Arad Y, Spadaro LA, Roth M, . Treatment of asymptomatic adults with elevated coronary calcium scores with atorvastatin, vitamin C, and vitamin E: the St. Francis Heart Study randomized clinical trial. J Am Coll Cardiol. 2005;46(1):166-72. PMID: 15992652. https://doi.org/10.1016/j.jacc.2005.02.089 15992652
122 Fowkes FG, Price JF, Stewart MC, . Aspirin for prevention of cardiovascular events in a general population screened for a low ankle brachial index: a randomized controlled trial. JAMA. 2010;303(9):841-8. PMID: 20197530. https://doi.org/10.1001/jama.2010.221 20197530
123 Belch J, MacCuish A, Campbell I, . The prevention of progression of arterial disease and diabetes (POPADAD) trial: factorial randomised placebo controlled trial of aspirin and antioxidants in patients with diabetes and asymptomatic peripheral arterial disease. BMJ. 2008;337:a1840. PMID: 18927173. https://doi.org/10.1136/bmj.a1840 18927173
124 Mora S, Glynn RJ, Hsia J, . Statins for the primary prevention of cardiovascular events in women with elevated high-sensitivity C-reactive protein or dyslipidemia: results from the Justification for the Use of Statins in Prevention: An Intervention Trial Evaluating Rosuvastatin (JUPITER) and meta-analysis of women from primary prevention trials. Circulation. 2012;121(9):1069-77. PMID: 20176986. http://dx.doi.org/10.1161/CIRCULATIONAHA.109.906479 20176986
125 Ankle Brachial Index Collaboration, Fowkes FG, Murray GD, . Ankle brachial index combined with Framingham Risk Score to predict cardiovascular events and mortality: a meta-analysis. JAMA. 2008;300(2):197-208. PMID: 18612117. https://doi.org/10.1001/jama.300.2.197 18612117
126 Collins GS, Omar O, Shanyinde M, . A systematic review finds prediction models for chronic kidney disease were poorly reported and often developed using inappropriate methods. J Clin Epidemiol. 2013;66(3):268-77. PMID: 23116690. https://doi.org/10.1016/j.jclinepi.2012.06.020 23116690
127 Greenland S, Mansournia MA, Altman DG. Sparse data bias: a problem hiding in plain sight. BMJ. 2016;352:i1981. PMID: 27121591. https://doi.org/10.1136/bmj.i1981 27121591
128 Janes H, Pepe MS. Matching in studies of classification accuracy: implications for analysis, efficiency, and assessment of incremental value. Biometrics. 2008;64(1):1-9. PMID: 17501939. https://doi.org/10.1111/j.1541-0420.2007.00823.x 17501939
129 Efstathopoulos EP, Pantos I, Thalassinou S, . Patient radiation doses in cardiac computed tomography: comparison of published results with prospective and retrospective acquisition. Radiat Prot Dosimetry. 2012;148(1):83-91. PMID: 21324959. http://dx.doi.org/10.1093/rpd/ncq602 21324959
130 Kim KP, Einstein AJ, Berrington de Gonzalez A. Coronary artery calcification screening: estimated radiation dose and cancer risk. Arch Intern Med. 2009;169(13):1188-94. PMID: 19597067. http://dx.doi.org/10.1001/archinternmed.2009.162 19597067
131 Diederichsen AC, Rasmussen LM, Sogaard R, . The Danish Cardiovascular Screening Trial (DANCAVAS): study protocol for a randomized controlled trial. Trials. 2015;16:554. PMID: 26637993. http://dx.doi.org/10.1186/s13063-015-1082-6 26637993
132 Ijkema R, Aerde MA, Aalst CM, . A randomized controlled trial measuring the effectiveness of screening for cardiovascular disease using classic risk assessment and coronary artery calcium: The ROBINSCA study. Eur J Prev Cardiol. 2014;21(1 suppl. 1):S21. https://doi.org/10.1177/2047487314534575 22659939
133 Lindholt JS, Søgaard R. Population screening and intervention for vascular disease in Danish men (VIVA): a randomised controlled trial. Lancet. 2017. PMID: 28859943. https://doi.org/10.1016/S0140-6736(17)32250-X28859943
134 Cook NR. Use and misuse of the receiver operating characteristic curve in risk prediction. Circulation. 2007;115(7):928-35. PMID: 17309939. https://doi.org/10.1161/CIRCULATIONAHA.106.672402 17309939
135 Blaha MJ, Blumenthal RS, Budoff MJ, . Understanding the utility of zero coronary calcium as a prognostic test: a Bayesian approach. Circ Cardiovasc Qual Outcomes. 2011;4(2):253-6. PMID: 21406674. http://dx.doi.org/10.1161/CIRCOUTCOMES.110.958496 21406674
136 Nasir K, Bittencourt MS, Blaha MJ, . Implications of Coronary Artery Calcium Testing Among Statin Candidates According to American College of Cardiology/American Heart Association Cholesterol Management Guidelines: MESA (Multi-Ethnic Study of Atherosclerosis). J Am Coll Cardiol. 2015;66(15):1657-68. PMID: 26449135. http://dx.doi.org/10.1016/j.jacc.2015.07.066 26449135
137 Sorensen MH, Gerke O, Lambrechtsen J, . Changes in medical treatment six months after risk stratification with HeartScore and coronary artery calcification scanning of healthy middle-aged subjects. European Journal of Preventive Cardiology. 2012;19(6):1496-502. PMID: 22019909. http://dx.doi.org/10.1177/1741826711428063 22019909
138 Lederman J, Ballard J, Njike VY, . Information given to postmenopausal women on coronary computed tomography may influence cardiac risk reduction efforts. J Clin Epidemiol. 2007;60(4):389-96. PMID: 17346614. https://doi.org/10.1016/j.jclinepi.2006.07.010 17346614
139 DeFilippis AP, Young R, Carrubba CJ, . An Analysis of Calibration and Discrimination Among Multiple Cardiovascular Risk Scores in a Modern Multiethnic Cohort. Ann Intern Med. 2015;162(4):266-75. PMID: 25686167. https://doi.org/10.7326/M14-1281 25686167
140 Cook NR, Paynter NP, Eaton CB, . Comparison of the Framingham and Reynolds Risk scores for global cardiovascular risk prediction in the multiethnic Women’s Health Initiative. Circulation. 2012;125(14):1748-56, S1-11. PMID: 22399535. https://doi.org/10.1161/CIRCULATIONAHA.111.075929 22399535
141 Psaty BM, Delaney JA, Arnold AM, . Study of Cardiovascular Health Outcomes in the Era of Claims Data: The Cardiovascular Health Study. Circulation. 2016;133(2):156-64. PMID: 26538580. https://doi.org/10.1161/CIRCULATIONAHA.115.018610 26538580
142 Committee to Assess Health Risks from Exposure to Low Levels of Ionizing Radiation, Board on Radiation Effects Research, Division on eart and Life Studies, . Health risks from exposure to low levels of ionizing radiation: BEIR VII Phase 2. Washington DC: National Academies Press; 2006.
143 Cardis E, Vrijheid M, Blettner M, . Risk of cancer after low doses of ionising radiation: retrospective cohort study in 15 countries. BMJ. 2005;331(7508):77. PMID: 15987704. https://doi.org/10.1136/bmj.38499.599861.E0 15987704
144 Brenner DJ, Hall EJ. Computed tomography--an increasing source of radiation exposure. N Engl J Med. 2007;357(22):2277-84. PMID: 18046031. https://doi.org/10.1056/NEJMra072149 18046031
145 Jacobs PC, Mali WP, Grobbee DE, . Prevalence of incidental findings in computed tomographic screening of the chest: a systematic review. J Comput Assist Tomogr. 2008;32(2):214-21. PMID: 18379305. http://dx.doi.org/10.1097/RCT.0b013e3181585ff2 18379305
146 Ridker PM, MacFadyen J, Libby P, . Relation of baseline high-sensitivity C-reactive protein level to cardiovascular outcomes with rosuvastatin in the Justification for Use of statins in Prevention: an Intervention Trial Evaluating Rosuvastatin (JUPITER). Am J Cardiol. 2010;106(2):204-9. PMID: 20599004. http://dx.doi.org/10.1016/j.amjcard.2010.03.018 20599004
147 Ridker PM, Rifai N, Clearfield M, . Measurement of C-reactive protein for the targeting of statin therapy in the primary prevention of acute coronary events. N Engl J Med. 2001;344(26):1959-65. PMID: 11430324. https://doi.org/10.1056/NEJM200106283442601 11430324
148 Yusuf S, Bosch J, Dagenais G, . Cholesterol Lowering in Intermediate-Risk Persons without Cardiovascular Disease. N Eng J Med. 2016;374(21):2021-31. PMID: 27040132. https://doi.org/10.1056/NEJMoa1600176 27040132
149 Heart Protection Study Collaborative G, Jonathan E, Derrick B, . C-reactive protein concentration and the vascular benefits of statin therapy: an analysis of 20,536 patients in the Heart Protection Study. Lancet. 2011;377(9764):469-76. PMID: 21277016. http://dx.doi.org/10.1016/S0140-6736(10)62174-521277016
150 Hippisley-Cox J, Coupland C, Vinogradova Y, . Predicting cardiovascular risk in England and Wales: prospective derivation and validation of QRISK2. BMJ. 2008;336(7659):1475-82. PMID: 18573856. https://doi.org/10.1136/bmj.39609.449676.25 18573856
151 Woodward M, Brindle P, Tunstall-Pedoe H, . Adding social deprivation and family history to cardiovascular risk assessment: the ASSIGN score from the Scottish Heart Health Extended Cohort (SHHEC). Heart. 2007;93(2):172-6. PMID: 17090561. https://doi.org/10.1136/hrt.2006.108167 17090561
152 Conroy RM, Pyorala K, Fitzgerald AP, . Estimation of ten-year risk of fatal cardiovascular disease in Europe: the SCORE project. Eur Heart J. 2003;24(11):987-1003. PMID: 12788299.12788299
153 Perk J, De Backer G, Gohlke H, . European Guidelines on cardiovascular disease prevention in clinical practice (version 2012). The Fifth Joint Task Force of the European Society of Cardiology and Other Societies on Cardiovascular Disease Prevention in Clinical Practice (constituted by representatives of nine societies and by invited experts). Eur Heart J. 2012;33(13):1635-701. PMID: 22555213. https://doi.org/10.1093/eurheartj/ehs092 22555213
154 Assmann G, Cullen P, Schulte H. Simple scoring scheme for calculating the risk of acute coronary events based on the 10-year follow-up of the prospective cardiovascular Munster (PROCAM) study. Circulation. 2002;105(3):310-5. PMID: 11804985. https://doi.org/10.1161/hc0302.102575 11804985
155 Wolf PA, D’Agostino RB, Belanger AJ, . Probability of stroke: a risk profile from the Framingham Study. Stroke. 1991;22(3):312-8. PMID: 2003301. https://doi.org/10.1161/01.STR.22.3.312 2003301
156 Hiatt WR. Medical treatment of peripheral arterial disease and claudication. N Engl J Med. 2001;344(21):1608-21. PMID: 11372014. https://doi.org/10.1056/NEJM200105243442108 11372014
157 Food and Drug Administration. Guidance for Industry - Review Criteria for Assessment of C Reactive Protein (CRP), High Sensitivity C-Reactive Protein (hsCRP) and Cardiac C-Reactive Protein (cCRP) Assays. In: Services USDoHaH, editor. Rockville, MD: Food and Drug Administration,; 2005.
158 Pencina MJ, D’Agostino RB. Overall C as a measure of discrimination in survival analysis: model specific population value and confidence interval estimation. Stat Med. 2004;23(13):2109-23. PMID: 15211606. https://doi.org/10.1002/sim.1802 15211606
159 Pencina MJ, D’Agostino Sr RB, Vasan RS. Response to ’Net reclassification improvement and decision theory’ by Vickers et al. Stat Med. 2009;28(3):526-7. PMID: 17907248. https://doi.org/10.1002/sim.3087 17907248
160 Marrugat J, D’Agostino R, Sullivan L, . An adaptation of the Framingham coronary heart disease risk function to European Mediterranean areas. J Epidemiol Community Health. 2003;57(8):634-8. PMID: 12883073. http://doi.org/10.1136/jech.57.8.634 12883073
161 Berger JS, Lala A, Krantz MJ, . Aspirin for the prevention of cardiovascular events in patients without clinical cardiovascular disease: a meta-analysis of randomized trials. Am Heart J. 2011;162(1):115-24 e2. PMID: 21742097. https://doi.org/10.1016/j.ahj.2011.04.006 21742097
162 Marti R, Parramon D, Garcia-Ortiz L, . Improving interMediAte risk management. MARK study. BMC Cardiovasc Disord. 2011;11:61. PMID: 21992621. https://doi.org/10.1186/1471-2261-11-61 21992621