# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project: Elisabeth U. Kato, MD, MRP, formerly at AHRQ, Justin Mills, MD, MPH, at AHRQ; current and former members of the U.S. Preventive Services Task Force who contributed to topic deliberations; Matthew Budoff, MD, Nancy Cook, ScD, Abby G. Ershow, ScD, RD, Gerry Fowkes, MD, Donald Lloyd-Jones, MD, ScM, Bruce M. Psaty, MD, PhD, and Janelle M. Guirguis-Blake, MD, who provided expert review of the draft report; Robert Platt, PhD, who provided advice regarding calculation of the NRI; Todd Hannon, MLS, who conducted literature searches; and Katherine Essick, BS, who provided editorial assistance.