# 4 Discussion

## Summary of Evidence

A large body of evidence has accrued since the previous USPSTF insufficient evidence statements for nontraditional risk factors in CHD risk assessment in 2009 and for ABI in CVD risk assessment in 2013 (Tables 39 and 40). However, we still lack direct evidence from adequately powered trials evaluating the impact of CVD risk assessment with or without the addition of nontraditional risk factors on patient health outcomes. While comparative trials evaluating the incremental value of nontraditional risk factor assessment to traditional cardiovascular risk assessment on patient health outcomes may never be conducted, there are two trials currently in progress that will help us understand the role of ABI and CAC screening in people without known CVD: the Danish Cardiovascular Screening Trial (DANCAVAS) and the Risk or Benefit IN Screening for Cardiovascular disease (ROBINSCA) trial (Appendix F). DANCAVAS is a large screening RCT (n~40,000) in older adults evaluating ABI and CAC to screen for vascular disease.^131^ DANCAVAS began in 2014 and has primary outcomes including CVD morbidity and mortality at 10 years; however, interim analyses are planned for 2018. ROBINSCA is a similarly large RCT (n~40,000) in asymptomatic adults (ages 45 to 74 years old) in the Netherlands evaluating CVD risk assessment using SCORE versus CAC screening versus a control group.^132^ The primary outcome of this trial is fatal or nonfatal CHD at 5 years, with results expected in 2019. The recently published Viborg Vascular (VIVA) population-based screening trial for AAA, PAD, and hypertension does not address the additive value of ABI to traditional CVD risk assessment and does not allow for the assessment of benefit of ABI separate from the other two screening interventions.^133^ Short of having trial data on health outcomes, we should consider the incremental improvement of nontraditional risk factor assessment with the ABI, hsCRP, and CAC on the calibration, discrimination, and risk reclassification of traditional cardiovascular risk assessment.

Table 39 Summary of Evidence

KQ | Outcome | No. of studies (k), no. of participants (n)^*^ Study designs | Summary of findings by outcome | Consistency/ precision | Reporting bias | EPC SOE | Study quality | Body of evidence limitations | Applicability
KQ1: Direct evidence for screening | CVD events or mortality | k=1, n=2,137 1 RCT | No statistically significant difference in MI and/or mortality at 4 years between those who received CAC vs. those who did not receive CAC. | Not applicable Not applicable | Not applicable | Insufficient | 1 Fair | Single trial; insufficient sample size and length of followup to detect differences in patient health outcomes | U.S.-based trial, volunteer sample
KQ2: ABI Risk prediction | Calibration | k=5 n=26,286 1 IPD MA 4 cohorts | Based on one IPD MA, various measures demonstrate that the addition of ABI to FRS can improve model fit. However, it is unclear the clinical meaning of changes in these measures of calibration. | Reasonably consistent Unable to assess precision | Undetected | Low | 1 Good 4 Fair | No preferred measures of calibration | No evidence for PCE, IPD MA in Whites only
KQ2: ABI Risk prediction | Discrimination | k=10 n=79,583 1 IPD MA 8 cohorts^†^ | Based on one IPD MA, ABI can result in large improvement in discrimination when added to FRS in women, but not men, primarily due to poorer discrimination of the base model (using published coefficients) in women, but not men. The incremental benefit in IPD MA model development analyses was very small for both men and women, owing to improved base model discrimination. | Reasonably consistent Reasonably precise | Undetected | Moderate | 1 Good 9 Fair | Adequate power for sex-stratified analyses limited to IPD MA; differences in study population, base models, and outcomes predicted limit direct comparison across studies | Limited evidence for PCE, IPD MA in Whites only
KQ2: ABI Risk prediction | Risk reclassification | k=9 n=46,979 1 IPD MA 7 cohorts^†^ | Based on one IPD MA, ABI can result in improvement in reclassification when added to FRS (using published coefficients) in women, but not men; most promising for women at intermediate risk for hard CHD events. However, examination of separate components of the NRI (event and nonevent NRI) suggests that improvement in reclassification comes from w omen w ho had events being appropriately reclassified as having a higher risk; in contrast, women who did not have a cardiovascular event (w hich is the majority of the population) were inappropriately reclassified as having a higher risk (i.e., a negative nonevent NRI). Improvement in NRI was not observed in the model development IPD MA. | Reasonably consistent Reasonably precise | Undetected | Moderate | 1 Good 8 Fair | Adequate power for sex-stratified analyses limited to IPD MA; differences in study population, base models, and outcomes predicted limit direct comparison across studies. The NRI is not weighted for prevalence of events/nonevents, so the reclassification benefit may be overstated. | Limited evidence for PCE, IPD MA in Whites only, risk categories on which NRI analyses are based can vary across studies and may not apply to current practice
KQ2: hsCRP Risk prediction | Calibration | k=9 n=50,343 8cohorts^‡^ 1 nested case-control | Various measures demonstrate that the addition of hsCRP to traditional risk factors can improve model fit. However, it is unclear the clinical meaning of changes in these measures. In model development studies, calibration plots suggest that the addition of hsCRP can improve model fit in some but not all risk groups. | Reasonably consistent Unable to assess precision | Undetected | Low | 2 Good, 7 Fair | No preferred measures for most studies (and none for published coefficient models); no calibration statistics for the IPD MA. | Limited evidence for PCE. Model development IPD mA only (calibration in model development less applicable to clinical practice)
KQ2: hsCRP Risk prediction | Discrimination | k=25 n=265,704 1 IPD MA 18 cohorts^‡^ 3 nested case-control studies 1 case-cohort study | At best, improvement in discrimination from the addition of hsCRP to traditional cardiovascular risk assessment is small and more likely to occur in the context of a poorly discriminating base model. IPD MA model development study found very small improvement in discrimination from the addition of hsCRP to FRS to predict hard CHD. | Inconsistent Reasonably precise for IPD MA | Undetected | Moderate | 2 Good, 23 Fair | Limited reporting of confidence intervals and statistical significance; differences in study population, base models, and outcomes predicted limit direct comparison across studies | Limited evidence for PCE. Model development IPD mA only (changes in discrimination in model development may be less applicable to clinical practice)
KQ2: hsCRP Risk prediction | Risk reclassification | k=15 n=115,686 1 IPD MA 13 cohorts^‡^ 1 nested case-control study | NRI from the addition of hsCRP to FRS are inconsistent; 1 published coefficient PCE-based study suggested no improvement in reclassification. Best evidence from IPD MA showed statistically significant NRI of 0.0152 (95% CI, 0.0078 to 0.0227). Sex-stratified analyses suggest that reclassification occurs in men but not women. The bias-corrected NRIINT from the IPD MA was 0.027 (95% CI, 0.007 to 0.047). | Inconsistent Reasonably precise for IPD MA | Undetected | Moderate | 2 Good, 13 Fair | Comparisons across studies are limited by inconsistency in risk category definitions; sex-specific analyses reported rarely and more are needed to confirm the signal of effect modification by sex. Limited information on NRIINT, as analyses often underpowered and often cannot be bias-corrected. | Limited evidence for PCE. Risk categories on which NRI analyses are based can vary across studies and may not apply to current practice. Estimates of reclassification in model development may be less applicable to clinical practice.
KQ2: CAC Risk prediction | Calibration | k=8 n=29,775 4 cohorts^§^ | Limited model development studies using various measures demonstrate that the addition of CAC to traditional risk factors can improve model fit. However, it is unclear the clinical meaning of changes in these measures. | Inconsistent Unable to assess precision | Undetected | Insufficient | 8 Fair | No preferred measures of calibration | No evidence for published coefficient models, calibration in model development less applicable to clinical practice, limited evidence in context of PCE
KQ2: CAC Risk prediction | Discrimination | k=18 n=60,486 10 cohortsǁ | CAC in addition to traditional risk factor assessment results in at least small improvements in discrimination, from changes of 0.02 to 0.102 in studies using published coefficients to 0.02 to 0.05 in model development studies. Discrimination is not consistently greater in men or women. | Reasonably consistent Reasonably precise | Undetected | Moderate | 18 Fair | Smaller cohorts compared to ABI and hsCRP body of evidence. No IPD MA limits understanding in differences by sex. Dfferences in study population, base models, and outcomes predicted limit direct comparison across studies | Limited evidence in context of PCE Non-population based cohorts may not be broadly applicable.
KQ2: CAC Risk prediction | Risk reclassification | k=15 n=58,289 9 cohorts^¶^ | CAC resulted in NRIs of 0.084 to 0.35 when added to traditional risk factor assessment. Evaluation of separate components of the NRI shows that improvements in NRI are consistently driven by event NRIs much larger than nonevent NRIs, which were commonly negative (when reported), and sometimes statistically significant. Reclassification is not consistently greater in men or women. | Reasonably consistent Reasonably precise | Undetected | Moderate | 15 Fair | Smaller cohorts compared to ABI and hsCRP body of evidence. No IPD MA limits understanding in differences by sex. Limited information on NRI_INT,_ as analyses often underpowered and often cannot be bias-corrected. Differences in study population, base models, and outcomes predicted limit direct comparison across studies. The NRI is not weighted for prevalence of events/nonevents, so the reclassification benefit may be overstated. | Non-population based cohorts may not be broadly applicable. Risk categories on which NRI analyses are based can vary across studies and may not apply to current practice.
KQ3: Harms of screening | Radiation dose | k=4 n=11,473 3 cohorts 1 RCT | Effective dose of radiation per CT exam for screening CAC was low, ≤2.1 mSv. | Reasonably consistent Reasonably precise | Suspected | Moderate # | 4 Fair | Only a limited subset of CAC studies included for KQ2 reported radiation dose. Dose not reported separately by EBCT vs MDCT | CT protocols evolve over time, most often reducing radiation exposure.
KQ3: Harms of screening | Psychological outcomes | k=2 n=1,619 1 cohort 1 RCT | Screening CAC is not associated with subsequent depression, anxiety, or decline in overall mental health functioning up to 1 year. | Reasonably consistent Reasonably precise | Undetected | Moderate | 2 Fair | No studies for ABI or hsCRP. Only one study with a comparator arm. | Baseline depression and anxiety scores were low in these studies. One study in a Danish cohort, the other in active military duty.
KQ3: Harms of screening | CVD events | k=2 n=11,364 2 cohorts | No paradoxical increase in CVD events (MI, CVA, unstable angina) or all-cause mortality with screening CAC at approximately 1.5 to 3 years of followup. | Reasonably consistent Reasonably precise | Undetected | Moderate | 2 Fair | No studies for ABI or hsCRP. Retrospective analyses of administrative data. Limited length of followup. | Large nationally representative samples.
KQ3: Harms of screening | Health care utilization | k=3 n=13,204 2 cohorts 1 RCT | Best-quality evidence from 1 RCT found no statistically significant increase in cardiac imaging or revascularization for screening CAC at 4 years of followup. Two retrospective cohort studies using differently assembled control groups had mixed findings. One study using Medicare claims data found a higher number of cardiac imaging and revascularization procedures associated with CAC as opposed to CRP or lipid screening. | Inconsistent Imprecise | Undetected | Low | 3 Fair | No studies for ABI or hsCRP. No studies of dow nstream utilization due to incidental findings on CT for CAC. 2 retrospective analyses of administrative data. | RCT may be less applicable to clinical practice.
KQ4: ABI-guided treatment benefit | CVD events | k=2 n=4,626 RCT | AAA and POPADAD found no benefit for ABI-guided low-dose aspirin (100 mg daily) in asymptomatic persons on composite CVD outcomes (MI, CVA, revascularization or amputation) at approximately 7 to 8 years of followup. | Reasonably consistent Reasonably precise | Undetected | Moderate | 2 Good | No ABI-guided statin trials | Nontraditional threshold for ABI used in both trials.
KQ4: hsCRP-guided treatment benefit | CVD events | k=1 n=17,802 RCT | JUPITER found a benefit for hsCRP-guided high-intensity statin (rosuvastatin 20mg daily) in asymptomatic persons on CVD outcomes. At 1.9 years followup, 1.6% had a CVD event (MI, CVA, hospitalization for unstable angina, revascularization, or CVD mortality) in the statin group compared to 2.8% in the placebo group, HR 0.56 (95% CI, 0.46 to 0.69). | Not applicable Reasonably precise | Undetected | Moderate | 1 Good | No hsCRP-guided aspirin treatment trials. Trial stopped early which may overestimate findings of benefit. | Threshold for hsCRP was 2.0 mg/L. Diverse population.
KQ4: CAC-guided treatment benefit | CVD events | k=1 n=1,005 RCT | St. Francis Heart Study found no benefit for CAC-guided moderate-intensity statin (atorvastatin 20mg daily) in asymptomatic persons on composite CVD outcomes at approximately 4 years of followup. | Not applicable Imprecise | Undetected | Low | 1 Fair | No CAC-guided aspirin treatment trials. Trial not powered to detect a difference in outcomes. | All participants were taking aspirin. Threshold for CAC was based on age/sex. Mean hsCRP was lower in this trial compared to JUPITER.
KQ5: ABI-guided aspirin treatment harms | Major bleeding | k=2 n=4,626 RCT | AAA and POPADAD found no statistically significant difference in bleeding events between low-dose aspirin (100mg daily) and placebo. However, AAA found a trend for increased bleeding events in the aspirin group (2.0%) versus placebo (1.2%), HR 1.71 (95% CI 0.99, 2.97) at 8.2 years of followup. | Reasonably consistent Imprecise | Undetected | Low | 2 Good | Limited followup. Likely not powered to detect a difference in bleeding events. POPADAD only reported on hemorrhagic CVA, and the event rate was very low. | These two trials should be interpreted in the context of the larger body of evidence on major bleeding from low-dose aspirin.
KQ5: hsCRP-guided statin treatment harms | Serious adverse events | k=1 n=17,802 1 RCT | JUPITER found a statistically significant increase in incident diabetes but not in other serious adverse events. There were 3.0% cases of diabetes in the rosuvastatin group compared to 2.4% cases in the placebo group, RR 1.25 (95% CI 1.04, 1.50) at 1.9 years of followup. | Reasonably consistent Reasonably precise | Undetected | Moderate | 1 Good | Limited followup. | This trial should be interpreted in the context of the larger body of evidence on adverse events from high-intensity statins.

* Ns approximated by using the largest N analyzed in each cohort

† Two studies using the MESA cohort^75,90^

‡ One study reported 2 cohorts separately^78^

§ Three studies using the Rotterdam cohort^76,82,^ ^89^; 2 studies using MESA^77,^ ^112^; 2 studies using Heinz Nixdorf Recall cohort^74,^ ^103^

ǁ Four studies using the Rotterdam cohort^76,^ ^82,^ ^89,^ ^111^; 7 studies using MESA^75,^ ^77^ ^607,^ ^90,^ ^94,^ ^101,^ ^111,^ ^112^; 5 studies using the Heinz Nixdorf Recall cohort^74,^ ^94^ ^103,^ ^111,^ ^114^

¶ Four studies using the Rotterdam cohort^76,^ ^82,^ ^89,^ ^111^; 6 studies using MESA^75,^ ^77,^ ^90,^ ^111-113^; 4 studies using the Heinz Nixdorf Recall cohort^74,^ ^103,^ ^111,^ ^114^

# Footnote, likely high in the context of external literature summarized in the discussion

Abbreviations: AAA = the Aspirin for Asymptomatic Atherosclerosis trial; ABI = ankle-brachial index; CAC = coronary artery calcium; CHD = coronary heart disease; CI = confidence interval; CT = computed tomography; CVA = cerebrovascular accident; CVD = cardiovascular disease; EBCT = electron-beam computed tomography; EPC SOE = Evidence-based Practice Center assessment of strength of evidence; ERFC = Emerging Risk Factors Collaboration; FRS = Framingham Risk Score; F/U = follow up; HR = hazard ratio; hsCRP = high sensitivity C-reactive protein; IPD MA = individual participant data meta-analyses; JUPITER = Justification for the Use of Statins in Prevention: an Intervention T rial Evaluating Rosuvastatin; KQ = key question; L = liter; MDCT = multidetector computed tomography; MESA = Multi-Ethnic Study of Atherosclerosis; mg = milligram; MI = myocardial infarction; mSv = millisievert; no = number; NR = not reported; NRI = net reclassification improvement; PCE = Pooled Cohort Equations; POPADAD = the Prevention of Progression of Arterial Disease and Diabetes trial; RCT = randomized controlled trial; RR = relative risk

Table 40 Snapshot to Assess Net Benefit

| | ABI | hsCRP | CAC | Considerations
Benefits | KQ1: Direct evidence for nontraditional risk factor assessment | No evidence | No evidence | k=1; n=2,137 No statistically significant difference in MI and/or mortality at 4 years | Ongoing screening trials in progress; may not directly address incremental benefit over traditional risk factor assessment
Benefits | KQ2: Calibration | k=5; n=26,286 Improved calibration | k=9; n=50,343 Improved calibration | k=8; n=29,775 Improved calibration | Preferred measures rarely reported; clinical meaning of changes in calibration unclear
Benefits | KQ2: Discrimination^*^ | k=10; n=79,583 Generally no to small improvement, but large improvement in women in IPD MA | k=25; n=265,704 Inconsistent, at most very small to small improvement | k=18; n=60,486 At least small, sometimes large improvement | Improvement likely influenced by discrimination of base model
Benefits | KQ2: Reclassification | k=9; n=46,979 NRIs are at best <0.1 and are usually much smaller and often nonsignificant; women without events inappropriately reclassified | k=15; n=115,686 Inconsistent improvement when added to FRS and best evidence shows NRI <0.02; no improvement when added to PCE | k=15; n=58,289 NRIs of 0.084 to 0.35; people without events inappropriately reclassified | NRI may overstate benefit; applicability of risk thresholds
Benefits | KQ4: Treatment guided by NTRF in addition to FRS/PCE | No evidence | No evidence | No evidence | Unlikely such a trial will occur due to required sample
Benefits | KQ4: Treatment guided by NTRF vs usual care | Aspirin: k=2; n=4,626 No benefit in CVD outcomes at 7-8 years | Statin: k=1; n=17,802 Benefit for high-intensity statin at 1.9 years of followup | Statin: k=1; n=1,005 No benefit for moderate-intensity statin at 4 years of followup | Results and conclusions not comparable across nontraditional risk factors
Harms | KQ3: Screening | No evidence | No evidence | Radiation: k=4; n=11,473 Low effective dose, ≤2.1 mSv Psychological outcomes: k=2; n=1,619 No association with depression, anxiety, or decline in mental health at 6 to 12 mo CVD outcomes: k=2; n=11,364 No paradoxical increase in CVD events approximately up to 2 to 3 y Health care utilization: k=3; n=13,204 Mixed results for downstream cardiac testing/procedures | Incidental findings not uncommon; unclear whether identification of incidental findings and/or increased health care utilization is a net benefit or net harm
Harms | KQ5: Treatment guided by NTRF | Aspirin: k=2; n=4,626 Mixed results for increase in bleeding events | Statin: k=1; n=17,802 Increase in incident diabetes but not in other serious adverse events | No evidence | Larger body of evidence not included in this review informs harms of aspirin and statins; inappropriate reclassification addressed in KQ2.

* For changes in the c-statistic, the term “large” is used to denote changes of 0.1 or greater, “moderate” for changes of 0.05 -0.1, “small” for 0.025 -0.05, and “very small” for changes less than 0.025.

Abbreviations: ABI = ankle-brachial index; CAC = coronary artery calcium; CHD = coronary heart disease; CVD = cardiovascular disease; FRS = Framingham Risk Score; hsCRP = high sensitivity C-reactive protein; KQ = key question; mo = month; NRI = net reclassification improvement; NTRF = non-traditional risk factor; PCE = Pooled Cohort Equations

### Predictive Performance of ABI, hsCRP and CAC

Unfortunately, risk prediction studies to date offer limited information about how ABI, hsCRP, or CAC can improve the calibration—agreement between predicted and observed events—of PCE or FRS risk assessment, due to sparse and inconsistent reporting of various measures (Table 39). The sparse reporting of calibration measures is not surprising and is consistent with the findings of other systematic reviews,^13^ as historically, the performance of risk prediction models has focused on discrimination.^134^ While limited reporting of measures of calibration suggests that all three nontraditional risk factors can improve model fit, the lack of reporting on calibration plots and O:E ratios, as well as the overall inconsistent reporting of calibration measures, severely limits our ability to understand the clinical meaning of these improvements in calibration. Given that current risk assessment tools can both under- and overestimate CVD risk, it is crucial to understand the impact of these risk factors on calibration as much as their impact on discrimination and risk reclassification. In addition, because the c-statistic or AUC is a rank order statistic, a model can discriminate well but still systematically under- or overestimate risk.^57^ Overall performance measures such as likelihood statistics, AIC, BIC, and R^2^ were reported more commonly than measures directly assessing calibration; however, since these measures capture both discrimination and calibration, improvements in these measures could indicate improvements to one or both aspects of model performance. Because we found that nontraditional risk factors can improve discrimination, the interpretation of improvements in overall performance measures on calibration is unclear.

Fortunately, we have more complete data to inform the impact of nontraditional risk factors on discrimination and risk reclassification when added to traditional risk factor assessment. Very few risk prediction studies in this review evaluated base models using published coefficients of existing models, therefore do not answer the pragmatic question for clinicians on whether to add ABI, hsCRP or CAC to their existing cardiovascular risk assessment using publicly available tools like the PCE or ATP III’s risk calculator. Overall, we found only four studies that evaluated the PCE as a base model; therefore, we cannot make any definitive conclusions about the value of ABI, hsCRP, or CAC to the PCE, and in particular about the ability of these nontraditional risk factors to improve the performance of the PCE. Almost the entirety of the evidence is focused on an FRS base model. The IPD meta-analysis by the ABI Collaboration demonstrated the improvement in both discrimination and risk reclassification after adding ABI to the FRS using published coefficients. This improvement was most promising for women and women at intermediate-risk; however, this is likely due to the poor base model performance. When investigators developed new models for women, which corrected the poor calibration and discrimination of the base model, improvements in discrimination and reclassification for ABI were no longer statistically significant. Findings from other studies were generally concordant with findings from the IPD meta-analysis. Findings for hsCRP were less consistent compared to ABI or CAC. Limited studies with methodological limitations suggest that at best, the addition of hsCRP to the FRS results in small improvements in discrimination and reclassification. The IPD meta-analysis by the Emerging Risk Factors Collaboration demonstrated statistically significant improvements in the c-statistic of only 0.0039 and NRI of only 0.0152 when hsCRP was added to the FRS, but this was a model development study. These improvements appear to accrue more for men than women. Sex differences observed in the ABI evidence base can be explained by performance of base models rather than biologic plausibility that the ABI performs differently in men and women; this is likely the case for sex differences in hsCRP as well, although more limited reporting about sex-specific base model performance prevents definitive conclusions. CAC appears to be the most promising nontraditional risk factor; however, this interpretation is based on a much smaller body of evidence compared to ABI or hsCRP. CAC, when added to the FRS, consistently resulted in improvements in discrimination and reclassification in studies using published coefficients and model development studies.

When we could evaluate event and nonevent NRI separately, the improvement in NRI for ABI and CAC appeared to be driven by the event (as opposed to nonevent) NRI, meaning the upward classification of individuals who had a cardiovascular event. Because the prevalence of nonevents is substantially greater than that of events, the total NRI may overstate the magnitude of improvement as the event and nonevent NRI are weighted equally. In addition, a negative nonevent NRI (i.e., erroneous classification of individuals without events into a higher-risk category) may lead to harms due to overtreatment or overutilization.^67^ For both ABI and CAC there was evidence of negative nonevent NRIs. In the ABI Collaboration IPD meta-analysis, the nonevent NRI was negative and statistically significant for women (for whom benefits were most promising), and similarly across the CAC evidence base, the nonevent NRI was negative (and sometimes statistically significant).

Experts have advocated for the separate consideration of NRI in the intermediate-risk group, as these are the individuals for whom the initiation of preventive therapies may be less certain. In instances where the bias-corrected NRI_INT_ was reported or could be calculated, it was not consistently greater than the NRI observed for all individuals (all risk strata). The most commonly used risk strata for the FRS base model was low (<10%), intermediate (10-19 or 20%), and high (>20%). These risk strata may no longer be as relevant for clinical decisionmaking because current practice has lowered the threshold to initiate preventive therapies, for example, with statins (USPSTF at 10% or greater, ACC/AHA at 7.5% or greater).

### Clinical Importance of Improvements in Discrimination and Risk Reclassification

Measures of discrimination (AUC, c-statistic) and reclassification (NRI) are important to evaluate in the context of one another, in addition to measures of calibration. For cardiovascular risk prediction, small changes in risk that do not change clinical decisionmaking can result in changes in discrimination. Conversely, the c-statistic or AUC can be insensitive and new markers can improve reclassification with little change in discrimination.^134^ Reclassification captures changes in risk categories or decision thresholds; however, the NRI only measures the difference between the base and extended models, without providing actual information about the performance of the models. Both the c-statistic/AUC and NRI lack consensus on how to interpret clinical meaningfulness. While the NRI may be more clinically helpful because it captures changes in risk categories, it is a combination of four proportions. Event NRI and nonevent NRI may be easier to interpret, as they are each a difference in proportion. For example, the event NRI is the net proportion of events assigned to a higher risk; that is, those with an event correctly reclassified into a higher-risk category minus those with an event who were incorrectly reclassified into a lower group. For cardiovascular risk assessment using three categories (low, intermediate, and high risk), the NRI equally weights reclassification; for example, all upward movement in the low to intermediate risk is valued the same as low to high risk, and likewise, intermediate to high risk.^67^ This is further complicated by the point made earlier: that the risk strata used to calculate the categorical NRI may no longer be relevant to clinical practice. For example, much of the reclassification evidence base uses three categories, whereas clinical decisions are based on a single threshold (of 7.5% or 10% 10-year risk), so the overall NRI will take into account movement between groups that is irrelevant for clinical decisionmaking (e.g., movement between 10-20% and >20% 10-year risk).

The bottom line is there is no consensus on a threshold for clinically meaningful changes in the c-statistic/AUC or NRI. However, we can state that there is moderate strength of evidence that the magnitude of improvement in discrimination and reclassification can be clinically important for ABI for populations in whom the FRS has poor discrimination, and for CAC, but not for hsCRP. These findings of potential benefit should be tempered by the observed misclassification of individuals (negative nonevent NRI) observed in both these instances and other potential harms, specifically for CAC (discussed below). Experts in CAC have argued that a CAC score of 0 may be helpful in reducing unnecessary care (subtractive medicine), as a CAC score of 0 portends a good prognosis in asymptomatic persons, and many asymptomatic persons have a CAC score of 0 (e.g., in the EISNER RCT 48% had a CAC score of 0).^135^ An analysis of the MESA cohort by Nasir and colleagues showed that the distribution of CAC is heterogeneous across groups recommended, not recommended, or considered for statins as defined by the 2013 ACC/AHA cholesterol guidelines.^136^ These recommendation groups are defined by a combination of risk equivalents (LDL of 190 mg/dL or greater or diabetes) or calculated 10-year PCE risk. In this analysis, 41 percent of those who would be recommended a statin based on LDL of 190 mg/dL or greater, diabetes, or 7.5 percent or greater 10-year risk have a CAC score of 0 and a 10-year risk of approximately 5%. While this analysis shows that a CAC score of 0 can appropriately downward reclassify a large proportion of individuals previously recommended a statin, the downward classification may be of nominal clinical importance because observed risk of 5% is still in the statin considered range. These results are not comparable to the analysis by Yeboah and colleagues^90^ used in our evidence review because of the different definition of risk categories (i.e., the use of risk equivalents in one but not both analyses) and the use of a different reclassification strategy (PCE in addition to CAC versus a CAC score of 0). The MESA analysis by Yeboah and colleagues^90^ shows that almost half of individuals with diabetes have calculated 10-year risk of less than 7.5 percent, whereas these individuals are automatically placed in the statin recommended group by ACC/AHA guidelines ^33^ and in the analysis by Nasir and colleagues.^136^ Although this analysis underscores the potential of CAC to reclassify individuals across the risk spectrum, the body of evidence reviewed for this report suggests that on a population level, the majority of reclassification is for individuals moved to a higher category of risk (i.e., more persons are inappropriately being reclassified to a higher risk than appropriately being reclassified to a lower risk category).

The use of nontraditional risk factor measurement is primarily important for aiding in the decisions to initiate preventive cardiovascular therapies (i.e., aspirin and statin) by improving on existing cardiovascular risk assessment, for example, in persons for whom traditional risk prediction does not perform adequately. Currently, the USPSTF has recommendations to initiate preventive low-dose aspirin and statins based on a 10-year CVD risk of 10 percent or greater, while the ACC/AHA advocates for initiating a discussion for statin initiation at a threshold of 7.5 percent using their PCE. We illustrate the impact of reclassification using current day thresholds based on reclassification tables from three selected included studies (Table 41). In this example, we show the absolute number of people and people-per-100 who are appropriately and inappropriately reclassified with ABI, hsCRP, or CAC using data from the MESA cohort^90^ and the two IPD meta-analyses included in our review.^65,^ ^66^ These examples were selected because the studies reported reclassification tables and they represented the most applicable studies to current day practice in the United States. The MESA analysis used a published coefficient model and evaluated both the FRS and PCE, and the IPD meta-analyses represent the largest assembled populations for their respective analyses. For the FRS-based analyses, which used 3 risk strata, the top 2 risk strata (10-20% and >20%) were combined to conform to the current USPSTF recommendation to initiate preventive low-dose aspirin and statins based on a 10-year CVD risk of ≥10 percent. Among individuals having an event, appropriate reclassification is defined as reclassification above a treatment threshold (7.5 or 10%), and inappropriate reclassification is defined as reclassification below a treatment threshold. The converse definitions are used for individuals not having an event. In our example for the PCE, CAC has the greatest reclassification but does inappropriately reclassify individuals who did not have an event to above the 7.5 percent treatment threshold. In the example for the PCE, 76 people having CVD events were appropriately reclassified upward when CAC was added to risk assessment, and 19 people who had events were inappropriately reclassified downward who had a CVD event—a net improvement of 57 individuals among the 320 having events—about 18 per 100 people (reported event NRI of 0.178 [95% CI, 0.080-0.256]). However, in the primary prevention populations to which CVD risk assessment with the PCE or FRS applies, the majority of people will not experience a CVD event. With the addition of CAC to risk assessment, 202 people not having events are appropriately reclassified downward, but 496 people are inappropriately reclassified upward—on net, a worsening of reclassification of 294 individuals out of 4865 not having events—or about 6 per 100 people (reported nonevent NRI of -0.059 [95% CI, -0.0750.030]). Therefore, the NRI of 0.119 [95% CI, 0.080-0.256) does not convey that for CAC, a sizeable proportion of individuals who are not having events will now be considered for treatment. The addition of the ABI to the FRS in women showed a similar pattern.

Table 41 Selected Examples of Appropriate and Inappropriate Reclassification Using Current Treatment Thresholds (≥7.5% for the PCE and ≥10% for the FRS)

| | | People having CVD or CHD event | | | | People not having CVD or CHD event
| | | Absolute num ber of people reclassified | | Per 100^*^ people reclassified | | Absolute num ber of people reclassified | | Per 100^*^ people reclassified
Base model and predicted outcome | Threshold for treatment | NTRF | Appropriate ↑ Reclass. | Inappropriate ↓ Reclass. | Appropriate ↑ Reclass. | Inappropriate ↓ Reclass. | Appropriate ↓ Reclass. | Inappropriate ↑ Reclass. | Appropriate ↓ Reclass. | Inappropriate ↑ Reclass.
PCE^†^ (Hard CVD) | ≥7.5% | ABI | 17 | 13 | 5 | 4 | 113 | 92 | 2 | 2
PCE^†^ (Hard CVD) | ≥7.5% | hsCRP | 18 | 9 | 6 | 3 | 98 | 120 | 2 | 2
PCE^†^ (Hard CVD) | ≥7.5% | CAC | 76 | 19 | 24 | 6 | 202 | 496 | 4 | 10
FRS^†^ (Hard CHD) | ≥10% | ABI | 7 | 4 | 4 | 2 | 50 | 57 | 1 | 1
FRS^†^ (Hard CHD) | ≥10% | ABI (Men)^‡^ | 14 | 17 | 3 | 4 | 260 | 174 | 6 | 4
FRS^†^ (Hard CHD) | ≥10% | ABI (Women)^‡^ | 46 | 5 | 15 | 2 | 136 | 426 | 2 | 7
FRS^†^ (Hard CHD) | ≥10% | hsCRP | 1 | 1 | 1 | 1 | 16 | 28 | 0 | 1
FRS^†^ (Hard CHD) | ≥10% | hsCRP^§^ | 162 | 131 | 2 | 2 | 993 | 922 | 2 | 1
FRS^†^ (Hard CHD) | ≥10% | CAC | 26 | 5 | 13 | 3 | 71 | 233 | 1 | 5

* Rounded to whole numbers

† MESA cohort from Yeboah, 2016^90^ (N in reclassification analyses: 5,185)

‡ IPD MA study for ABI reported in ABI Collaboration, 2014^66^ (N in reclassification analyses, Women: 6,459; Men: 4,962)

§ IPD MA study for CRP reported in Emerging Risk Factors Collaboration, 2012^65^ (N in reclassification analyses: 72,574)

Abbreviations: ABI = ankle-brachial index; CAC = coronary artery calcium; CHD = coronary heart disease; CVD = cardiovascular disease; FRS = Framingham Risk Score; hsCRP = high-sensitivity c-reactive protein; IPD MA = individual participant data meta-analyses; NTRF = non-traditional risk factor; PCE = Pooled Cohort Equations; Reclass = reclassification

Some experts and advocates have argued that nontraditional risk factor assessment may also be helpful for individuals who choose not to initiate preventive therapy (e.g., aspirin or statin), although this has not been proven. One comprehensive systematic review addressed the effect of CAC screening on risk perception, adherence to medication, and behavioral therapies.^10^ This review included 15 studies of varying study designs. While the findings were somewhat mixed across different studies and outcomes, in general this review found that CAC screening can increase adherence to lifestyle changes, increase use of preventive medications, influence physician-prescribing practices, and improve risk factor control from 6 months up to 6 years compared to no CAC screening. Only two of these studies evaluated traditional cardiovascular risk assessment versus CAC.^137,^ ^138^ Neither of these studies found that screening CAC was superior to traditional cardiovascular risk assessment on use of preventive medications or risk factor control (cholesterol).

### Reynolds Risk Score

The Reynolds Risk Score (RRS), which includes hsCRP, family history, and HbA1c for individuals with diabetes (in the model for women but not men),^15,^ ^50^ was not evaluated in this review because the addition of multiple nontraditional risk factors precludes examination of the additional value of hsCRP alone. External validation studies of the RRS have shown moderate discrimination in the range of 0.72 to 0.756; these values are similar to those of hsCRP-extended models in our review such as the IPD MA, which reports an extended model discrimination of 0.7179.^65,^ ^139,^ ^140^ These external validation studies are mixed with respect to findings for calibration. The external validation study in the MESA cohort showed an overprediction of 9 percent in men and an underprediction of 21 percent in women;^139^ calibration plots from an external validation study in the Women’s Health Initiative, however, showed O:E ratios very close to 1 for most of the spectrum of risk, and overprediction of only about 4 percent in persons with 15 percent 10-year risk (which is not clinically important as these persons are already above treatment thresholds of 7.5 or 10%).^140^ Differences in findings for calibration could be due to differences in risk and case mix between validation and development cohorts and/or differences in ascertainment of CVD events across the different cohorts.^141^ In our analyses evaluating the incremental value of hsCRP to improve risk prediction, calibration outcomes were reported in only about one-third of included studies (9 of 25 articles), and preferred measures of calibration such as graphical measures and O:E were rarely reported. From these limited data, we conclude that hsCRP could improve the calibration of risk prediction models, at least for individuals in some risk groups. Therefore, the evidence for calibration of the RRS shown in these external validation studies is consistent with our review’s finding.

### Harms of Nontraditional Risk Factors

While CAC is the most promising nontraditional risk factor to improve discrimination and reclassification, it does have potential harms. We have previously discussed the issue with erroneous upward reclassification for individuals without a cardiovascular event, which is not specific to CAC. In addition, CT imaging for CAC is associated with exposure to low-dose radiation and a potential for increased burden of testing/procedures. Our review found that the estimate of radiation exposure or effective radiation dose is low—0.4 to 2.1 mSv per exam. Given that the average amount of radiation exposure from background sources in the United States is about 3.0 mSv per year,^142^ ionizing radiation from a single examination for CAC is low. Even low doses of ionizing radiation, however, may convey a small excess risk of cancer.^143,^ ^144^

Literature reviews of radiation exposure or effective radiation dose from CT imaging for CAC confirm that the exposure to radiation is low, but observe a wider range of doses. One review found the effective dose in 20 studies ranged from 0.5 to 7.7 mSv (excluding CAC from CT angiography).^129^ This review found that prospective ECG-triggering had lower radiation exposure than retrospective ECG gating. Another recent review of 20 MDCT imaging protocols for CAC found a median exposure of 2.3 mSv per exam and a range of 0.8 to 10.5 mSv per exam.^130^ This review also modeled cancer risk using the risk models from the National Research Council’s Biological Effects of Ionizing Radiation (BIER) VII committee. Based on a one-time screen at age 40 years, using a median dose of 2.3 mSv, the estimated lifetime excess cancer risk of 9 (range 3 to 42) cancers per 100,000 men, and 28 (range 9 to 130) cancers per 100,000 women. This excess risk decreased as individuals aged. The greater risk in women was attributed to excess breast cancer risk and a 2-fold-higher lung cancer risk.

CAC may also increase downstream health care utilization. We found mixed findings on whether CAC increased subsequent cardiac imaging or procedures (including revascularization). In the EISNER RCT, CAC did not increase subsequent imaging or procedures; however, a large retrospective analysis of Medicare claims data found an association of greater cardiac imaging and revascularization compared to an hsCRP or lipid screening group. Even if CAC does increase downstream testing in certain practice settings, it is unclear if this is a net benefit or harm, as the analysis from the Medicare claims data also found a nonstatistically significant association of fewer CVD events in the CAC versus hsCRP screening groups. A very small body of evidence, clinical heterogeneity, and methodological limitations of retrospective analyses of claims data prevent any definitive conclusions.

None of our included studies examined the prevalence of incidental findings on CT imaging for CAC. One systematic review included seven studies of screening CAC that reported the prevalence of any incidental findings (majority pulmonary nodules), which ranged from 8 to 58.1 percent of scans, 2.8 to 41.5 percent for “significant” findings, defined as cases requiring followup and 0.07 to 1.2 percent for newly diagnosed cancer.^145^ Again, it is unclear whether identification of incidental findings represents a net benefit or harm. We found no studies that addressed downstream utilization of medical testing or procedures secondary to incidental findings, and/or benefits/harms from detection of incidental findings.

### Benefits and Harms of Nontraditional Risk Factor-Guided Therapy

We found no studies that evaluated the benefit of nontraditional risk factor assessment when added to traditional multivariate risk factor assessment. Nonetheless, we included four trials that evaluated ABI, hsCRP, and CAC-guided therapy in asymptomatic individuals without known CVD. JUPITER found a benefit in CVD morbidity and all-cause mortality for high-intensity statin therapy consisting of rosuvastatin 20 mg in people with an elevated hsCRP but normal LDL (less than 130 mg/dL) compared to a placebo group. At baseline, approximately half of the participants had a 10-year risk of 10 percent or less (as calculated by the FRS) and therefore would likely not have been treated with a statin. All trial participants had an hsCRP of 2.0 mg/L or greater and thus this trial provides no direct evidence comparing treatment in those with an elevated compared to a normal hsCRP. Exploratory subgroup analyses by baseline hsCRP showed an increased absolute risk of a cardiovascular event with higher hsCRP levels, but similar relative risk reductions with rosuvastatin across the range of hsCRP levels included in the study.^146^ It is unclear whether the benefit seen in JUPITER is applicable to just those with an elevated hsCRP or if this benefit would be applicable to a broader, unselected population as studies have shown mixed results about whether the benefit of statins extends to both those with normal and elevated hsCRP. A post-hoc analysis of the AFCAPS/TexCAPS trial showed the strongest support for effect modification; among participants with LDL less than 149 mg/dL, low- or moderate-intensity statin (lovastatin 20 or 40 mg) was associated with a reduction in CHD events in those with baseline hsCRP of 1.6 mg/L or greater (RR 0.58 [95% CI, 0.34 to 0.98]), but not in those with hsCRP below this level (RR 1.08 [95% CI, 0.56 to 2.08]); the pvalue in a test for interaction among statin treatment, CRP, and lipid level was 0.06.^147^ This was the hypothesis-generating analysis for JUPITER, which restricted its inclusion to individuals with normal LDL and elevated hsCRP (≥2.0 mg/L). HOPE-3, which evaluated moderateintensity statin therapy consisting of rosuvastatin 10 mg compared to placebo, showed largely overlapping confidence intervals for CVD outcomes in analyses stratified by a hsCRP threshold of 2.0 mg/L (HR 0.82 [95% CI 0.64 to 1.06] for hsCRP ≤2.0 versus 0.77 [95% CI, 0.60 to 0.98] for hsCRP >2.0; p for interaction=0.694).^148^ The Heart Protection Study, which included a higher-risk population (existing CHD, occlusive disease, diabetes, or receiving antihypertensive therapy), similarly showed no evidence of effect modification for CVD events by CRP level, with an overall event rate ratio of 0.76 (95% CI, 0.72 to 0.81) for moderate-intensity statin therapy consisting of simvastatin 40 mg versus placebo.^149^ The benefit observed in JUPITER may represent an upper bound as the trial was stopped early at 1.9 years of followup. This trial found an increase in diabetes incidence in the statin group compared to the placebo group, but no other serious adverse events. The nonstatistically significant results of the St. Francis trial which evaluate CAC-guided statin therapy should not be directly compared to JUPITER (i.e., lack of benefit for CAC-guided statin therapy and benefit for hsCRP-guided statin therapy), as the St. Francis trial evaluated moderate-intensity statin therapy (as opposed to high-intensity) and was not adequately powered to detect differences in CVD events.

## Limitations of the Review

Our review has numerous limitations. First, we focused this review on the three most promising nontraditional risk factors: ABI, hsCRP, and CAC. We also restricted our inclusion to English language studies and studies in developed countries, although we do not believe this restriction biased our review findings. Given the large volume of studies included for KQ2, we made some explicit exclusions so as to focus on the most clinically relevant analyses, such as the exclusion of: CVA-specific outcomes, CAC derived from lung cancer screening, or CT angiography, studies in which the comparator was a single nontraditional risk factor alone, and analyses that did not allow us to isolate the contribution of individual nontraditional risk factors (i.e., studies using base models including other risk factors and studies comparing the FRS to the RRS). Additionally, studies were excluded if it could not be determined whether reclassification was appropriate (i.e., reclassification was reported without respect to events). Additionally, the predictive value of traditional risk factors such as total or HDL cholesterol was taken as given, but some literature suggests that these, too, might be very small to small when assessed in terms of the c-statistic.^65^ We were conservative in our data synthesis across the body of evidence; that is, we did not quantitatively pool c-statistics/AUC or NRI and we did not make direct comparisons of finding across studies. Even though we stratified our discussion by base model (the FRS vs. PCE) and model type (published coefficients vs. model development), many of the studies had variations in included populations (e.g., inclusion of patients with diabetes, distribution of CVD risk), differences in analyses (e.g., model recalibration, time horizon), differences in outcomes predicted (e.g., hard vs. soft events), and definitions of risk strata that prohibited more definitive conclusions. We did, however, explore differences in nontraditional risk factor performance in those studies which examined more than one nontraditional risk factor.

## Limitations of Included Studies and Future Research Needs

No studies have evaluated the clinical impact of cardiovascular risk assessment with or without nontraditional risk factors on patient health outcomes. Clinical impact studies should be a priority if any of these nontraditional risk factors are implemented on a targeted population level. Largely speaking, the proliferation of cardiovascular risk assessment literature, particularly model development studies without external validation, will not provide the much-needed clinical answers on nontraditional risk factor assessment. However, there are some exceptions. Given that traditional risk tools can overestimate CVD risk, it is crucial to understand the incremental value of promising nontraditional risk factors on calibration, as well as discrimination and reclassification. More consistent reporting of calibration plots will allow for better understanding of what individuals will benefit from improved calibration and O:E ratios will facilitate comparison of calibration across studies. To understand the true net benefit of reclassification, robust reporting of event and nonevent NRI, and reporting of integrated measures that weight the erroneous misclassification for nonevent proportionally, are important. More studies in diverse populations will aid in understanding whether there are population segments for whom traditional risk factor assessment may underperform to a greater degree and thereby achieve greater benefit from nontraditional risk factor assessment. External validation studies of extended models with nontraditional risk factors are needed. Apart from the ABI Collaboration IPD meta-analysis, none of the extended models has been externally validated.

Given that CAC appears to be the most promising nontraditional risk factor, an IPD metaanalysis for CAC (including longer followup of included cohorts) would be informative in furthering understanding of reclassification in subpopulations (e.g., intermediate-risk groups, those for whom traditional risk factor assessment typically underperforms), and vet what impact a CAC score of 0 has on appropriate downward classification of people at intermediate or high risk by traditional risk assessment. Well-designed prospective studies that are reflective of realworld practice are needed to evaluate the downstream effects of CAC on cardiac imaging and revascularization, as well as incidental findings, since these are common. These include studies that aid in determining whether the identification of incidental findings, and/or increased health care utilization, is a net benefit or net harm.

## Conclusion

In the absence of true clinical impact studies reporting cardiovascular morbidity and/or mortality, we need to understand the incremental value of risk prediction with nontraditional risk factors, using calibration, discrimination and reclassification. Despite limitations in the reporting of these performance measures as well as limitations in the measures themselves, we can draw some conclusions. There remains scant information on the incremental value of nontraditional risk factors to help with the problem of miscalibration of traditional cardiovascular risk assessment. Evidence from one large IPD meta-analysis suggests that clinicians could use ABI in addition to the FRS to improve upon discrimination and reclassification in populations for whom the FRS model has poor discrimination. While CAC appears to be the most promising nontraditional risk factor to improve discrimination and reclassification, it is based on a smaller body of evidence which lacks IPD meta-analyses. CAC may also result in additional downstream testing/procedures, and it is unclear whether these sequelae represent a net benefit or harm to individuals. One large RCT shows that high-intensity statin therapy in individuals with elevated hsCRP and normal lipid levels can reduce CVD morbidity and mortality, but it is unclear whether these benefits would not also be applicable to individuals with normal hsCRP. The use of hsCRP-guided therapy has not been evaluated against therapy guided by multivariate cardiovascular risk assessment.