# 3 Results

## Overview of Included Trials and Cohorts

Our literature search yielded 22,707 unique citations. From these, we provisionally accepted 483 articles for review based on titles and abstracts (Appendix B Figure 1). After reviewing the full-text articles and performing critical appraisal, we included a total of 43 studies that reported results in 54 publications (some studies were included for multiple questions). We found 1 study (1 article) for KQ1,^11^ 33 studies (43 articles) for KQ2,^65,^ ^66,^ ^74-114^ 8 studies (8 articles) for KQ3,^11,^ ^88,^ ^89,^ ^115-119^ 4 studies (5 articles) for KQ4,^120-124^ and 3 studies (3 articles) for KQ5.^120,^ ^122,^ ^123^ Appendix C contains a full list of included studies. For the 483 articles that we reviewed in full, the most common reasons for exclusion were study aim, outcomes, study design, and eligibility of the base prediction model (KQ2). Appendix D contains a list of all excluded full-text articles and their reasons for exclusion.

Table 5 is an overview of all included trials and cohorts, and the key questions each trial or cohort addresses. In total, our review includes studies representing 38 unique trials or cohorts. We describe the included populations separately for each respective KQ, and for KQ2, describe populations included in ABI, hsCRP, and CAC studies separately.

Table 5 Evidence Landscape

KQ1 | KQ2 | KQ3 | KQ4 | KQ5 | Cohort study | Author, Year | Nontraditional risk ractor(s) evaluated
× | | × | | | EISNER | Rozanski, 2011^11^ | CAC
| × | × | | | Framingham Offspring + 3rd Generation | Hoffmann, 2016^88^ | CAC
| × | × | | | Rotterdam | Bos, 2015^89^ | CAC
| × | | | | ABI Collaboration | Fowkes, 2014^66^ | ABI
| × | | | | ARIC | Murphy, 2012^79^ | ABI
| × | | | | ARIC | Folsom, 2006^110^ | CRP
| × | | | | British Regional Heart Study | Wannamethee, 2011^102^ | CRP
| × | | | | EAS | Price, 2007^80^ | ABI
| × | | | | EAS | Shah, 2009^78^ | CRP
| × | | | | EISNER | Rana, 2012^99^ | CAC, CRP
| × | | | | EISNER + Referred Participant Database | Wong, 2009^106^ | CAC
| × | | | | EPIC-Norfolk | Rana, 2009^104^ | CRP
| × | | | | ERFC IPD MA | Emerging Risk Factors Collaboration, 2012^65^ | CRP
| × | | | | Framingham + Framingham Offspring | Wilson, 2005^85^ | CRP
| × | | | | Framingham Offspring | Wilson, 2008^107^ | CRP
| × | | | | Framingham Offspring | Zhou, 2013^97^ | CRP
| × | | | | Health ABC | Rodondi, 2010^81^ | ABI, CRP
| × | | | | HNR | Geisel, 2017^114^ | ABI, CAC
| × | | | | HNR | Mohlenkamp, 2011^103^ | CAC, CRP
| × | | | | HNR | Erbel, 2010^74^ | CAC
| × | | | | Houston Methodist DeBakey Heart and Vascular Center | Chang, 2015^93^ | CAC
| × | | | | Inter99 | Seven, 2015^92^ | CRP
| × | | | | MESA | Yeboah, 2016^90^ | ABI, CAC, CRP
| × | | | | MESA | Yeboah, 2012^75^ | ABI, CAC, CRP
| × | | | | MESA | Polak, 2017^113^ | CAC
| × | | | | MESA | Fudim, 2016^112^ | CAC
| × | | | | MESA | Polonsky, 2010^77^ | CAC
| × | | | | MESA | Malik, 2011^101^ | CAC
| × | | | | MESA and HNR | Yeboah, 2014^94^ | CAC
| × | | | | MONICA - Augsburg | Koenig, 2004^84^ | CRP
| × | | | | MONICA - Copenhagen | Lyngbaek, 2013^96^ | CRP
| × | | | | Nijmegen Biomedical Study | Holewijn, 2014^95^ | ABI
| × | | | | NPHS II | Shah, 2009^78^ | CRP
| × | | | | Pooled Analysis of 5 Cohorts^‡^ of Low Risk Women | Kavousi, 2016^111^ | CAC
| × | | | | PROSPER | Sattar, 2007^108^ | CRP
| × | | | | REGICOR | Velescu, 2015^91^ | ABI
| × | | | | Reykjavik | Danesh, 2004^87^ | CRP
| × | | | | Rotterdam | Kavousi, 2012^82^ | ABI, CAC, CRP
| × | | | | Rotterdam | Eias-Smale, 2010^76^ | CAC, CRP
| × | | | | Scottish Health Survey | Hamer, 2009^105^ | CRP
| × | | | | SHIP | Schneider, 2012^100^ | CRP
| × | | | | Singapore Chinese Health Study | Salim, 2016^109^ | CRP
| × | | | | South Bay Heart Watch | Greenland, 2004^86^ | CAC
| × | | | | WHS | Cook, 2006^83^ | CRP
| × | | | | WOSCOPS | Welsh, 2013^98^ | CRP
| | × | | | Active-duty Army personnel | O’Malley, 2003^119^ | CAC
| | × | | | DanRisk | Nielsen, 2012^118^ | CAC
| | × | | | HealthCore Integrated Research Database | Chi, 2014^116^ | CAC
| | × | | | Medicare | Shreibati, 2014^117^ | CAC, CRP
| | × | | | MESA | Messenger, 2016^115^ | CAC
| | | × | × | AAA | Fowkes, 2010^122^ | ABI
| | | × | × | JUPITER | Ridker, 2008^120^ | CRP
| | | × | | JUPITER | Mora, 2010^124,†^ | CRP
| | | × | × | POPADAD | Belch, 2008^123^ | ABI
| | | × | | St. Francis Heart Study | Arad, 2005^121^ | CAC
1 | 44^*^ | 8 | 5 | 3 | Number of total articles

* There are 44 cohorts reported in 43 articles. Shah, 2009, analyzes both EAS and NPHS cohorts.

† Sex-specific analyses

‡ Five pooled cohorts: DHS, FHS, HNR, MESA, and Rotterdam

Abbreviations: AAA = the Aspirin for Asymptomatic Atherosclerosis trial; ABI = ankle-brachial index; ARIC = Atherosclerosis Risk in Communities study; CAC = coronary artery calcium; CRP = C-reactive protein; DanRisk = the Danish Risk Score study; DHS = Dallas Heart Study; EAS = Edinburgh Artery Study; EISNER = Early Identification of Subclinical Atherosclerosis by Noninvasive Imaging Research; EPIC = European Prospective Investigation into Cancer and Nutrition; ERFC = Emerging Risk Factors Collaboration; FHS = Framingham Heart Study; Health ABC = Health, Aging, and Body Composition study; HNR = Heinz Nixdorf Recall study; IPD MA = individual participant data meta-analyses; JUPITER = Justification for the Use of Statins in Prevention: an Intervention Trial Evaluating Rosuvastatin; KQ = key question; MESA = Multi-Ethnic Study of Atherosclerosis; MONICA = MONItoring of trends and determinants in CArdiovascular disease; NPHS = Northwick Park Heart Study; POPADAD = the Prevention of Progression of Arterial Disease and Diabetes trial; PROSPER = Prospective Study of Pravastatin in the Elderly at Risk; REGICOR = Registre Gironí del Cor (Girona Heart Registry); SHIP = the Study of Health in Pomerania; WHS = Women’s Health Study; WOSCOPS = the West of Scotland Coronary Prevention Study

## KQ1 Compared With the PCE or FRS Alone, Does Risk Assessment of Asymptomatic Adults Using Nontraditional Risk Factors—Followed by Treatment Specific to Risk Level—Lead to Reduced Incidence of Cardiovascular Events and/or Mortality?

We included only one study that examined the effectiveness of nontraditional risk factor assessment on patient health outcomes.^11^ This fair-quality randomized controlled trial (RCT) (n=2,137) was primarily designed to assess the impact of CAC screening on CVD risk factors and downstream testing, but it also reported health outcomes and therefore is included for this key question. The Early Identification of Subclinical Atherosclerosis by Non-invasive Imaging Research (EISNER) trial, conducted in the United States, randomized volunteers to undergo CT scanning for CAC scoring in addition to the FRS versus no CT before risk factor counseling (Table 6). The primary outcome was a change in CVD risk factors and Framingham Risk Score at 4 years. Participants were middle-aged adults with CVD risk factors but no known CVD or symptoms (Table 7). This study found no statistically significant difference in MI, mortality, or combined MI and mortality at 4 years between the two groups (Table 8). The trial was well conducted but did not have adequate sample size and length of followup to detect differences in patient health outcomes. This study is discussed with respect to downstream testing and radiation dose in KQ3, and to adherence to risk factor modification in the Discussion section.

Table 6 Methodological and Intervention Characteristics of Included Screening Studies (KQs 1 and 3)

Author, Year Study name | Quality | Country | N | Recruitment setting and method | Followup | Intervention | Control | Primary outcome
Rozanski, 2011^11^ EISNER | Fair | U.S. | 2,137 | Volunteers recruited from medical center | 4 years | One individual risk factor counseling session with trained NP and CAC scan. Counseling session included review of CAC images, score and percentile; patients encouraged to share CAC scan report with their physician (report was not directly shared) CAC scanning performed with electron beam or multislice CT; imaging protocol involved single scan of ~30 to 40 slices of 3 or 2.5 mm thickness. Agatston method used to determine calcium score. | One individual risk factor counseling session with trained NP | 4-year change in CAD risk factors and FRS

Abbreviations: CAC = coronary artery calcium; CAD = coronary artery disease; CT = computed tomography; EISNER = Early Identification of Subclinical Atherosclerosis by Noninvasive Imaging Research; FRS = Framingham Risk Score; mm = millimeter; NP = nurse practitioner

Table 7 Patient Characteristics of Included Screening Studies (KQs 1 and 3)

Author, Year Study name | Population description | Mean age, years | % Women | % by Race/ethnicity | % Smoking | % Diabetes | % High Cholesterol | % HTN | % Medications | % by CAC score categories^*^ | FRS, %
Rozanski, 2011^11^ EISNER | Middle-aged individuals with CAD risk factors, but no CVD history or symptoms | 58.5 | 47.5 | Caucasian: 77.0 African American: 5.0 Asian/PI: 10.5 Latino: 4.2 | Past: 41.5 Current: 5.7 | 8.2 | 77.5 | 57.3 | Aspirin: 12.8 BP: 32.2 Diabetes: 4.1 Statins: 23.5 | 0: 48.1 1-99: 30.5 100-399: 13.0 ≥400: 8.3 | 6 (2, 12)^†^

* For N=1,311

† Median (25th, 75th percentile) 10-year risk for CAD; patients with diabetes automatically assigned high risk of 20%, or higher if so calculated

Abbreviations: BMI = body mass index; BP = blood pressure; CAC = coronary artery calcium; EISNER = Early Identification of Subclinical Atherosclerosis by Noninvasive Imaging Research; FRS = Framingham Risk Score; PI = Pacific Islander; HTN = hypertension

Table 8 Cardiovascular Events, Mortality, and Harms Outcomes in Included Screening Studies (KQs 1 and 3)

Author, Year Study name | Followup | Outcome | IG N | IG N (% or level) | CG N | CG N (% or level) | Between group difference; RR (95% CI)^*^; p
Rozanski, 2011^11^ EISNER | 4 years | Composite of all deaths and MI | 1,256 | 27 (2.1) | 584 | 6(1.0) | 2.09 (0.87 to 5.04); p=0.08
Rozanski, 2011^11^ EISNER | 4 years | All-cause death | 1,256 | 17 (1.3) | 584 | 4 (0.6) | 1.98 (0.67 to 5.85); p=0.24
Rozanski, 2011^11^ EISNER | 4 years | Cardiac death | 1,256 | 2 (0.2) | 584 | 1 (0.2) | 0.93 (0.08 to 10.24); p=1.00
Rozanski, 2011^11^ EISNER | 4 years | MI | 1,256 | 10 (0.8) | 584 | 2 (0.3) | 2.32 (0.51 to 10.58); p=0.36
Rozanski, 2011^11^ EISNER | 4 years | Estimated radiation dose (mSv) | 1,256 | 1 to 2 | 584 | NA | NR

* Calculated crude RR and CI; p-values are study-reported

Abbreviations: CG = control group; CI = confidence interval; EISNER = Early Identification of Subclinical Atherosclerosis by Noninvasive Imaging Research; IG = intervention group; MI = myocardial infarction; mSv = millisievert; RR = relative risk

## KQ2 Does Use of Nontraditional Risk Factors in Addition to Traditional Risk Factors to Predict CVD Risk Improve Measures of Calibration, Discrimination, and Risk Reclassification?

### Summary

We included 33 studies reported in 43 articles that evaluated ABI, hsCRP, and/or CAC in addition to traditional cardiovascular risk assessment using one or more measures of calibration, discrimination, and/or risk reclassification. Ten studies (including 1 large IPD meta-analysis) evaluated ABI, 25 studies (including 1 large IPD meta-analysis) evaluated hsCRP, and 19 studies evaluated CAC (Table 9). This body of evidence answers two related yet distinct questions: 1) studies using the published coefficients answer “what is the added predictive value of assessing ABI, hsCRP, or CAC after using a traditional risk assessment tool like the FRS (recommended by ATP III) or the PCE (recommended by the ACC/AHA)?” and 2) model development studies answer “what is the incremental predictive value of adding a nontraditional risk factor to traditional CVD risk factors when developing a risk prediction tool?” Only four studies evaluated ABI, hsCRP, and/or CAC in addition to the PCE;^89,^ ^90,^ ^111,^ ^112^ most used a base model of the FRS. The vast majority of the included studies are model development studies (as opposed to studies using published coefficients) without external validation.

Table 9 Study Counts for Key Question 2

Risk factor | For any KQ2 outcome | Calibration | Discrimination | Reclassification
ABI | 10 articles 22 cohorts^*^ 12 models | 5 articles 20 cohorts^*^ 5 models | 10 articles 22 cohorts^*^ 12 models | 9 articles 22 cohorts^*^ 10 models
CRP | 25 articles^†^ 49 cohorts^‡^ 28 models | 9 articles^†^ 10 cohorts 11 models | 25 articles^†^ 49 cohorts^‡^ 28 models | 15 articles^†^ 33 cohorts^§^ 17 models
CAC | 19 articles 10 cohorts 24 models | 8 articles 4 cohorts 8 models | 18 articles 10 cohorts 23 models | 15 articles 9 cohorts 18 models

* 18 cohorts represented in 1 IPD MA

† 1 article, Shah 2009, reports 2 cohorts separately

‡ 38 cohorts represented in 1 IPD MA

§ 22 cohorts represented in 1 IPD MA (studies were included for reclassification analyses if they had >10 years of followup and reported both fatal and nonfatal CVD events)

Abbreviations: ABI = ankle-brachial index; CAC = coronary artery calcium; CRP = C-reactive protein; CVD = cardiovascular disease; IPD MA = individual participant data meta-analyses; KQ = key question

Overall, while good measures of calibration are not well reported in this body of literature, it appears that all three nontraditional risk factors can improve calibration of CHD or CVD risk prediction when added to the FRS or PCE; the magnitude and clinical impact of this improvement is not certain. Calibration plots and O:E ratio are preferable because of their ease of interpretation and ability to indicate direction of miscalibration, but are rarely reported.

Discrimination and reclassification are commonly reported. The improvement in discrimination, in large part, is dependent on the underlying performance of the base model, such that if the FRS or PCE has poor discrimination, the improvement in discrimination by adding ABI, hsCRP, and/or CAC is larger. Two included studies recalibrated the FRS or PCE to the analyzed population;^90,^ ^91^ because this will improve the base model discrimination, estimates of improvement in with the addition of a nontraditional risk factor will be conservative (i.e., underestimate the change in discrimination with the addition of a nontraditional risk factor to a non-recalibrated based model). Changes in discrimination were most often less than 0.025 for ABI and hsCRP, and it is difficult to interpret the clinical impact of very small or small improvements in AUC or c-statistic. Measures of reclassification may be more clinically intuitive, but there are limitations in its interpretation; the most common measure of reclassification reported in this literature is the total NRI. Total NRI is the sum of event and nonevent NRI and is not weighted by the prevalence of events and nonevents. Because nonevents are substantially more common, the total NRI may overstate the improvement in reclassification.

#### ABI

Based on one large IPD meta-analysis by the ABI Collaboration that includes 18 different cohorts, ABI can lead to potentially meaningful improvements in discrimination (c-statistic change >0.1) and reclassification (NRI >0.09) in women to predict hard CHD events when added to the FRS using published coefficients. The incremental improvement in c-statistic and NRI for women is most likely due to the poorer discrimination of the base model in women, compared to men; in other words, ABI is not inherently superior in women than in men, but is compensating for the poorer performance of the FRS in women than in men. Examination of separate components of the NRI (event and nonevent NRI) suggests that improvement in reclassification comes from women who had events being appropriately reclassified as having a higher risk; in contrast, women who did not have a cardiovascular event (which is the majority of the population) were inappropriately reclassified as having a higher risk (i.e., a negative nonevent NRI). In the model development analyses conducted by the ABI Collaboration, the discrimination for the base model was higher in women compared to men (the opposite of what was observed using published coefficients), and subsequently, the improvement in discrimination and reclassification (observed using published coefficients) was not observed (i.e., no statistically significant change in discrimination or NRI). Based on this IPD meta-analysis, ABI appears to be most promising for women at intermediate risk (10-19% 10-year risk for hard CHD outcomes) with an NRI of 0.288 (95% CI, 0.064 to 0.513). However, the ABI Collaboration analyses were restricted to Whites only.

#### hsCRP

Results for hsCRP are less consistent, and while hsCRP can improve discrimination and risk reclassification, the improvements are small at best. Studies using published coefficients for the FRS demonstrate that hsCRP can improve discrimination, but results are not consistent, and the higher estimates of improvement in discrimination, which are small (0.03), likely represent an upper bound of improvement. Based on one large IPD meta-analysis, a model development study, by the Emerging Risk Factors Collaboration that included 38 different cohorts, hsCRP had a very small improvement on discrimination to predict hard CHD (0.005) or CVD (0.004) events. Correspondingly, the improvement in NRI is 0.015 (95% CI, 0.008 to 0.023). Sex-stratified analyses suggest that improvement in discrimination and reclassification may be better for men than women.

#### CAC

CAC has the smallest body of evidence, owing to the smaller sample sizes of included cohorts; no IPD meta-analysis presents results for the incremental predictive value of CAC. Nonetheless, CAC consistently appears to result in at least small, and often larger, improvements in discrimination in studies evaluating hard outcomes in all participants using published coefficients (0.02 to 0.102) and model development studies (0.02 to 0.05). Five studies report improvement in discrimination and reclassification from adding CAC to the PCE or models with PCE variables: three published coefficient studies evaluating just two cohorts and two model development studies. Categorical NRI from model development studies in all participants ranged from 0.14 to 0.319 (continuous NRI ranged from 0.20 to 0.28); evaluation of separate components of the NRI shows that improvements in NRI are consistently driven by event NRIs much larger than nonevent NRIs, which were commonly negative (when reported), and sometimes statistically significant. A limited number of studies report sex-stratified analyses; however, without IPD meta-analyses, it is unclear if there are any consistent sex differences in discrimination or reclassification. The bias-corrected NRI_int_ was not consistently reported or calculable. Based on limited data, the bias-corrected NRI_int_ is not consistently greater than the NRI for all participants.

#### Direct Comparisons of ABI, hs CRP, and CAC

Nine studies evaluate more than one nontraditional risk factor and therefore allow for more direct comparison across ABI, hsCRP, and CAC (Table 10). Overall, CAC appears to be the most promising nontraditional risk factor to add to traditional cardiovascular risk factor assessment. Only two studies using published coefficients evaluated multiple nontraditional risk factors; one evaluated both the PCE and FRS. This study, using the Multi-Ethnic Study of Atherosclerosis (MESA) cohort, found no improvement in discrimination or reclassification for ABI and hsCRP, but the study was limited to lower-risk people because participants taking a statin were excluded from the analyses. However, in this study, CAC did improve both discrimination and reclassification. The other published coefficient analysis using the Heinz Nixdorf Recall cohort evaluated both ABI and CAC added to the FRS and similarly found greater improvement for CAC than ABI. Six model development studies evaluated more than one nontraditional risk factor in addition to the FRS to predict hard CHD or soft CVD events. Five of these six studies included CAC and found statistically significant improvements in discrimination and reclassification; these improvements were greater than effects seen for either ABI and/or hsCRP.

Table 10 Comparison of Predictive Ability of Nontraditional Risk Factors Across Selected Analyses Reporting More Than One Nontraditional Risk Factor (ABI, hsCRP, CAC)

| Cohort (Publication) | MESA (Yeboah, 2016)^90^ | MESA (Yeboah, 2016)^90^ | Heinz Nixdorf Recall (Geisel, 2017)^114^ | MESA–Intermediate risk only^#^ (Yeboah, 2012)^75^ | Rotterdam^**^ (Kavousi, 2012)^82^ | Health ABC (Rodondi, 2010)^81^ | Heinz Nixdorf Recall (Mohlenkamp, 2011)^103^ | EISNER (Rana, 2012)^99^
| Model Type | Published coefficient | Published coefficient | Published coefficient | Model development | Model development | Model development | Model development | Model development
| Base Model | PCE | FRS | FRS | FRS variables | FRS variables | FRS variables | FRS variables | FRS variables
| Predicted Outcome | Hard CVD | Hard CHD | Hard CVD | Soft CVD | Hard CHD | Hard CHD | Hard CHD | Soft CVD
| Risk Thresholds (%) | ≥7.5 <7.5 10 yr-risk | >20 10 to 20 <10 10-yr risk | >20 10 to 20 <10 10-yr risk | >21.1 3.4 to 21.1 <3.47 5-yr risk | >20 10 to 20 <10 10-yr risk | ≥15 7.5 to <15 <7.5 7.5-yr risk | >20 10 to 20 <10 10-year risk | >8 2.4 to 8 <2.4 4-yr risk
| N analyzed; # events | 5,135 320 | 5,185 194 | 3,108 223 | 1,330 132 | 3,029 to 5,933^‡^ 347 | 1,515 to 2,191^††^ 197 | 3,966 91 | 1,586 35
ABI | C-statistic (Δ^*^) | 0.75 (Δ=0.01) p=0.55 | 0.75 (Δ=0.01) p=0.042 | 0.687 (Δ=-0.006) p=0.54 | 0.65 (Δ=0.027) p=0.01 | NR (Δ=0.00^†^, [0.00 to 0.00]) p=NR | 0.612 (Δ=0.012) p=NR; N=1,515
ABI | Event NRI Nonevent NRI Total NRI (95% CI) | 0.013 0.004 0.017 (-0.031 to 0.058) | 0.041 -0.003 0.039 (-0.011 to 0.109) | NR NR 0.190^‡‡^ (0.102 to 0.278) | 0.041 0.027 0.068 (NR) | NR NR 0.006 (-0.018 to 0.029) | NR NR 0.079 (NR)
hsCRP | C-statistic (Δ^*^) | 0.74 (Δ=0.0) p=0.25 | 0.74 (Δ=0.0) p=0.925 | | 0.64 (Δ=0.017) p=0.03 | NR (Δ=0.00^†^ [-0.01 to 0.00]) p=NR | 0.592 (Δ=-0.008) p=NR | 0.732 (0.684 -0.780) (Δ=0.013) p=0.12 | 0.73 (0.65 - 0.82) (Δ=0.0) p=0.95
hsCRP | Event NRI Nonevent NRI Total NRI (95% CI) | 0.028 -0.005 0.024 (-0.015 to 0.067) | 0.005 -0.002 0.003 (-0.028 to 0.026) | | 0.016 0.021 0.037 (NR) | NR NR 0.020 (-0.023 to 0.064) | NR ǁ | NR NR 0.105 p=0.026 | NR ǁ
CAC | C-statistic (Δ^*^) | 0.76 (Δ=0.02) p=0.04 | 0.78 (Δ=0.04) p=0.001 | 0.731 (Δ=0.038) p=0.02 | 0.78 (Δ=0.161) p<0.001 | NR (Δ=0.05^†^, [0.02 to 0.06]) | | 0.763 (0.715 to 0.812) (Δ=0.044) p=0.0067 | 0.84 (0.78 to 091) (Δ=0.11) p=0.003
CAC | Event NRI Nonevent NRI Total NRI (95% CI) | 0.178 -0.059 0.119 (0.080 to 0.256) | 0.119 -0.034 0.084 (0.024 to 0.19) | NR NR 0.551^‡‡^ (0.416 to 0.686) | 0.106 0.360 0.466 (NR) | 0.235 -0.041 0.193 (0.125 to 0.262) | | NR NR 0.238 p=0.0007 | 0.286 0.060 0.35 (0.11 to 0.58)

* Change in c-statistics calculated as extended model minus base model

† c-statistic is corrected for over-optimism by using 100 bootstrap repetitions

‡ The analyses for hsCRP (n=3,029) and CAC score (n=3,678) were performed in a smaller group.

§ In case of hsCRP, power was not enough to perform sex-specific analysis.

ǁ NRI was not reported because hsCRP did not result in significant improvement in c-statistics

¶ Chose external validation dataset; model development was available

# NRI is not bias-corrected.

** Not shown: Elias-Smale, 2010^76^ obtained similar results with a smaller cohort (n=2,028) from the Rotterdam Study: C-statistics – hsCRP: Δ*=0.0, p=0.31; CAC: Δ*=0.04 p<0.001; NRI – CAC: 0.14; hsCRP: NR, due to c-statistics not resulting in significant improvement.

†† c-statistics analyzed with completed data on all markers in Health ABC, n=1,515; NRI analyzed with complete data on ABI in Health ABC, n=1,985.

‡‡ Continuous NRI

Abbreviations: ABI = ankle-brachial index; CAC = coronary artery calcium; CHD = coronary heart disease; CI = confidence interval; CVD = cardiovascular disease; EISNER = Early Identification of Subclinical Atherosclerosis by Noninvasive Imaging Research; FRS = Framingham Risk Score; F/U = follow up; Health ABC = Health, Aging, and Body Composition study; HNR = Heinz Nixdorf Recall study; hsCRP = high-sensitivity C-reactive protein; MESA = Multi-Ethnic Study of Atherosclerosis; NR = not reported; NRI = net reclassification improvement; PCE = Pooled Cohort Equations

### Detailed Results for ABI

#### Description of Cohorts

We included 10 unique studies, including one IPD meta-analysis that examined whether ABI added to traditional CVD risk assessment could improve calibration, discrimination, or risk reclassification (Tables 11 and 12).^66,^ ^79-82,^ ^90,^ ^91,^ ^95^ These 10 studies include data from 22 different cohorts (Table 11). The included IPD meta-analysis^66^ is an updated analysis from the ABI Collaboration’s prior analyses in 2008.^125^ This IPD meta-analysis includes 18 of the 22 cohorts (Heinz Nixdorf Recall, MESA, Nijmegen Biomedical Study, and REGICOR populations are not included).

Table 11 A Comparison of Cohorts in the Included ABI Risk Prediction Studies With ABI Collaboration IPD Meta-Analysis

Cohort | 2014 IPD MA^66,*^ | Individual publications
ARIC | n=10,467 | Murphy, 2012^79^; n=11594
Belgian Physical Fitness | n=2,020
CHS | n=3,877
EAS | n=1,392 | Price, 2007^80^; n=1007
Framingham Offspring | n=3,126
Health ABC | n= 1,405 | Rodondi, 2010^81^; n=2191
Health in Men | n=3,217
Honolulu Heart Program
HNR | | Geisel, 2017^114^; n=3,108
Hoorn Study | n=557
InCHIANTI | n=1,161
Limburg PAOD | n=2,361
Men Born in 1914 | n=392
MESA | | Yeboah, 2016^90^; n=5185
MONICA Augsburg | n= 1,283
Mr OS | n=4,167
Nijmegen | | Holewijn, 2014^95^; n=1367
REGICOR | | Velescu, 2015^91^; n=5248
Rotterdam | n=5,549 | Kavousi, 2012^82^; n=5933
San Diego | n=556
San Luis Valley Diabetes | n=1,513
Strong Heart
Study of Osteoporotic Fractures | n=1,233
Women’s Health and Aging | n=476
22 total cohorts: 4 not represented in IPD MA

* The 2008 IPD MA from the ABI Collaboration additionally included the Honolulu Heart Program and Strong Heart Study, which were excluded in the 2014 updated due to restriction to White populations.^125^

Abbreviations: ABI = ankle-brachial index; ARIC = Atherosclerosis Risk in Communities study; CHS = Cardiovascular Health Study; EAS = Edinburgh Artery Study; Health ABC = Health, Aging, and Body Composition study; HNR = Heinz Nixdorf Recall = InCHIANTI = Invecchiare in Chianti (aging in the Chianti area); IPD MA = individual participant data meta-analyses; Limburg PAOD = the Limburg peripheral arterial occlusive disease study; MESA = Multi-Ethnic Study of Atherosclerosis; MONICA = MONItoring of trends and determinants in CArdiovascular disease; Mr OS = the Osteoporotic Fractures in Men study; REGICOR = Registre Gironí del Cor (Girona Heart Registry)

Table 12 Study Design and Participant Characteristics of Included ABI Risk Prediction Studies (KQ 2)

Author, Year | Model type: Base model | Study name | Country | N | F/U, mean (yrs); range | Mean age | % Women | % White | % DM | % HTN (% treated) | % Chol meds^*^ | % Current smoker | Mean ABI; (% Low ABI)^¶¶¶^
Yeboah, 2016^90^ǁǁ | Published coefficient: PCE | MESA | United States | 5,185 | 10; NR | 61.2 | 53.1 | 38 | 9.8 | NR (32.5) | 0 | 13.6 | 1.1^§^; (NR)
Yeboah, 2016^90^ǁǁ | Published coefficient: FRS | MESA | United States | 5,185 | 10; NR | 61.2 | 53.1 | 38 | 9.8 | NR (32.5) | 0 | 13.6 | 1.1^§^; (NR)
Geisel, 2017 ^114^ | Published coefficient: FRS | HNR | Germany | 3,108 | 10.3; NR | 59.2 | 52.9 | NR | 11.5 | NR (31.6) | 9.2 | 22.6 | 1.14; (3.7)
Velescu, 2015^91^ | Published coefficient: FRS | REGICOR | Spain | 5,248 | 5.9^§^; NR | 53.7 | 54.5 | NR | 12.6 | 41.8 (NR) | NR | 24.1 | NR; (3.2)
Fowkes, 2014^66^ | Published coefficient: FRS | ABI Collaboration IPD MA^†^ | Multi- national | 44,752^‡^ | NR; 5.0-19.6^§^ | NR | 45.5 | 100 | NR | NR (NR) | NR | NR | NR; (NR)
Fowkes, 2014^66^ | Model development: FRS variables | ABI Collaboration IPD MA^†^ | Multi- national | 44,752% | NR; 5.0-19.6^§^ | NR | 45.5 | 100 | NR | NR (NR) | NR | NR | NR; (NR)
Holewijn, 2014^95^ | Model development: FRS variables | Nijmegen Biomedical Study | Netherlands | 1,242 | 3.8; 0.083-5.6 | 60.8 | 53.1 | NR^***^ | 4.5 | 35 (21.6) | 9.9 | 16.5 | 1.11; (1.3)
Yeboah, 2012^75^ǁǁ | Model development: FRS variables | MESA | United States | 1,330ǁǁǁ | 7.6^§^; 7.3-7.8 (IQR) | 63.8 | 33.3 | 35.7 | 0 | NR (38.2) | 14.1 | 16.5 | 1.14^§^; (NR)
Kavousi, 2012^82^ǁǁ | Model development: FRS variables | Rotterdam | Netherlands | 5,933 | 6.8^§^; 5.8-8.1 (IQR) | 69.1 | 59.4 | NR | 12.9 | NR (23.5) | 10.2 | 17.5 | 1.1; (14)
Murphy, 2012^79^ | Model development: FRS variables | ARIC | United States | 11,594 | 14^§^; (Max 16) | 53.8 | 56.4 | 75.8 | 0 | 33.4 (24.5) | 2.1 | 25.7 | 1.15; (2.3^¶^)
Rodondi, 2010^81^ †† | Model development: FRS variables | Health ABC | United States | 2,191 | 8.2^§^; (Max 10.2) | 73.5 | 55.3 | 58.9 | 13.3 | 46.1 (12.5^§§^) | 10.5 | 10.1 | NR; (12.2^‡‡‡^)
Price, 2007^80^ | Model development: FRS variables | EAS | United Kingdom | 1,007 | NR; (Max 12) | 69.4 | 51.7 | NR | 3.9 | NR (NR) | NR | 2.48^**^ | 1.02; (18.7)

* Percent with hyperlipidemia not reported in any included ABI study

† 18 included cohorts: ARIC, Belgian Physical Fitness Study, CHS, EaS, Framingham Offspring Study, Health ABC Study, Health In Men Study, Hoorn Study, InCHIANTI Study, Limburg PAOD Study, Men Born in 1914 Study, MONICA Augsburg Survey, Mr OS Study, Rotterdam Study, San Diego Study, San Luis Valley Diabetes Study, Study of Osteoporotic Fractures, Women’s Health and Aging Study. Strong Heart Study and Honolulu Heart Program included in Fowkes, 2008, but not present study as non-Whites excluded from this analysis.

‡ 24,707 in development/internal validation dataset and 20,045 in external validation data set

§ Median

¶ Symptomatic PAD present in 3.7% of those with ABI <0.9 and 0.4% in those with ABI ≥0.9

** Mean pack-years

†† Also a study of CRP

§§ ACE inhibitors are the only anti-HTN drug class reported

ǁǁ Also a study of CAC and CRP

*** “Most” Caucasian

††† FRS recalibrated to REGICOR population

‡‡‡ Calculated from denominator of 1702 in Table 6 (207/1702)

ǁǁǁ Intermediate-risk population only, defined as >5% to <20% 10-yr CHD risk

¶¶¶ Threshold for low ABI was < or ≤0.9 where reported

Abbreviations: ABI = ankle-brachial index; ARIC = Atherosclerosis Risk in Communities study; CAC = coronary artery calcium; CHD = coronary heart disease; Chol = cholesterol; CRP = C-reactive protein; DM = diabetes mellitus; EAS = Edinburgh Artery Study; FRS=Framingham Risk Score; F/U = follow up; Health ABC = Health, Aging, and Body Composition study; HTN = hypertension; InCHIANTI = Invecchiare in Chianti (aging in the Chianti area); IPD MA = individual participant data meta-analyses; IQR = interquartile range; Limburg PAOD = the Limburg peripheral arterial occlusive disease study; meds = medications; MESA = Multi-Ethnic Study of Atherosclerosis; MONICA = MONItoring of trends and determinants in CArdiovascular disease; Mr OS = the Osteoporotic Fractures in Men study; NR = not reported; PCE = Pooled Cohort Equations; REGICOR = Registre Gironí del Cor (Girona Heart Registry); yr(s) = year(s)

In total, 12 models were evaluated (Table 13). Four studies evaluated five different models employing published coefficients of the PCE or FRS.^66,^ ^90,^ ^91,^ ^114^ Seven model development studies used FRS variables.^66,^ ^75,^ ^79-82,^ ^95^ Generally, the intended outcome of interest for the FRS is CHD hard outcomes (e.g., ATP III) or soft CVD outcomes (e.g., D’Agostino 2008), and for the PCE, CVD hard outcomes. Two cohorts (Nijmegen and REGICOR) report soft, as opposed to hard, CVD outcomes.^91,^ ^95^ One analysis of the MESA cohort focusing exclusively on intermediate-risk people also reported only soft CHD and CVD outcomes.^75^

Table 13 Base Models for Included ABI Risk Prediction Studies (KQ2)

Author, Year | Model type: Base model | Study name | Age | Sex | Race/ethnicity | Smoking | SBP | Anti- HTN Tx | TC | HDL | TC: HDL ratio | DM | Predicted outcomes^ǁǁ^:N (%) | Handling of ABI in extended model
Yeboah, 2016^90,††^ | Published coefficient: PCE (Goff, 2014)^‡‡^ | MESA | x | x | x | x | x | x | x | x | | x | Hard CVD: 320 (6.2) | Continuous (ABI ≥:1.4 excluded)
Yeboah, 2016^90,††^ | Published coefficient: FRS (D’Agostino, 2001)^‡‡^ | MESA | x | x | | x | x^†^ | | x | x | | x | Hard CHD: 194 (3.7) | Continuous (ABI ≥1.4 excluded)
Geisel, 2017^114^ | Published coefficient: FRS | HNR | x | x | | x | x | x | x | x | | x | Hard CVD: 223 (7.2) | Continuous (per-SD decrease) for discrimination analyses; Categorical: <0.9, ≥0.9 for reclassification analyses
Velescu, 2015^91^ | Published coefficient: FRS (D’Agostino, 2001)^§§^ | REGICOR | x | x | | x | x^†^ | | x | x | | x | Soft CVD: 175 (3.3) Soft CHD: 111 (2.1) | Categorical: <0.9, ≥0.9 (>1.39 excluded)
Fowkes, 2014^66^ | Published coefficient: FRS (Wilson, 1998) | ABI Collaboration IPD MA | x | x | | x | x^†^ | | x | x | | x | Hard CHD: 2950 (6.6)^§^ Fatal CVD^‡^: 2704 (60)^§^ | Categorical: ≥0.90, 0.91-1.10, 1.11-1.40, >1.40
Fowkes, 2014^66^ | Model development: FRS variables | ABI Collaboration IPD MA | x | x | | x | x^†^ | | x | x | | x | Hard CHD: 2950 (6.6)^§^ | Categorical: ≥0.90, 0.91-1.10, 1.11-1.40, >1.40
Holewijn, 2014^95^ | Model development: FRS variables | Nijmegen Biomedical Study | x | x | | x | x | | | | x | | Soft CVD: 71 (5.7) | Categorical: ≥0.9, >0.9 (>1.4 excluded)
Yeboah, 2012^75,††^ | Model development: FRS variables | MESA | x | x | x | x | x | x | x | x | | | Soft CVD: 123 (9.2) Soft CHD: 94 (7.1) | Continuous
Kavousi, 2012^82,††^ | Model development: FRS variables | Rotterdam | x | x | | x | x | x | x | x | | x | Hard CHD: 347 (5.8) | Categorical: ≥0.9, >0.9 (>1.4 excluded)
Murphy, 2012^79^ | Model development: FRS variables | ARIC | x | x | x | x | x | x | | x^¶^ | | | Hard CVD: 659 (5.7) Hard CHD: 403 (3.5) | Continuous^#^
Rodondi, 2010^81,**^ | Model development: FRS variables | Health ABC | x | x | | x | x | x | x | x | | x | Hard CHD: 197 (9.0) Soft CHD: 351 (16.0) | Categorical: ≥0.9, 0.91-1.00, 1.01-1.30, 1.31-1.40, >1.4
Price, 2007^80^ | Model development: FRS variables | EAS | x | x | | x | x | | | | x | x | Hard CVD: 137 (13.6) Soft CVD: 249 (24.7) | Continuous (ABI >1.5 excluded)

† BP categories as defined in JNC-V; includes DBP

‡ This outcome only reported for published coefficient model, not the newly developed model

§ For development and validation datasets

ǁ Recalibration applies only to published coefficient models, not model development studies

¶ Also included LDL

# C-statistics measured with continuous ABI, but categorical ABI is reported for “2-step” risk assessment analysis which reports sensitivity, specificity, PPV, etc.

** Also a study of CRP

†† Also a study of CRP and CAC

‡‡ Recalibrated by including the PCE in the Cox model predicting Hard CVD and used baseline survival estimated from MESA data; similar procedure used for FRS model predicting hard CHD events

§§ Recalibrated by replacing Framingham means of risk factors and average event rate with those of Girona population (Marrugat, 2003).

ǁ ǁ Hard CVD defined as fatal or nonfatal MI or CVA or CVD mortality; hard CHD defined as fatal or nonfatal MI or CHD mortality; soft CVD could additionally include angina, revascularization, TIA or claudication in composites defined by the study. Similarly, hard CHD could additionally include angina or coronary revascularization in composites defined by the study.

Abbreviations: ABI = ankle-brachial index; BP = blood pressure; CAC = coronary artery calcium; CHD = coronary heart disease; CRP = C-reactive protein; CVD = cardiovascular disease; DBP = diastolic blood pressure; DM = diabetes mellitus; EAS = Edinburgh Artery Study; FRS=Framingham Risk Score; HDL = high-density lipoprotein; Health ABC = Health, Aging, and Body Composition study; HTN = hypertension; IPD MA = individual participant data meta-analyses; JNC-V = the fifth Joint National Committee; LDL = low-density lipoprotein; MESA = Multi-Ethnic Study of Atherosclerosis; NR = not reported; PCE = Pooled Cohort Equations; PPV = positive predictive value; SBP = systolic blood pressure; TC = total cholesterol; Tx = treatment

In general, study cohorts were sufficiently large (adequate number of outcome events accrued) and representative of the general population for whom CVD risk assessment would be applicable. Analyzed cohorts range from approximately 1,000 to 11,000 people; the ABI Collaboration IPD meta-analysis includes over 44,000 individuals. Studies have a median of at least 5 years of followup, except the Nijmegen Biomedical Study (n=1,242), which has both short followup (3.8 years) and fewer than 100 outcome events observed.^95^ Cohorts include a mix of men and women, with a mean age ranging from 53.7 to 73.5 years. The ARIC cohort analysis excluded individuals with known diabetes.^79^ Only MESA, ARIC, and the Health, Aging, and Body Composition Study (Health ABC), all conducted in the United States, reported any racial/ethnic diversity.^79,^ ^81,^ ^90^ All of the cohorts except Nijmegen and ARIC included diabetes as a variable in the risk prediction model.^95^ Only MESA and ARIC included race/ethnicity as a variable in the risk prediction model.^79,^ ^90^ In the most recent analyses from the MESA cohort, people already taking statins (approximately a quarter of the population) were removed from the analysis.^90^

Most studies reported excluding or are assumed to have excluded people with missing data (e.g., for ABI or other CVD risk factors). Five studies handled ABI as a categorical variable in the model, four studies handled ABI continuously, and one study evaluated ABI both categorically and continuously. When ABI was handled categorically, a threshold of ≤0.9 was considered abnormal. Treatment of continuous risk predictors as dichotomous or categorical variables results in loss of statistical power. However, because ABI has a well-established cut-point in clinical practice, treating it as a categorical variable is a pragmatic approach; preserving the continuous form (including more complex nonlinear relations) addresses a more explanatory question.^126^

Most studies were fair quality. Limitations of included studies are described above. Fair-quality, as opposed to good-quality, studies had less than 10 years of followup to predict 10-year CHD or CVD risk, had fewer than 20 outcome events per variable, did not report any calibration or goodness-of-fit measures, and/or did not report confidence intervals or statistical significance of changes in measures of discrimination or risk reclassification; additionally, published coefficient models did not conduct recalibration. The IPD meta-analysis by the ABI Collaboration was a well-conducted analysis and represents the best evidence to address this key question; however, it was rated as fair quality because many of the cohorts had less than 10 years of followup and the model was not recalibrated to the population analyzed which may result in overly optimistic results.

#### Model Performance (Calibration, Discrimination, Risk Reclassification)

For model performance, we will first discuss results of calibration, then discrimination, and finally risk reclassification. Of the 10 studies (22 cohorts) included, 5 articles (20 cohorts) reported some measure of calibration, all articles and cohorts reported discrimination, and 9 articles (22 cohorts) reported risk reclassification (Table 9). To guide the reader, each section is formatted similarly with a discussion of results from models using the published coefficients first, then model development studies. Because this body of evidence includes a single, large IPD meta-analysis from the ABI Collaboration, which includes 18 different cohorts, we discuss findings from the ABI Collaboration as the central piece of evidence, and discuss other studies of individual cohorts in relation to the ABI Collaboration findings if these studies provide additional insight.

##### Calibration

In general, we have very limited information to assess the change in calibration from the addition of ABI to a base model consisting of the FRS or PCE, or a model using similar traditional risk factors (Table 14). None of the included studies reported graphical measures of calibration. Five of the 10 studies reported the Hosmer-Lemeshow test or measures of overall performance, which are integrated measures of both calibration and discrimination.^66,^ ^95^ None of the included studies reported the O:E ratio or provided sufficient data for us to calculate the change in O:E ratio. From limited reported data on calibration, it appears ABI can improve upon the calibration of the FRS. The only study using the PCE as the base model did not report on calibration.^90^

Table 14 Calibration and Overall Performance Measures in Included ABI Risk Prediction Studies (KQ2)

Measure | Author, Year | Model type: Base model | Study name | N | Outcome^‡^ | Subgroup | Base model | Base model P-Value | Extended model | Extended model P-Value | Between model P-Value | Calculated change between models
AIC | Fowkes, 2014^66^ | Published coefficient: FRS | ABI Collaboration | 5,869 | Hard CHD | Women^†^ | 6689.92 | -- | 6662.06 | -- | -- | -27.86
AIC | Fowkes, 2014^66^ | Published coefficient: FRS | ABI Collaboration | 5,632 | Hard CHD | Men^†^ | 9541.82 | -- | 9521 | -- | -- | -20.82
AIC | Velescu, 2015^91^ | Published coefficient: FRS | REGICOR | 5,248 | Soft CVD | All Participants | 2571 | -- | 2562.2 | -- | -- | -8.8
AIC | Velescu, 2015^91^ | Published coefficiens: FRS | REGICOR | 5,248 | Soft CHD | All Participants | 1653 | -- | 1650.2 | -- | -- | -2.8
AIC | Rodondi, 2010^81^ | Model development: FRS variables | Health ABC | 1,515 | Hard CHD | All Participants | 1796.7 | -- | 1795.6 | -- | -- | -1.1
AIC | Rodondi, 2010^81^ | Model development: FRS variables | Health ABC | 1,515 | Soft CHD | All Participants | 3102.6 | -- | 3100.2 | -- | -- | -2.4
BIC | Fowkes, 2014^66^ | Published coefficient: FRS | ABI Collaboration | 5,869 | Hard CHD | Women^†^ | 6693.93 | -- | 6678.09 | -- | -- | -15.84
BIC | Fowkes, 2014^66^ | Published coefficient: FRS | ABI Collaboration | 5,632 | Hard CHD | Men^†^ | 9546.22 | -- | 9538.61 | - | - | -7.61
BIC | Rodondi, 2010^81^ | Model development: FRS variables | Health ABC | 1,515 | Hard CHD | All Participants | 1839.3 | -- | 1859.5 | -- | -- | 20.2
BIC | Rodondi, 2010^81^ | Model development: FRS variables | Health ABC | 1,515 | Soft CHD | All Participants | 3145.2 | -- | 3164.1 | -- | -- | 18.9
Hosmer- Lemeshow test | Rodondi, 2010^81^ | Model development: FRS variables | Health ABC | 1,515 | Hard CHD | All Participants | 4.8 | 0.85 | 10.64 | 0.3 | -- | 5.84
Hosmer- Lemeshow test | Holewijn, 2014^95^ | Model development: FRS variables | Nijmegen Biomedical Study | 659 | Soft CVD | Women | 9.26 | 0.321 | 14.75 | 0.064 | -- | 5.49
Hosmer- Lemeshow test | Holewijn, 2014^95^ | Model development: FRS variables | Nijmegen Biomedical Study^*^ | 582 | Soft CVD | Men | 7.08 | 0.528 | NR | NR | -- | --
Hosmer- Lemeshow test | Rodondi, 2010^81^ | Model development: FRS variables | Health ABC | 1,515 | Soft CHD | All Participants | 4.23 | 0.9 | 15.01 | 0.09 | -- | 10.78
Likelihood ratio X^2^ | Rodondi, 2010^81^ | Model development: FRS variables | Health ABC | 1,515 | Hard CHD | All Participants | 27.48 | <0.001 | 36.56 | <0.001 | NR | 9.08
Likelihood ratio X^2^ | Kavousi, 2012^82^ | Model development: FRS variables | Rotterdam | 5,933 | Hard CHD | All Participants | 230.49 | NR | 3.7 | NR | <0.05 | -226.79
Likelihood ratio X^2^ | Kavousi, 2012^82^ | Model development: FRS variables | Rotterdam | 3,525 | Hard CHD | Women | NR | NR | 0.1 | NR | >0.05 | --
Likelihood ratio X^2^ | Kavousi, 2012^82^ | Model development: FRS variables | Rotterdam | 2,408 | Hard CHD | Men | NR | NR | 5.6 | NR | <0.05 | --
Likelihood ratio X^2^ | Holewijn, 2014^95^ | Model development: FRS variables | Nijmegen Biomedical Study | 659 | Soft CVD | Women | 15.81 | 0.003 | 24.55 | <0.001 | NR | 8.74
Likelihood ratio X^2^ | Holewijn, 2014^95^ | Model development: FRS variables | Nijmegen Biomedical Study^*^ | 582 | Soft CVD | Men | 35.85 | <0.001 | NR | NR | NR | --
Likelihood ratio X^2^ | Rodondi, 2010^81^ | Model development: FRS variables | Health ABC | 1,515 | Soft CHD | All Participants | 35.31 | <0.001 | 45.8 | <0.001 | NR | 10.49
R^2^ | Holewijn, 2014^95^ | Model development: FRS variables | Nijmegen Biomedical Study | 659 | Soft CVD | Women | 6.2 | -- | 9.6 | -- | -- | 3.4
R^2^ | Holewijn, 2014^95^ | Model development: FRS variables | Nijmegen Biomedical Study^*^ | 582 | Soft CVD | Men | 12.5 | -- | NR | -- | -- | --
R^2^ | Fowkes, 2014^66^ | Published coefficient: FRS | ABI Collaboration | 5,869 | Hard CHD | Women^†^ | 0.0353 | -- | 0.0475 | -- | -- | 0.0122
R^2^ | Fowkes, 2014^66^ | Published coefficient: FRS | ABI Collaboration | 5,632 | Hard CHD | Men^†^ | 0.1138 | -- | 0.1241 | -- | -- | 0.0103

* Extended model risk prediction statistics NR for men because HR analysis showed that ABI had no significant additional predictive value on top of traditional cardiovascular risk factors.

† Development Dataset

‡ Hard CVD defined as fatal or nonfatal MI or CVA or CVD mortality; hard CHD defined as fatal or no nfatal MI or CHD mortality; soft CVD could additionally include angina, revascularization, TIA or claudication in composites defined by the study. Similarly, hard CHD could additionally include angina or coronary revascularization in composites defined by the study.

Abbreviations: ABI = ankle-brachial index; AIC = Akaike information criterion; BIC = Bayesian information criterion; CHD = coronary heart disease; CVD = cardiovascular disease; FRS=Framingham Risk Score; Health ABC = Health, Aging, and Body Composition study; HR = hazard ratio; NR = not reported; REGICOR = Registre Gironí del Cor (Girona Heart Registry)

Published coefficient models. The ABI Collaboration, which used published coefficients, reported the overall performance measures of R^2^, Akaike information criterion (AIC), and Bayes information criterion (BIC). All three measures suggest that the ABI can improve the overall performance of the FRS in both men and women (Table 14). Reductions in AIC greater than 10 indicate important differences in model fit;^84^ however, the clinical importance of these changes is uncertain. The REGICOR study, not included in the ABI Collaboration, which also used published coefficients of the FRS, only reported the AIC and found improvements in all participants (sex-specific analyses not reported) to predict both soft CHD and CVD outcomes, in contrast to hard CHD outcomes in the ABI Collaboration.

Model development. Three model development studies, one cohort of which was not included in the ABI Collaboration, reported some measure of calibration or overall performance. The Nijmegen Biomedical Study, not included in the ABI Collaboration, had a total of only 71 soft CVD events over an average of 3.8 years.^95^ While the Hosmer-Lemeshow test suggests a decrement in calibration by adding the ABI to FRS variables in women, this is likely a result of sparse data bias.^127^ In addition, the R^2^ statistic for this same comparison in women suggests an improvement in calibration and discrimination with the addition of ABI to a base model including FRS variables. Overall, the BIC and Hosmer-Lemeshow test in the Health ABC study do not suggest an improvement with the addition of ABI to an FRS base model to predict hard CHD outcomes. The Rotterdam study conducted sex-specific analyses and demonstrated that while the addition of ABI to a base model of FRS variables improved the overall model performance for predicting hard CHD outcomes, as measured by the likelihood ratio test, this appears to be true for men but not women. Since this is an integrated measure, we cannot determine whether calibration, discrimination, or both are improved in the absence of other measures, which are not reported.

##### Discrimination

All of the included studies reported measures of discrimination (i.e., AUC, c-statistic) by adding ABI to traditional cardiovascular risk assessment (Table 15). Only one study evaluated the addition of ABI to the PCE and this study did not show improved discrimination;^90^ however, this cohort excluded people already taking statins, and over 80 percent of the population had 10-year hard CVD risk of 7.5 percent or less. Additionally, this analysis recalibrated the PCE to the MESA population which would render a conservative estimate of change in discrimination in the extended model. The IPD meta-analysis by the ABI Collaboration demonstrated that improvement in discrimination with the addition of ABI was higher for women than for men. This difference between men and women is likely due to the poorer performance of the FRS in women compared to men. Studies in cohorts not represented in the IPD meta-analyses mostly do not present sex-stratified analyses. In the one study not included in the ABI Collaboration that reported sex-stratified analyses, the Nijmegen Biomedical cohort, findings of improvement in discrimination for women were not statistically significant, likely owing to lack of power.

Table 15 Discrimination Outcomes in Included ABI Risk Prediction Studies (KQ2)

Model type: Base model | Author, Year | Study name | Outcome^§§^ | Subgroup | N | Base model c-statistic (95% CI) | Extended model c-statistic (95% CI) | Change in discrimination (95% CI)^*^ | Change P-Value
Published coefficient: PCE | Yeboah, 2016^90^ | MESA ^ǁ^ | Hard CVD | All Participants | 5,185 | 0.74 (NR to NR) | 0.75 (NR to NR) | 0.01 (NR to NR) | 0.55
Published coefficient: FRS | Geisel, 2017^114^ | HNR | Hard CVD | All Participants | 3,108 | 0.693 (0.661 to 0.726) | 0.687 (0.653 to 0.721) | -0.006 (NR to NR) | 0.54
Published coefficient: FRS | Geisel, 2017^114^ | HNR | Hard CVD | Low risk | 1,694 | 0.658 (0.602 to 0.713) | 0.666 (0.608 to 0.724) | 0.008 (NR to NR) | 0.45
Published coefficient: FRS | Geisel, 2017^114^ | HNR | Hard CVD | Intermediate risk | 1,022 | 0.575 (0.520 to 0.629) | 0.596 (0.541 to 0.651) | 0.021 (NR to NR) | 0.32
Published coefficient: FRS | Geisel, 2017^114^ | HNR | Hard CVD | High risk | 392 | 0.556 (0.482 to 0.629) | 0.608 (0.521 to 0.694) | 0.052 (NR to NR) | 0.28
Published coefficient: FRS | Fowkes, 2014^66^ | ABI Collaboration | Hard CHD | Women^¶^ | 5,869 | 0.661 (0.587 to 0.728) | 0.681 (0.607 to 0.746) | 0.02 (NR to NR) | NR
Published coefficient: FRS | Fowkes, 2014^66^ | ABI Collaboration | Hard CHD | Women^#^ | 6,459 | 0.578 (0.492 to 0.661) | 0.69 (0.605 to 0.764) | 0.112 (NR to NR) | NR
Published coefficient: FRS | Fowkes, 2014^66^ | ABI Collaboration | Hard CHD | Women^**^ | 5,872 | 0.676 (0.599 to 0.745) | 0.71 (0.633 to 0.775) | 0.034 (NR to NR) | NR
Published coefficient: FRS | Fowkes, 2014^66^ | ABI Collaboration | Hard CHD | Men^¶^ | 5,632 | 0.715 (0.655 to 0.768) | 0.721 (0.661 to 0.773) | 0.006 (NR to NR) | NR
Published coefficient: FRS | Fowkes, 2014^66^ | ABI Collaboration | Hard CHD | Men^#^ | 4,962 | 0.672 (0.599 to 0.737) | 0.685 (0.612 to 0.749) | 0.013 (NR to NR) | NR
Published coefficient: FRS | Fowkes, 2014^66^ | ABI Collaboration | Hard CHD | Men^**^ | 5,638 | 0.721 (0.664 to 0.722) | 0.721 (0.664 to 0.722) | 0 (NR to NR) | NR
Published coefficient: FRS | Yeboah, 2016^90^ | MESA ^ǁ^ | Hard CHD | All Participants | 5,185 | 0.74 (NR to NR) | 0.75 (NR to NR) | 0.01 (NR to NR) | 0.042
Published coefficient: FRS | Velescu, 2015^91^ | REGCOR^††^ | Soft CVD | All Participants | 5,248 | 0.787 (NR to NR) | 0.795 (NR to NR) | 0.008^*^ (0.001^*^ to 0.017^*^) | 0.049^*^
Published coefficient: FRS | Velescu, 2015^91^ | REGICOR^††^ | Soft CHD | All Participants | 5,248 | 0.795 (NR to NR) | 0.797 (NR to NR) | 0.002^*^ (-0.001^*^ to 0.007^*^) | 0.529^*^
Model development: FRS variables | Murphy, 2012^79^ | ARIC | Hard CVD | All Participants | 11,594 | 0.756 (0.739 to 0.773)^†^ | 0.758 (0.741 to 0.775) | 0.002 (NR to NR) | 0.23
Model development: FRS variables | Price, 2007^80^ | EAS | Hard CVD | All Participants | 1,007 | 0.614 (0.56 to 0.67) | 0.64 (0.59 to 0.69) | 0.026 (NR to NR) | 0.02
Model development: FRS variables | Fowkes, 2014^66^ | ABI Collaboration | Hard CHD | Women^#^ | 6,459 | 0.788 (0.709 to 0.85) | 0.791 (0.712 to 0.852) | 0.003 (NR to NR) | NR
Model development: FRS variables | Fowkes, 2014^66^ | ABI Collaboration | Hard CHD | Men^#^ | 4,962 | 0.683 (0.611 to 0.748) | 0.69 (0.618 to 0.754) | 0.007 (NR to NR) | NR
Model development: FRS variables | Murphy, 2012^79^ | ARIC | Hard CHD | All Participants | 11,594 | NR | NR | NR | NS
Model development: FRS variables | Rodondi, 2010^81^ | Health ABC | Hard CHD | All Participants | 1,515 | 0.6 (NR to NR) | 0.612 (NR to NR) | 0.012 (NR to NR) | NR
Model development: FRS variables | Kavousi, 2012^82^ | Rotterdam | Hard CHD | All Participants | 5,933 | 0.73 (0.71 to 0.75) | NR | 0.00^*^ (0.00^*^ to 0.00^*^) | NR
Model development: FRS variables | Kavousi, 2012^82^ | Rotterdam | Hard CHD | Women | 3,525 | NR | NR | 0.00^*^ (0.00^*^ to 0.00^*^) | NR
Model development: FRS variables | Kavousi, 2012^82^ | Rotterdam | Hard CHD | Men | 2,408 | NR | NR | 0.010^*^ (0.00^*^ to 0.01^*^) | NR
Model development: FRS variables | Yeboah, 2012^75^ | MESA | Soft CVD | Intermediate risk | 1,330 | 0.623 (NR to NR) | 0.65 (NR to NR) | 0.027 (NR to NR) | 0.01
Model development: FRS variables | Holewijn, 2014^95^ | Nijmegen Biomedical Study | Soft CVD | Women | 659 | 0.691 (NR to NR) | 0.726 (NR to NR) | 0.036^*^ (NR to NR) | 0.26^*^
Model development: FRS variables | Holewijn, 2014^95^ | Nijmegen Biomedical Study | Soft CVD | Men | 582 | 0.748 (NR to NR) | NR (NR to NR) | NR (NR to NR)^§^ | NR
Model development: FRS variables | Rodondi, 2010^81^ | Health ABC | Soft CHD | All Participants | 1,515 | 0.611 (NR to NR) | 0.624 (NR to NR) | 0.013 (NR to NR) | NR
Model development: FRS variables | Yeboah, 2012^75^ | MESA | Soft CHD | Intermediate risk | 1,330 | 0.623 (NR to NR) | 0.65 (NR to NR) | 0.027 (NR to NR) | 0.01

* Calculated as Extended-Base except where noted; asterisk indicates reported (not calculated) change

† Sensitivity, specificity, also reported for use of FRS alone and a two-step risk assessment where those with ABI <0.9 and who are in the intermediate FRS group ‘move up.’

§ Extended model AUC NR because HR analysis showed that ABI had no significant additional predictive value on top of traditional cardiovascular risk factors.

ǁ Recalibrated by including the PCE in the Cox model predicting Hard CVD and used baseline survival estimated from MESA data; similar procedure used for FRS model predicting hard CHD events

¶ Development dataset

# External validation dataset

** Internal validation dataset

†† Recalibrated by replacing Framingham means of risk factors and average event rate with those of Girona population (Marrugat, 2003)^160^.

§§ Hard CVD defined as fatal or nonfatal MI or CVA or CVD mortality; hard CHD defined as fatal or nonfatal MI or CHD mortality; soft CVD could additionally include angina, revascularization, TIA or claudication in composites defined by the study. Similarly, hard CHD could additionally include angina or coronary revascularization in composites defined by the study.

Abbreviations: ABI = ankle-brachial index; CHD = coronary heart disease; CI = confidence interval; CVD = cardiovascular disease; EAS = Edinburgh Artery Study; FRS=Framingham Risk Score; Health ABC = Health, Aging, and Body Composition study; MESA = Multi-Ethnic Study of Atherosclerosis; NR = not reported; NRI = net reclassification improvement; NS = not significant; PCE = Pooled Cohort Equations; REGICOR = Registre Gironí del Cor (Girona Heart Registry)

Published coefficient models. The ABI Collaboration, which used published coefficients for the FRS, presented only sex-stratified analyses, and the base model discrimination was lower in women (0.578) than in men (0.672).^66^ This study demonstrated a large improvement in discrimination with the addition of ABI in women (but not men) to predict hard CHD outcomes (0.112); although statistical significance is not reported, the 95% CI of the base model does not include the point estimate of the extended model (however, 95% CI of base and extended models do overlap). MESA, REGICOR, and Heinz Nixdorf Recall did not report discrimination separately for men and women; the overall change in discrimination in these three studies was very small (-0.006 to 0.01), with borderline or no statistical significance.^90,^ ^91,^ ^114^ One study, conducted in the MESA cohort, reported a base model discrimination of 0.74 for both the PCE and FRS. This study demonstrated a very small improvement in discrimination with the addition of ABI to the FRS to predict hard CHD outcomes (0.010, p=0.042); in contrast, results were not statistically significant with the addition of ABI to the PCE to predict hard CVD outcomes (0.010, p=0.55). In one study, REGICOR, the base model discrimination for the FRS was good (0.787 for soft CVD, 0.795 for soft CHD), such that there was only very small improvement in discrimination with the addition of ABI to predict soft CVD (0.008, p=0.049) but not soft CHD outcomes.

Model development. The ABI Collaboration also conducted model development analyses. For these sex-stratified analyses, the discrimination for the base model was higher than analyses using published coefficients, and higher in women (0.788) than in men (0.683). In these analyses, the incremental benefit of adding ABI to FRS variables to predict hard CHD outcomes is very small (0.003 for women and 0.007 for men); although statistical significance is not reported, the 95% CI of the base model includes the point estimates for the extended models. Results from individual model development studies of cohorts included in the ABI Collaboration (ARIC, EAS, Rotterdam, and Health ABC) were consistent with the ABI Collaboration’s findings of very small to small improvements in discrimination.^79-82^ The Nijmegen Biomedical Study, not included in the ABI Collaboration, had both limited followup and a limited number of soft CVD events.^95^ Sex-stratified analyses showed lower base model discrimination in women (0.691) than in men (0.748). This study reported a small but not statistically significant improvement in discrimination in women (0.036, p=0.26) but not men (data NR). An analysis of the MESA cohort, also not included in the ABI Collaboration and restricted to intermediate-risk people (5-20% 10-year risk of soft CVD outcomes), found a small improvement (0.027, p=0.01).

##### Risk Reclassification

All but one of the included studies reported NRI plus or minus IDI (Table 16; Appendix E Table 1). Studies used different definitions of low, intermediate, and high CHD or CVD risk categories and one study reported a continuous NRI.^114^ Overall, and based primarily on the ABI Collaboration IPD meta-analysis, the addition of the ABI to the FRS can improve reclassification; NRI are at best less than 0.1 and are usually much smaller and often nonsignificant. Consistent with findings on changes in discrimination, the effect of ABI on reclassification appears to be larger for women than men. However, the nonevent NRI in women was negative, suggesting incorrect upward reclassification of risk in women who did not have a CHD event. Considering that the vast majority of women did not have events (92.9%), the overall NRI measure may overstate the improvement in reclassification.^67^ Based on data from a single cohort (MESA) using a PCE base model, ABI does not appear to result in statistically significant change in reclassification to detect hard CVD outcomes in people not already taking statins. Four studies, including the ABI Collaboration, allow for bias-corrected calculation of NRI for the intermediate-risk group. The most promising results appear to be for adding ABI in women at intermediate risk for developing hard CHD events (10-19% over 10 years).

Table 16 Reclassification Outcomes in Included ABI Risk Prediction Studies (KQ2)

Model type: Base model | Author, Year | Study name | N | Outcome ¶¶ | Subgroup | Total NR (95% CI) | Event NR (95% CI) | Nonevent NRI (95% CI) | Risk categories (High, Intermediate, Low) 10-yr risk
Published coefficient: PCE | Yeboah, 2016^90^ | MESA | 5,185 | Hard CVD | All Participants | 0.017 (-0.031 to 0.058)^*^ | 0.013 (-0.034 to 0.051)^*^ | 0.004 (-0.004 to 0.011)^*^ | ≥7.5%, <7.5%
Published coefficient: FRS | Geisel, 2017^114^ | HNR | 3,108 | Hard CVD | All Participants | 0.190 (0.102 to 0.278) | NR | NR | Continuous NRI used
Published coefficient: FRS | Geisel, 2017^114^ | HNR | 1,694 | Hard CVD | Low risk (<10% FRS) | 0.041 (-0.062 to 0.144) | NR | NR | Continuous NRI used
Published coefficient: FRS | Geisel, 2017^114^ | HNR | 1,022 | Hard CVD | Intermediate risk (10-20% FRS) | 0.129 (0.014 to 0.245) | NR | NR | Continuous NRI used
Published coefficient: FRS | Geisel, 2017^114^ | HNR | 392 | Hard CVD | High risk (>20% FRS) | 0.455 (0.212 to 0.698) | NR | NR | Continuous NRI used
Published coefficient: FRS | Fowkes, 2014^66^ | ABI Collaboration^‡^ | 6,459 | Hard CHD | Women | 0.096 (0.061 to 0.164)^§,#^ | 0.145 (0.101 to 0.189)^§^ | -0.051 (-0.059 to -0.043)^§^ | ≥20%, 10-19%, <10%
Published coefficient: FRS | Fowkes, 2014^66^ | ABI Collaboration^‡^ | 552 | Hard CHD | Women, Intermediate Risk | 0.288 (0.064 to 0.513)^†,#^ǁ ǁ | NR | NR | ≥20%, 10-19%, <10%
Published coefficient: FRS | Fowkes, 2014^66^ | ABI Collaboration^‡^ | 4,962 | Hard CHD | Men | 0.043 (0.008 to 0.076)^§,**^ | 0.026 (-0.005 to 0.058)^§^ | 0.016 (0.004 to 0.027)^§^ | ≥20%, 10-19%, <10%
Published coefficient: FRS | Fowkes, 2014^66^ | ABI Collaboration^‡^ | 1,851 | Hard CHD | Men, Intermediate Risk | 0.051 (-0.016 to 0.119)^†^ ††ǁǁ | NR | NR | ≥20%, 10-19%, <10%
Published coefficient: FRS | Yeboah, 2016^90^ | MESA | 5,185 | Hard CHD | All Participants | 0.039 (-0.011 to 0.109) | 0.041 (-0.01 to 0.108) | -0.003 (-0.008 to 0.004) | ≥20%, 10-20%, <10%
Published coefficient: FRS | Yeboah, 2016^90^ | MESA | 201 | Hard CHD | Intermediate Risk | 0.11 (-0.138 to 0.357)^†^ | NR | NR | >20%, 10-20%, <10%
Published coefficient: FRS | Velescu, 2015^91^ | REGICOR | 5,182 | Soft CVD | All Participants | 0.029 (0.014 to 0.045) | 0.006 (-0.007 to 0.022) | 0.023 (0.017 to 0.029) | ≥10%, 5-10%, 0-5%
Published coefficient: FRS | Velescu, 2015^91^ | REGICOR | 1,201 | Soft CVD | Intermediate Risk | 0.061 (0.024 to 0.098)^†^ | NR | NR | ≥10%, 5-10%, 0-5%
Published coefficient: FRS | Velescu, 2015^91^ | REGICOR | 5,182 | Soft CHD | All Participants | 0.001 (-0.06 to 0.058) | -0.01 (-0.07 to 0.045) | 0.011 (0.007 to 0.017) | ≥10%, 5-10%, 0-5%
Published coefficient: FRS | Velescu, 2015^91^ | REGICOR | 935 | Soft CHD | Intermediate Risk | 0.021 (-0.061 to 0.103)^†^ | NR | NR | ≥10%, 5-10%, 0-5%
Model development: FRS variables | Murphy, 2012^79^ | ARIC | 11,594 | Hard CVD | All Participants | 0.008 (-0.015 to 0.03) | 0.003 (-0.019 to 0.025)1 | 0.005 (0 to 0.009)ǁ | ≥20%, ≥6% to <19%, <6%
Model development: FRS variables | Murphy, 2012^79^ | ARIC | 3,376 | Hard CVD | Intermediate Risk | 0.011 (-0.021 to 0.042)^†^ | NR | NR | ≥20%, ≥6% to <19%, <6%
Model development: FRS variables | Fowkes, 2014^66^ | ABI Collaboration^§^ | 6,459 | Hard CHD | Women | 0.011 (-0.019 to 0.04)^§^ | NR | NR | ≥20%, 10-19%, <10%
Model development: FRS variables | Fowkes, 2014^66^ | ABI Collaboration^‡^ | 552 | Hard CHD | Women, Intermediate Risk | 0.024 (-0.03 to 0.105)^§^ | NR | NR | ≥20%, 10-19%, <10%
Model development: FRS variables | Fowkes, 2014^66^ | ABI Collaboration^‡^ | 4,962 | Hard CHD | Men | 0.02 (-0.023 to 0.042)^§^ | NR | NR | ≥20%, 10-19%, <10%
Model development: FRS variables | Fowkes, 2014^66^ | ABI Collaboration^‡^ | 1,851 | Hard CHD | Men, Intermediate Risk | 0.077 (0 to 0.13)^§^ | NR | NR | ≥20%, 10-19%, <10%
Model development: FRS variables | Rodondi, 2010^81^ | Health ABC | 1,985 | Hard CHD | All Participants | 0.079 (NR to NR) | NR | NR | ≥15%, 7.5 to <15%, <7.5%^‡‡^
Model development: FRS variables | Rodondi, 2010^81^ | Health ABC | 1,020 | Hard CHD | Intermediate Risk | 0.193 (NR to NR) | NR | NR | ≥15%, 7.5 to <15%, <7.5%^‡‡^
Model development: FRS variables | Kavousi, 2012^82^ | Rotterdam | 5,933 | Hard CHD | All Participants | 0.006 (-0.018 to 0.029) | NR | NR | ≥20%, 10-20%, <10%
Model development: FRS variables | Kavousi, 2012^82^ | Rotterdam | NR | Hard CHD | Intermediate Risk | 0.073 (0.029 to 0.117) | 0.047 (NR to NR) | 0.026 (NR to NR) | >20%, 10-20%, <10%
Model development: FRS variables | Kavousi, 2012^82^ | Rotterdam | 3,525 | Hard CHD | Women | -0.009 (-0.027 to 0.01) | NR | NR | >20%, 10-20%, <10%
Model development: FRS variables | Kavousi, 2012^82^ | Rotterdam | NR | Hard CHD | Women, Intermediate Risk | -0.012 (-0.042 to 0.017) | -0.016 (NR to NR) | 0.004 (NR to NR) | >20%, 10-20%, <10%
Model development: FRS variables | Kavousi, 2012^82^ | Rotterdam | 2,408 | Hard CHD | Men | -0.016 (-0.065 to 0.033) | NR | NR | >20%, 10-20%, <10%
Model development: FRS variables | Kavousi, 2012^82^ | Rotterdam | NR | Hard CHD | Men, Intermediate Risk | 0.065 (-0.011 to 0.141) | 0.046 (NR to NR) | 0.019 (NR to NR) | >20%, 10-20%, <10%
Model development: FRS variables | Yeboah, 2012^75^ | MESA | 1,330 | Soft CVD | Intermediate Risk | 0.068 (NR to NR) | 0.041 (NR to NR) | 0.027 (NR to NR) | <3.4%, 3.4 to 21.1%, >21.1%^‡‡^
Model development: FRS variables | Holewijn, 2014^95^ | Nijmegen Biomedical Study | 659 | Soft CVD | Women | 0.159 (NR to NR) p= 0.056 | NR | NR | ≥20%, 10-20%, <10%§§
Model development: FRS variables | Holewijn, 2014^95^ | Nijmegen Biomedical Study | NR | Soft CVD | Women, Intermediate Risk | 0.60 (NR to NR) | NR | NR | ≥20%, 10-20%, <10%^§§^
Model development: FRS variables | Holewijn, 2014^95^ | Nijmegen Biomedical Study | 582 | Soft CVD | Men | -0.011 (NR to NR) p=0.686 | NR | NR | ≥20%, 10-20%, <10%^§§^
Model development: FRS variables | Holewijn, 2014^95^ | Nijmegen Biomedical Study | NR | Soft CVD | Men, Intermediate Risk | 0.136 (NR to NR) | NR | NR | ≥20%, 10-20%, <10%^§§^
Model development: FRS variables | Rodondi, 2010^81^ | Health ABC | 1,985 | Soft CHD | All Participants | 0.033 (0.0004 to 0.065) | 0.022 (NR to NR) | 0.01 (NR to NR) | ≥15%, 7.5 to <15%, <7.5%^‡‡^
Model development: FRS variables | Rodondi, 2010^81^ | Health ABC | 1,020 | Soft CHD | Intermediate Risk | 0.038 (-0.028 to 0.104)^†^ | NR | NR | ≥15%, 7.5 to <15%, <7.5%^‡‡^
Model development: FRS variables | Yeboah, 2012^75^ | MESA | 1,330 | Soft CHD | Intermediate Risk | 0.036 (NR to NR) | 0.021 (NR to NR) | 0.015 (NR to NR) | <2.0%, 2.0 to 15.4%, >15.4%^‡‡^

* Sensitivity analysis using 3 categories (0-5%, 5-7.5%, >7.5%) produced similar results

† Bias-corrected NRIint calculated using simple variance method

‡ All reclassification analyses conducted in external validation datasets

§ Calculated using Kaplan-Meier estimates reported in study.

ǁ Event and nonevent NRI calculated using simple variance method

¶ Sensitivity analyses using wider intermediate risk group of 5-19% showed NRI of 0.204 (0.116 to 0.225; p<0.001)

# Sensitivity analyses using wider intermediate risk group of 5-19% showed NRI of 0.130 (0.073 to 0.179; p<0.001).

** Sensitivity analyses using wider intermediate risk group of 5-19% showed NRI of 0.031 (0.006 to 0.064; p=0.018).

†† Sensitivity analyses using wider intermediate risk group of 5-19% showed NRI of 0.079 (0.037 to 0.115; p<0.001).

‡‡ 7.5-yr risk

§§ Time horizon NR

ǁǁ Calculated from Kaplan-Meier estimates

¶¶ Hard CVD defined as fatal or nonfatal MI or CVA or CVD mortality; hard CHD defined as fatal or nonfatal MI or CHD mortality; soft CVD could additionally include angina, revascularization, TIA or claudication in composites defined by the study. Similarly, hard CHD could additionally include angina or coronary revascularization in composites defined by the study.

Abbreviations: ABI = ankle-brachial index; AIC = Akaike information criterion; BIC = Bayesian information criterion; CHD = coronary heart disease; CVD = cardiovascular disease; FRS=Framingham Risk Score; Health ABC = Health, Aging, and Body Composition study; HR = hazard ratio; NR = not reported; REGICOR = Registre Gironí del Cor (Girona Heart Registry)

Published coefficient models. The ABI Collaboration, using published coefficients for the FRS, demonstrated an improvement in reclassification with the addition of ABI in women to predict hard CHD outcomes, but not in men as confidence intervals included 0. The ABI Collaboration used 10-year risk thresholds of <10 percent for low, 10-19 percent for intermediate, and ≥20 percent for high risk of hard CHD outcomes. NRI for ABI in addition to the FRS in women was 0.096 (95% CI, 0.061 to 0.164), and the bias-corrected NRI_int_ in women was 0.288 (95% CI, 0.064 to 0.513). The overall NRI is largely driven by reclassification upward of those having events (event NRI: 0.145 [95% CI, 0.101 to 0.189]), but this represents the minority of the population as only 7.1 percent of women experienced a hard CHD event. Of note, the nonevent NRI was negative and statistically significant (-0.051 [95% CI, -0.059 to -0.043]). MESA, REGICOR, and Heinz Nixdorf Recall, not included in the ABI Collaboration, did not report sex-stratified analyses. MESA, employing published coefficients, found no change in NRI when ABI was added to the FRS in analyses employing the same risk categories as the ABI Collaboration, and no change in NRI when ABI was added to the PCE in analyses using a threshold of ≥7.5% 10-year risk for hard CVD outcomes. REGICOR, using published coefficients for the FRS, employed categories of low (<5%), intermediate (5-10%), and high (≥10%) 10-year risk for either soft CHD or CVD outcomes. NRI for soft CVD outcomes was 0.029 (95% CI, 0.014 to 0.045) in all people and the bias-corrected NRI_int_ was 0.061 (95% CI, 0.024 to 0.098); NRI for soft CHD outcomes was not statistically significant. REGICOR also reported IDI as a measure of reclassification for adding ABI; the magnitude and statistical significance of improvement was generally consistent with findings using NRI (Appendix E Table 1). Analyses of the Heinz Nixdorf Recall cohort using a published coefficient FRS base model found a statistically significant improvement in NRI when ABI was added to the model; however, a continuous NRI was reported, which is not comparable in scale to categorical NRIs reported in other studies (0.190 [95% CI, 0.102 to 0.278]).^114^ Subgroup analyses by risk group showed statistically significant NRI only in the intermediate (10-20% 10-year risk) and high (>20% 10-year risk) risk groups.

Model development. The ABI Collaboration also conducted model development analyses; in these analyses, adding ABI to FRS variables did not improve risk reclassification in men or women. We were not able to calculate bias-corrected NRI_int_; however, uncorrected NRI_int_ were not statistically significant. Results from individual model development studies of cohorts included in the ABI Collaboration (ARIC, Rotterdam, and Health ABC) did not report sex-stratified analyses and found no statistically significant risk reclassification with the addition of ABI to FRS variables to predict hard CHD or CVD outcomes. The Nijmegen Biomedical Study found an improvement in reclassification (NRI 0.159, p=0.056) for women but not men for soft (and not hard) CVD outcomes. This study was not included in the ABI Collaboration but used similar risk categories; followup and number of events were limited. The Nijmegen Biomedical Study also reported IDI as a measure of reclassification; the IDI for addition of ABI to FRS variables in women was not statistically significant (Appendix E Table 1). An analysis of the MESA cohort, also not included in the ABI Collaboration, demonstrated an improvement in reclassification with ABI for intermediate-risk people (5-20% 10-year risk of soft CVD outcomes). However, this study did not report bias-corrected NRI_int_ (and data were not sufficient to calculate) nor statistical significance.

### Detailed Results for hsCRP

#### Description of Cohorts

We included 25 unique studies, including one IPD meta-analysis, that examined whether hsCRP added to traditional CVD risk assessment could improve calibration, discrimination, or risk reclassification (Tables 17 and 18).^65,^ ^75,^ ^76,^ ^78,^ ^81-85,^ ^87,^ ^90,^ ^92,^ ^96-100,^ ^102-105,^ ^107-110^ These 26 studies include data from 49 different cohorts, and the included IPD meta-analysis^65^ includes 38 of the 49 cohorts (Table 17). The 11 cohorts not represented in the IPD meta-analysis are: the British Regional Heart Study,^102^ EISNER,^99^ the Framingham Heart Study (original cohort),^85^ Health ABC,^81^ Heinz Nixdorf Recall,^103^ Inter99,^92^ MONItoring of trends and determinants in Cardiovascular disease (MONICA) Copenhagen,^96^ the Northwick Park Heart Study,^78^ the Scottish Health Survey,^105^ the Study of Health in Pomerania,^100^ and the Singapore Chinese Health Study.^109^

Table 17 A Comparison of Cohorts in Included hsCRP Risk Prediction Studies With Emerging Risk Factors Collaboration IPD Meta-Analysis (KQ2)

Cohort | 2012 IPD meta-analysis^65,*^ | Publications not included in IPD meta-analysis
AFTCAPS | n=5,613
ARIC | n=9,326 | Folsom, 2006^110^; n=1,511
British Regional Heart Study | | Wannamethee, 2011^102^; n=2,893
BRUN | n=817
BWHHS | n=2,652
CaPS | n=816
CHS | 4,211
COPEN | n=7,772
EAS | n=741 | Shah, 2009^78^; n=962
EISNER | | Rana, 2012^99^; n=1,286
EPIC- Norfolk | n=15,902 | Rana, 2009^104^; n=2,550
ESTHER | n=4,738
FINRISK-92 | n=891
FINRISK-97 | n=1,150
FHS | | Wilson, 2005^85^; n=4,446
Framingham Offspring | n=2,713 | Wilson, 2005^85^ n=4,446; Wilson, 2008^107^; n=3,006; Zhou, 2013^97^; n=1,687
Health ABC | | Rodondi, 2010^81^; n=2,191
Heinz Nixdorf Recall | | Mohlenkamp, 2011^103^; n=3,966
HISAYAMA | n=2,577
HOORN | n=525
Inter99 | | Seven, 2015^92^; n=6,502
KIHD | n=2,020
LEADER | n=437
MESA | n=6,722 | Yeboah, 2016^90^ n=5,185; Yeboah, 2012 n=1,330^75^
MONICA 1 | n=873 | Koenig, 2004^84^; n=3,435
MONICA 2 | n=1,265 | Koenig, 2004^84^; n=3,435
MONICA 3 | n=3,150 | Koenig, 2004^84^; n=3,435
MONICA Goteborg | n=740
MONICA Copenhagen | | Lyngbaek, 2013^96^; n=2,315
NHANES III | n=2,359
NPHS-II | | Shah, 2009^78^; n=2,479
NSHS | n=1,324
PREVEND | n=5,819
PROSPER | n=3,180 | Sattar, 2007^108^; n=3,165
QUEBEC | n=1,219
RANCHO | n=1,381
REYK | n=14,927 | Danesh, 2004^87^; n=6,428
ROTTERDAM | n=4,437 | Kavousi, 2012^82^, n=3,029; Elias-Smale, 2010^76^, n=2,028
Scottish Health Survey | | Hamer, 2009^105^; n=5,944
SHIP | | Schneider, 2012^100^; n=3,967
SHS | n=3,112
Singapore Chinese Health Study | | Salim, 2013^109^; n=1,493
TARFS | n=1,673
ULSAM | n=926
PHS-II | n=10,715
WHITE (Whitehall I) | n=3,808
WHITE II (Whitehall II) | n=7,326
WHS | n=23,287 | Cook, 2006^83^; n=26,927
WOSCOPS | n=5,452 | Welsh, 2013^98^; n=4,128
49 total included cohorts; 11 unique cohorts not represented in IPD MA

* (k=38 for discrimination; k=22 for reclassification)

Abbreviations: AFTCAPS = Air Force / Texas Coronary Atherosclerosis Prevention Study; ARIC = Atherosclerosis Risk in Communities study; BRUN = Bruneck Study; BWHHS = British Womens Heart and Health Study; CaPS = Caerphilly Prospective Study; CHS = Cardiovascular Health Study; COPEN = Copenhagen City Heart Study; EAS = Edinburgh Artery Study; EISNER = Early Identification of Subclinical Atherosclerosis by Noninvasive Imaging Research; EPIC = European Prospective Investigation into Cancer and Nutrition; ESTHER = EpidemiologischeStudiezu Chancen der Verhütung, Früherkennung und optimierten Therapie chronischer Erkrankungen in der älteren Bevölkerung (Epidemiological investigations of the chances of preventing, recognizing early and optimally treating chronic diseases in an elderly population); FINRISK = national FINRISK study; FHS = Framingham Heart Study; Health ABC = Health, Aging, and Body Composition study; HISAYAMA = Hisayama study; HNR = Heinz Nixdorf Recall study; hsCRP = high sensitivity C-reactive protein; HOORN = Hoorn study; IPD MA = individual participant data meta-analyses; KIHD = Kuopio Ischemic Heart Disease Study; LEADER = Lower Extremity Arterial Disease Event Reduction Trial; MESA = Multi-Ethnic Study of Atherosclerosis; MONICA = MONItoring of trends and determinants in CArdiovascular disease; NHANES = National Health and Nutrition Examination Survey; NPHS = Northwick Park Heart Study; NSHS = Nova Scotia Health Survey; PHS = Physicians’ Health Study; PREVEND = Prevention of Renal and Vascular End Stage Disease Study; PROSPER = Prospective Study of Pravastatin in the Elderly at Risk; QUEBEC = Quebec CV Study; RANCHO = Rancho Bernardo Study; REYK = Reykjavik Study; ROTTERDAM = Rotterdam study; SHIP = the Study of Health in Pomerania; SHS = Strong Heart Study; TARFS = Turkish Adult Risk Factor Study; ULSAM = Uppsala Longitudinal Study of Adult Men study; WHITE = Whitehall study; WHS = Women’s Health Study; WOSCOPS = the West of Scotland Coronary Prevention Study

Table 18 Study Design and Participant Characteristics in Included hsCRP Risk Prediction Studies (KQ2)

Author, Year | Model type: Base model | Study name | Country | N | F/U, mean (yrs); Range | Mean age | % Women | % White | % DM | % HTN (% treated) | % Cholmeds^*^ | % Current Smoker | Mean hsCRP, mg/L | hsCRP Elevated Threshold, mg/L (% Elevated hsCRP)
Yeboah, 2016^†^,^90,*^ | Published coefficient: PCE | MESA | United States | 5,185 | 10; NR | 61.2 | 53.1 | 38 | 9.8 | NR (32.5) | 0 | 13.6 | 1.9^§^ | NR (NR)
Yeboah, 2016^†^,^90,*^ | Published coefficient: FRS | MESA | United States | 5,185 | 10; NR | 61.2 | 53.1 | 38 | 9.8 | NR (32.5) | 0 | 13.6 | 1.9^§^ | NR (NR)
Zhou, 2013^97^ | Published coefficient: FRS | Framingham Offspring | United States | 1,687 | NR; NR | NR | 100 | NR | NR | NR (NR) | NR | NR | NR | NR (NR)
Lyngbaek, 2013^96^ | Published coefficient: FRS | MONICA - Copenhagen | Denmark | 2,315 | 12.7^§^; 4.0-13.4 (5/95 percentile) | 53.9 | 50.5 | NR | 3.7 | NR (NR) | NR | 46.1 | 1.73^§^ | approx. ≥3.0 (NR)
Rana, 2009^104^ | Published coefficient: FRS | EPIC- Norfol k^**^ | United Kingdom | 2,550 | 6; NR | 65 | 36.1 | NR | 3.1 | NR (NR) | 0 | 10.9 | 1.8^§^ | NR (NR)
Hamer, 2009^105,*^ | Published coefficient: FRS | Scottish Health Survey | United Kingdom | 5,944 | 7.1; NR | 53.6 | 55.5 | NR | 2.6 | 26.1 (NR) | NR | 25.8 | 3.58 | ≥3 (32.1)
Koenig, 2004^84,*^ | Published coefficient: FRS^††^ | MONICA - Augsburg | Germany | 3,435 | 6.6; NR | 56.4 | 0 | 100 | 5.8 | NR (NR) | NR | 27.4 | 1.69 | >3.0 (29)
Salim, 2016^109^ | Model development: FRS variables | Singapore Chinese Health Study^**^ | Singapore | 1,493 | NR; NR | 64 | 35.4 | NR | 0 | NR (29.1) | NR | 25.1 | 1.14^‡‡^ | NR (NR)
Seven, 2015^92^ | Model development: FRS variables | Inter99 | Denmark | 6,502 | 11.4; NR | 45.9 | 51.9 | NR | 1.9 | NR (6) | 3 | 39 | 0.9^§^ | NR (NR)
Welsh, 2013^98,*^ | Model development: FRS variables | WOSCOPS | United Kingdom | 4,128^§§^ | 14.7^§^; NR | NR | 0 | NR | NR | NR (NR) | NR^‡^ | NR | 1.73 | >3.65 (NR)
Rana, 2012ǁ ǁ^99^ | Model development: FRS variables | EISNER | United States | 1,286 | 4.1; NR | 58.6 | 47.2 | NR | 8.1 | 57.9 (NR) | NR | 5.4 | 5.0 | NR (NR)
Emerging Risk Factors Collaboration, 2012^65^ | Model development: FRS variables | ERFC IPD MA^¶¶^ | Multi-national | 166,596 | 8.8^§^; 2.9 to 23.3 (5/95 percentile) | 59.7 | 51 | NR | 6 | NR (NR) | NR | 21 | 0.59^##^ | NR (NR)
Yeboah, 2012^75^ǁ ǁ^*^ | Model development: FRS variables | MESA | United States | 1,330 | 7.6^§^ 7.3-7.8 (IQR) | 63.8 | 33.3 | 35.7 | 0 | NR (38.2) | 14.1 | 16.5 | 1.62^§^ | NR (NR)
Kavousi, 2012^†^,^82^ | Model development: FRS variables | Rotterdam | Netherlands | 3,029 | 6.8^§^; 5.8-8.1 (IQR) | 69.1 | 59.4 | NR | 12.9 | NR (23.5) | 10.2 | 17.5 | 2.3^§^ | NR (NR)
Schneider, 2012^100^ | Model development: FRS variables | SHIP | Germany | 3,967 | 10.0^§^; 9.3, 10.0 (IQR) | 49^§^ | 52.3 | NR | 7.2 | NR (26.5) | NR | 33.2 | 1.38^§^ | NR (NR)
Wannamethee, 2011^102^ | Model development: FRS variables | British Regional Heart Study | United Kingdom | 2,893^***^ | 9; 8-10 | 68.2 | 0 | >99 | 10.6 | NR (NR) | NR | 12.4 | 1.67^†††^ | NR (NR)
Mohlenkamp, 2011ǁ ǁ^103,*^ | Model development: FRS variables | HNR | Germany | 3,966 | 5.1; NR | 59.3 | 52.8 | NR | 7.2 | 54.2 (31.7) | 9.1 | 22.6 | 1.4^§^ | >3 (22.6)
Rodondi, 2010^‡‡‡^,^81^ | Model development: FRS variables | Health ABC | United States | 2,191 | 8.2^§^; (Max 10.2) | 73.5 | 55.3 | 58.9 | 13.3 | 46.1 (12.5ǁǁǁ) | 10.5 | 10.1 | NR | >3.0 (NR)
Eias-Smale, 2010ǁ ǁ^76^ | Model development: FRS variables | Rotterdam | Netherlands | 2,028 | 9.2^§^; 8.3-10.0 (IQR) | 69.6 | 57.4 | NR | NR | NR (27.6) | 14 | 16.8 | NR | NR (NR)
Shah, 2009^78,*^ | Model development: FRS variables | EAS | Scotland | 962 | 17; NR | NR | NR | NR | NR | NR (NR) | NR | NR | 1.93^†††^ | >3 (33.3)
Shah, 2009^78^ | Model development: FRS variables | NPHS ǁ | United Kingdom | 2,479 | 10; NR | NR | 0 | NR | NR | NR (NR) | NR | NR | 2.46^†††^ | >3 (43.9)
Wilson, 2008^107,*^ | Model development: FRS variables | Framingham Offspring | United States | 3,006 | 12^††††^; NR | 45.5 | 52.4 | NR | 2.4 | NR (9.9) | NR | 36 | 2.5 | >3 (21.9)
Sattar, 2007^108^ | Model development: FRS variables | PROSPER | Multi-national | 3,165^§^§§§ | 3.2; NR | 75.4 | 51.7 | NR | 10.7 | 61.8 (NR) | 0 | 26.8 | 3.1 ††† | >3 (52)
Folsom, 2006^110,*^ | Model development: FRS variables | ARICǁǁǁǁ | United States | 1,511 | 7.3^§^; NR | NR | NR | 72.7 ǁǁǁǁǁ | NR | NR (NR) | NR | NR | 3.08 | NR (NR)
Cook, 2006^83,*^ | Model development: FRS variablesN | WHS | United States | 26,927 | 10; NR | 54 | 100 | NR | 0 | 14.8 (12) | NR | 12.2 | 1.5^§^ | NR (NR)
Wilson, 2005^85^ | Model development: FRS variables | FHS and Framingham Offspring | United States | 4,446 | 8; NR | 58.1 | 56.2 | NR | 7.3 | NR (20.6) | NR | 19.5 | NR | >3.0 (38.4)
Danesh, 2004^87^ | Model development: FRS variables | Reykjavik^**^ | Iceland | 6,428 ***** | 19.4†††††; NR | 55.7 | 29.7 | NR | 2.3 | NR (NR) | NR | 52.2 | 1.46††††† | 2 (37.1)

* Explicitly states that a high-sensitivity assay was used to measure CRP

† Also a study of ABI and CAC

‡ 100% with hyperlipidemia at baseline

§ Median

ǁ 2 models; 1 de novo, 1 full recalibration of ATP III

** Nested case-control study

†† FRS entered categorically, not continuously. This will underestimate the prognostic value of the published FRS and overestimate the prognostic value of CRP.^63^

‡‡ Weighted geometric mean

§§ Only abstracted data for “clean CVD cohort” which excluded those with minor ECG abnormalities, angina, those taking nitrat es, those with IC, or history of CVD (673, 16.3% excluded)

ǁǁ Also a st udy of CAC

¶¶ 38 cohorts for Hard CVD; 37 for Hard CHD: Air Force/Texas Coronary Atherosclerosis Study, ARIC, Bruneck Study, British Women’s Heart and Health Study, Caerphilly Prospective Study, CHS, Copenhagen City Heart Study, EAS, EPIC Norfolk Study, ESTHER, Finrisk 1992 Cohort, Finrisk 1997 Cohort, FHS Offspring, Hisayama Study, Hoorn Study, Kuopio Ischemic Heart Disease Study, Lower Extremity Arterial Disease Event Reduction Trail, MESA, MONICA/KORA Augsburg Survey 1, MONICA/KORA Augsburg Survey 2, MONICA/KORA Augsburg Survey 3, MONICA Goteborg Study, NHANES HI, Nova Scotia Health Survey, Prevention ofRenal and Vascular End Stage Disease Study, Prospective Study of Pravastatin in the Elderly at Risk, Quebec Cardiovascular Study, Rancho Bernardo Study, Reykjavik Study, Rotterdam, SHS, Turkish Adult Risk Factor Study, Uppsala Longitudinal Study of Adult Men, PHS II, Whitehall I Study, Whitehall II Study, WHS, West of Scotland Coronary Prevention Study

## log CRP

*** Participants without prevalent CVD (an additional 756 with CVD are reported in the paper in stratified analyses)

††† Geometric mean

‡‡‡ Also a study of ABI

ǁǁǁ ACE inhibitors are the only anti-HTN drug class reported

¶¶¶ Tzoulaki, 2007 reports that 1,010 of 1,592 in original cohort had CRP measurement; based on Ns in Shah, 2009 inferring that 48 individuals did not have valid CRP measurement and 43 did not have other variables to calculate FRS

**** 3,012 in original cohort, inferring 533 had no valid CRP measurement and 67 had missing FRS variable data

†††† Unclear whether this is mean, median, or maximum

§§§§ N for cohort with no history of vascular disease; total cohort with CRP data=5,680

ǁǁǁǁ Case-cohort study

***** 376 (5.8%) with baseline ECG abnormalities or history of angina

††††† F/U averaged between cases (17.5 years) and controls (20.6 years)

‡‡‡‡‡ hsCRP values are log-transformed and presented as geometric mean

ǁǁǁǁǁ In overall ARIC population, as reported on the study’s website: https://www2.cscc.unc.edu/aric/system/files/CohortCharacteristics.pdf

Abbreviations: ABI = ankle-brachial index; ATP III = Adult Treatment Panel III; ARIC = Atherosclerosis Risk in Communities study; CAC = coronary artery calcium; CHD = coronary heart disease; Chol = cholesterol; CVD = cardiovascular disease; DM = diabetes mellitus; EAS = Edinburgh Artery Study; ECG = echocardiogram; EISNER = Early Identification of Subclinical Atherosclerosis by Noninvasive Imaging Research; EPIC = European Prospective Investigation into Cancer and Nutrition; ERFC IPD MA= Emerging Risk Factors Collaboration individual participant data meta-analysis; FRS = Framingham Risk Score; F/U = follow up; Health ABC = Health, Aging, and Body Composition study; HNR = Heinz Nixdorf Recall study; hsCRP = high sensitivity C-reactive protein; HTN = hypertension; IQR = inter-quartile range; meds = medications; MESA = Multi-Ethnic Study of Atherosclerosis; mg/L = milligrams per Liter; MONICA = MONItoring oftrends and determinants in CArdiovascular disease; NPHS = Northwick Park Heart Study; NR = not reported; PCE = Pooled Cohort Equations; PROSPER = Prospective Study of Pravastatin in the Elderly at Risk; SHIP = the Study of Health in Pomerania; WHS = Women’s Health Study; WOSCOPS = the West of Scotland Coronary Prevention Study; yr(s) = year(s)

In total, 28 models were evaluated (Table 19). Six studies evaluated seven models using published coefficients for the PCE or FRS. Twenty studies reported the results of 21 newly developed models based on FRS variables; 2 of these models additionally included race/ethnicity as a predictor.^75,^ ^110^ Fifteen models predicted CVD outcomes, and 13 predicted CHD. Seventeen models predicted hard outcomes (CVD or CHD), 10 models predicted soft outcomes (CVD or CHD), and 1 model predicted fatal CVD outcomes only.

Table 19 Base Models for Included hsCRP Risk Prediction Studies (KQ2)

Author, Year | Base model: Model type | Study name | Age | Sex | Race/ethnicity | Smoking | SBP | Anti-HTN Tx | TC | HDL | TC: HDL ratio | DM | Predicted outcomes ‡‡‡‡: N (%) | Handling of hsCRP in extended model
Yeboah, 2016^*^,^90^ | Published coefficient: PCE (Goff, 2014)^†^ | MESA | × | × | × | × | × | × | × | × | | × | Hard CVD: 320 (6.2) | Log-transformed
Yeboah, 2016^*^,^90^ | Published coefficient: FRS^†^ | MESA | × | × | | × | ×^‡^ | | × | × | | × | Hard CHD: 194 (3.7) | Log-transformed
Lyngbaek, 2013^96^ | Published coefficient: FRS (Wilson, 1998) | MONICA - Copenhagen | × | × | | × | ×^‡^ | × | × | × | | × | Hard CVD: 302 (13.0) | Categorical by tertile (mg/L): men (0.12-1.12, 1.13-2.81, 2.82-92.55); women (0.13-1.00, 1.01-2.97, 2.98-98.45)
Zhou, 2013^97^ | Published coefficient: FRS (Wilson, 1998) | Framingham Offspring | × | × | | × | ×^‡^ | | × | × | | × | Soft CVD^§^: 261 (15.5) | Log-transformed
Rana, 2009^104^ | Published coefficient: FRS (Wilson, 1998) | EPIC-Norfolk | × | × | | × | ×^‡^ | | × | × | | × | Soft CHD: 921 (36.1) | Log-transformed
Hamer, 2009^105^ | Published coefficient: FRS (D’Agostino, 2008) | Scottish Health Survey | × | × | | × | × | × | × | × | | × | Soft CVD: 308 (5.2) Soft CHD: 240 (4.0) Fatal CVD: 138 (2.3) | Log-transformed and categorical for discrimination: <1 mg/L, 1 to <3 mg/L, ≥3 mg/L
Koenig, 2004^84^ | Published coefficient: FRS (Wilson, 1998)ǁ | MONICA - Augsburg | × | × | | × | ×^‡^ | | × | × | | × | Hard CHD: 191 (5.6) | Categorical: <1, 1-3, >3 mg/L
Salim, 2016^109^ | Model development: FRS variables | Singapore Chinese Health Study | × | × | | × | × | | × | × | | | Hard CHD: 441 (29.5) | Log-transformed for men, quadratic for women
Seven, 2015^92^ | Model development: FRS variables^#^ | Inter99 | × | × | | × | × | × | × | × | | × | Soft CVD: 493 (8.0) | Log-transformed^**^
Welsh, 2013^98^ | Model development: FRS variables^#^ | WOSCOPS | × | †† | | × | × | | × | × | | × | Soft CVD: 1357 (32.9) Soft CHD: 779 (18.9) Fatal CVD: 253 (6.1) Fatal CHD: 171 (4.1) | Log-transformed
Emerging Risk Factors Collaboration, 2012^65^ | Model development: FRS variables | ERFC IPD MA | × | × | | × | × | | × | × | | × | Hard CVD: 13568 (8.1) Hard CHD: 8816 (5.3) | Log-transformed
Yeboah, 2012^*^,^75^ | Model development: FRS variables^‡‡^ | MESA | × | × | × | × | × | × | × | × | | | Soft CVD: 123 (9.2) Soft CHD: 94 (7.1) | Log-transformed
Kavousi, 2012^*^,^82^ | Model development: FRS variables^§§^ | Rotterdam | × | × | | × | × | × | × | × | | × | Hard CHD: 347 (5.8) | Continuous
Rana, 2012ǁǁ^99^ | Model development: FRS variables | EISNER | × | × | | × | × | × | × | × | | × | Soft CVD: 35 (2.7) | Continuous
Schneider, 2012^100^ | Model development: FRS variables | SHIP | × | × | | × | × | × | × | × | | × | Fatal CVD: 91 (2.5) | Log-transformed
Wannamethee, 2011^102^ | Model development: FRS variables | British Regional Heart Study | × | †† | | × | × | | × | × | | × | Hard CVD: 402 (13.9) Hard CHD: 194 (6.7) Fatal CVD: 223 (7.7) Fatal CHD: 119 (4.1) | Log-transformed
Mohlenkamp, 2011ǁǁ^103^ | Model development: FRS variables | HNR | × | × | | × | × | | | ×^¶¶^ | | × | Hard CHD: 91 (2.3) | Continuous^##^
Elias-Smale, 2010ǁǁ^76^ | Model development: FRS variables | Rotterdam | × | × | | × | × | × | × | × | | × | Hard CHD: 135 (6.6) | Continuous
Rodondi, 2010^***^,^81^ | Model development: FRS variables | Health ABC | × | × | | × | × | × | × | × | | × | Hard CHD: 197 (9.0) Soft CHD: 351 (16.0) | Categorical: <1, 1-3, >3 mg/L
Shah, 2009^78^ | Model development: FRS variables | Edinburgh Artery Study | × | × | | × | × | | × | × | | × | Hard CHD: 147 (15.3) | Log-transformed
Shah, 2009^78^ | Model development: FRS variables | Northwick Park Heart Study ǁ | × | †† | | × | × | | × | | | × | Hard CHD: 162 (6.5) | Log-transformed
Wilson, 2008^107^ | Model development: FRS variables | Framingham Offspring | × | × | | × | × | × | × | × | | × | Hard CHD: 129 (4.3) Soft CVD: 286 (9.5) | Log-transformed
Sattar, 2007^108^ | Model development: FRS variables^†††^ | PROSPER | × | × | | × | × | × | | ×^¶¶^ | | × | Hard CVD: 373 (11.8) Hard CHD: NR (NR) | Log-transformed
Cook, 2006^83^ | Model development: FRS (NCEP ATP III, 2002)^‡‡‡^ | WHS | × | †† | | × | × | × | × | × | | | Soft CVD: NR (NR)^§§§^ | Log-transformed
Cook, 2006^83^ | Model development: FRS variables ǁǁǁ | WHS | × | †† | | × | × | ×^¶¶¶^ | × | × | | | Soft CVD: 390 (2.6)^###^ | Log-transformed
Folsom, 2006^110^ | Model development: FRS variables | ARIC | × | × | × | × | × | × | × | × | | × | Soft CHD: 666 (44.1) | Log-transformed
Wilson, 2005^85^ | Model development: FRS | FHS and Framingham offspring | × | × | | × | × | | | | × | × | Hard CVD: 283 (6.4) Hard CHD: 160 (3.6) Soft CVD: 466 (10.5) | Categorical: <1, 1-3, >3 mg/L
Danesh, 2004^87^ | Model development: FRS variables^****^ | Reykjavik | × | × | | × | × | | × | | | | Hard CHD: 2,459 (38.2) | Log-transformed^††††^

* Also a study of ABI and CAC

† Recalibration accomplished by including the PCE (or FRS in that corresponding model) in the Cox model predicting hard CVD events (or hard CHD in FRS model); created a calibrated PCE which used the BL survival estimated from MESA data

‡ BP categories as defined in JNC-V; includes DBP

§ CVD definition is not specified; assuming soft CVD based on number of events

ǁ FRS was entered categorically, not continuously in the model. Two categorizations reported for 10-yr risk of hard CHD: 1) 3 risk categories: <6%, 6% to 19%, and ≥20%; and 2) 5 risk categories, <6%, 6% to 10%, 11% to 14%, 15% to 19%, and ≥20%. Models were additionally adjusted for survey year.

# Also adjusted for intervention arm

** Assumed log-transformation since hsCRP distribution was skewed; no other details reported

†† Sex not included as a predictor as sample was entirely Men or entirely Women

‡‡ FRS (NCEP ATP III, 2002) plus addition of race/ethnicity served as the base model

§§ Additionally adjusted for CAC scanner type

ǁǁ Also a study of CAC

¶¶ Also included LDL

## Assumed continuous for relevant analyses, though categorical analyses also presented for association data (HR analyses)

*** Also a study of ABI

††† Also adjusted for randomized treatment and country

‡‡‡ ATP III beta-coefficients recalculated for all traditional risk factors before adding CRP to the model to be conservative and allow best possible fit.

§§§ Reported for model development cohort only

ǁǁǁ For generalizability, predicted probabilities were calibrated to observed risk from the Framingham Heart Study.

¶¶¶ SBP included as two variables: (SBP-125) and (SBP-125)^2^

### Among model development population of 15,048 women with data on all variables who were not taking HRT

**** Also adjusted for enrollment year. Inclusion of predictors in the base model derived from Figure 1.

†††† Assumed log-transformed for relevant analyses, though categorical analyses also present for association data (OR analyses)

‡‡‡‡ Hard CVD defined as fatal or nonfatal MI or CVA or CVD mortality; hard CHD defined as fatal or nonfatal MI or CHD mortality; soft CVD could additionally include angina, revascularization, TIA or claudication in composites defined by the study. Similarly, hard CHD could additionally include angina or coronary revascularization in composites defined by the study.

Abbreviations: ABI = ankle-brachial index; ATP III = Adult Treatment Panel III; ARIC = Atherosclerosis Risk in Communities study; CAC = coronary artery calcium; CHD = coronary heart disease; CVD = cardiovascular disease; DM = diabetes mellitus; EAS = Edinburgh Artery Study; ECG = echocardiogram; EISNER = Early Identification of Subclinical Atherosclerosis by Noninvasive Imaging Research; EPIC = European Prospective Investigation into Cancer and Nutrition; ERFC IPD MA= Emerging Risk Factors Collaboration individual participant data meta-analysis; FRS = Framingham Risk Score; F/U = follow up; Health ABC = Health, Aging, and Body Composition study; HDL = high-density lipoprotein; HNR = Heinz Nixdorf Recall study; HR = hazard ratio; hsCRP = high sensitivity C-reactive protein; HTN = hypertension; LDL = low-density lipoprotein; MESA = Multi-Ethnic Study of Atherosclerosis; mg/L = milligrams per Liter; MONICA = MONItoring of trends and determinants in CArdiovascular disease; NPHS = Northwick Park Heart Study; NR = not reported; OR = odds ratio; PCE = Pooled Cohort Equations; PROSPER = Prospective Study of Pravastatin in the Elderly at Risk; SBP = systolic blood pressure; SHIP = the Study of Health in Pomerania; TC = total cholesterol; WHS = Women’s Health Study; WOSCOPS = the West of Scotland Coronary Prevention Study

In general, study cohorts were sufficiently large, with an adequate number of outcome events accrued and reflective of the general population for whom CVD risk assessment would be applicable. Analyzed cohorts ranged from approximately 1,000 to nearly 27,000 participants; the Emerging Risk Factors Collaboration IPD meta-analysis included 166,596 individuals. Most populations were from prospective, population-based cohort studies, including one case-cohort analysis^110^ and three nested case-control analyses.^87,^ ^104,^ ^109^ Additionally, five populations consisted of randomized control trial participants; these trials evaluated CAC screening (an included study for KQ1),^99^ lifestyle modification for CVD risk reduction,^92^ statins,^98,^ ^108^ and aspirin.^83^ The cohort from the EISNER RCT, with just 4.1 years of followup, modeled a predicted time horizon of 4 years, though only 35 events accrued.^99^ Otherwise, cohorts reported about 100 events at minimum and the Emerging Risk Factors Collaboration IPD meta-analysis reported 13,568 hard CVD events and 8,816 hard CHD events.^65^

Of the 25 studies, 4 were analyses of men only,^78,^ ^84,^ ^98,^ ^102^ and 2 were exclusively in women.^83,^ ^97^ Mean ages ranged from 45.5 to 75.4 years. Three studies excluded participants with diabetes;^75,^ ^83,^ ^109^ diabetes status was not included as a variable in the respective risk prediction models, nor was it in the Reykjavik case-control analysis, where a very small proportion of participants had diabetes (2.3%).^87^ The proportion of participants with diabetes in other studies ranged from 1.9 to 13.3 percent, where reported, and diabetes was included as a predictor in these models. MESA, ARIC, and Health ABC, all conducted in the United States, reported racial/ethnic diversity, of which analyses for MESA and ARIC included race/ethnicity as a variable in their risk prediction model.^75,^ ^81,^ ^90,^ ^110^ The analysis by Salim and colleagues^109^ was conducted in a cohort of exclusively Chinese adults in Singapore. Three studies excluded participants taking statins at baseline,^90,^ ^104,^ ^108^ and where reported, statin use ranged from 3 to 14 percent in other studies. Use of antihypertensive agents was relatively common in studies reporting it, generally about 12 to 32 percent. Aspirin use was reported in only Health ABC, a study of adults age 70 or older, which reported that 18.8 percent of this primary prevention population was taking the drug.

Mean baseline Framingham Risk Scores were sparsely reported, and the distribution of risk among low-, intermediate-, and high-risk classifications varied widely between studies. Comparisons of baseline risk across cohorts are limited by different predicted outcomes and variable followup time, but generally suggest heterogeneity. For example, 6.2 percent of the MESA cohort experienced a hard CVD event over 10 years of followup,^90^ whereas the hard CVD event rate was nearly twice as high in the British Regional Heart Study of exclusively men (13.9% over 9 years of followup).^102^

Ten of 26 studies explicitly indicated that a high-sensitivity CRP assay was used; however, others reported low limits of detection consistent with hsCRP. Where reported, the threshold defining an elevated hsCRP was 3.0 mg/L, and in one case it was 2.0 mg/L.^87^ In studies reporting the proportion of participants with an elevated hsCRP, about 22 to 52 percent of participants met the studies’ respective definitions. Mean hsCRP levels ranged from 1.69 to 5.0 mg/L, and median hsCRP levels ranged from 0.9 to 2.3 mg/L. Most studies excluded or are assumed to have excluded people with missing data for hsCRP or traditional cardiovascular risk factors; two analyses, both from the Rotterdam cohort, used imputation.^76,^ ^82^ HsCRP was most commonly log-transformed when included in risk prediction models, owing to its frequently skewed distribution. When entered categorically in risk prediction models—as it was in five studies—thresholds were typically defined as: less than 1 mg/L, 1 to 3 mg/L, and greater than 3 mg/L. Treatment of continuous risk predictors as dichotomous or categorical variables results in loss of statistical power and compromises predictive performance.^63^ However, the threshold of 2 mg/L has been used in a large randomized trial of statin therapy in participants with elevated hsCRP but normal LDL levels;^120^ thus, use of a categorical form may address a more explanatory question, although most included risk prediction studies used a threshold of 3 mg/L when categorical analyses were used.

Most studies were fair quality. Limitations of studies are described above. Fair-quality as opposed to good-quality studies had followup time equivalent to the time horizon predicted by the model, had fewer than 20 outcome events per variable, did not report any calibration or goodness-of-fit measures, and/or did not report confidence intervals or statistical significance of changes in measures of discrimination or risk reclassification; additionally, published coefficient models did not conduct any recalibration. Just two studies evaluating hsCRP had these characteristics and were therefore assessed as good quality.^81,^ ^96^ The Emerging Risk Factors Collaboration IPD meta-analysis was a well-conducted model development study and represents the best evidence to address this key question; however, it was deemed fair quality because calibration, a key domain of model performance, was not reported.^65^ Additionally, many of the included cohorts had less than 10-year followup (although reclassification analyses were limited to studies reporting this duration). The Emerging Risk Factors Collaboration model has limited applicability because it is not publicly available as a calculator for clinical practice.

#### Model Performance (Calibration, Discrimination, Risk Reclassification)

For model performance, we will first discuss results of calibration, then discrimination, and finally risk reclassification. Of the 25 studies (49 cohorts) included, 9 articles (10 cohorts) reported some measure of calibration, all articles and cohorts reported discrimination, and 15 articles (33 cohorts) reported risk reclassification. To guide the reader, each section is formatted similarly, with a discussion of results from models using the published coefficients first, then model development studies. Because this body of evidence includes a single, large IPD meta-analysis by the Emerging Risk Factors Collaboration, which comprises 38 different cohorts, we discuss findings from the Emerging Risk Factors Collaboration as the central piece of evidence and discuss other studies of individual cohorts in relation to these IPD meta-analyses findings if these studies provide additional information/insight.

##### Calibration

Limited evidence from three published coefficient models, each reporting different measures, suggests that the addition of hsCRP to traditional cardiovascular risk factors can improve calibration (Table 20). However, calibration plots and O:E ratios are not available for these studies. More evidence is available for model development studies, although better calibration would be expected in these models because measures are evaluated in the same population from which the model was derived. Calibration plots are available for a small subset of model development studies and show that the addition of hsCRP can improve model fit in some risk groups, but may worsen it in others. Based on the included studies and limited reporting around calibration, we cannot determine when hsCRP improves calibration in some risk groups but not others. Various measures generally show improvement when models are extended to include hsCRP, with some exceptions. The Health ABC cohort of older adults showed a decrement in most measures of model fit with the addition of hsCRP to the model. Calibration measures are not reported in the Emerging Risk Factors Collaboration IPD meta-analysis. No studies evaluating the extension of hsCRP to a PCE base model, or a model including race/ethnicity, reported any measure of calibration.

Table 20 Calibration and Overall Performance Measures in Included hsCRP Risk Prediction Studies (KQ2)

Measure | Author, Year | Model Type: Base model | Study name | N | Outcome^‡‡^ | Subgroup | Base model | Base model P-Value | Extended model | Extended model P-Value | Between model P-Value | Calculated change between models
AIC | Shah, 2009^78^ | Model development: FRS variables | Edinburgh Artery Study^*^ | 962 | Hard CHD | All Participants | 2397.6 | -- | 2390.5 | -- | <0.001 | -7.1
AIC | Rodondi, 2010^81^ | Model development: FRS variables | Health ABC | 1,515 | Hard CHD | All Participants | 1796.7 | -- | 1800.5 | -- | -- | 3.8
AIC | Koenig, 2004^84^ | Published coefficient: FRS^†^ | MONICA - Augsburg | 3,435 | Hard CHD | All Participants | 2816 | -- | 2797 | -- | -- | -19^‡^
AIC | Shah, 2009^78^ | Model development: FRS variables | NPHS-II^§^ | 2,479 | Hard CHD | All Participants | 2368.6 | -- | 2355.8 | -- | <0.001 | -12.8
AIC | Rodondi, 2010^81^ | Model development: FRS variables | Health ABC | 1,515 | Soft CHD | All Participants | 3102.6 | -- | 3104.8 | -- | -- | 2.2
AIC | Cook, 2006^83^ | Model development: FRS variables (ATP III Full Recalibration) | WHS | 26,927 | Soft CVD | All Participants | 6942.74 | -- | 6928.58 | -- | -- | -14.16
AIC | Cook, 2006^83^ | Model development: FRS variables (WHS Model) | WHSǁ | 15,048 | Soft CVD | All Participants | 6941.84 | -- | 6928.53 | -- | -- | -13.31
BIC | Rodondi, 2010^81^ | Model development: FRS variables | Health ABC | 1,515 | Hard CHD | All Participants | 1839.3 | -- | 1859.1 | -- | -- | 19.8
BIC | Cook, 2006^83^ | Model development: FRS variables (ATP III Full Recalibration) | WHS | 26,927 | Soft CVD | All Participants | 6974.46 | -- | 6964.28 | -- | -- | -10.18
BIC | Cook, 2006^83^ | Model development: FRS variables (WHS Model) | WHSǁ | 15,048 | Soft CVD | All Participants | 6969.60 | -- | 6960.26 | -- | -- | -9.34
BIC | Rodondi, 2010^81^ | Model development: FRS variables | Health ABC | 1,515 | Soft CHD | All Participants | 3145.2 | -- | 3163.3 | -- | -- | 18.1
Brier score | Cook, 2006^83^ | Model development: FRS variables (ATP III Full Recalibration) | WHS | 26,927 | Soft CVD | All Participants | 0.01964 | -- | 0.01959 | -- | -- | -0.00005
Brier score | Cook, 2006^83^ | Model development: FRS variables (WHS Model) | WHSǁ | 15,048 | Soft CVD | All Participants | 0.01965 | -- | 0.01960 | -- | -- | -0.00005
Gronnesby-Borgan goodness-of-fit | Lyngbaek, 2013^96^ | Published coefficient: FRS | MONICA - Copenhagen | 2,315 | Hard CVD | All Participants | NR | >0.05 | NR | >0.05 | -- | --
Hosmer-Lemeshow test | Shah, 2009^78^ | Model development: FRS variables | Edinburgh Artery Study^*^ | 962 | Hard CHD | All Participants | NR | 0.65 | NR | 0.65 | -- | --
Hosmer-Lemeshow test | Rodondi, 2010^81^ | Model development: FRS variables | Health ABC | 1,515 | Hard CHD | All Participants | 4.80 | 0.85 | 7.96 | 0.54 | -- | --
Hosmer-Lemeshow test | Mohlenkamp, 2011^103^ | Mbdel development: FRS variables | HNR | 3,966 | Hard CHD | All Participants | 11.5 | 0.18 | NR | NR | -- | --
Hosmer-Lemeshow test | Shah, 2009^78^ | Model development: FRS variables | NPHS-II^§^ | 2,479 | Hard CHD | All Participants | NR | 0.82 | NR | 0.90 | -- | --
Hosmer-Lemeshow test | Cook, 2006^83^ | Model development: FRS variables (ATP III Full Recalibration) | WHS | 26,927 | Soft CVD | All Participants | NR | 0.79^¶^ | NR | 0.71^¶^ | -- | --
Hosmer-Lemeshow test | Cook, 2006^83^ | Model development: FRS variables (ATP III Full Recalibration) | WHS | 26,927 | Soft CVD | All Participants | NR | 0.008^#^ | NR | 0.25^#^ | -- | --
Hosmer-Lemeshow test | Cook 2006^83^ | Model development: FRS variables (WHS Model) | WHSǁ | 15,048 | Soft CVD | All Participants | NR | 0.59^¶^ | NR | 0.19^¶^ | -- | --
Hosmer-Lemeshow test | Cook, 2006^83^ | Model development: FRS variables (WHS Model) | WHSǁ | 15,048 | Soft CVD | All Participants | NR | 0.039^#^ | NR | 0.23^#^ | -- | --
Hosmer-Lemeshow test | Rana, 2009^104^ | Published coefficient: FRS | EPIC-Norfolk | 2,550 | Soft CHD | All Participants | 18.0 | 0.02 | 20.3 | 0.009 | NR | 2.3
Hosmer-Lemeshow test | Rana, 2009^104^ | Published coefficient: FRS | EPIC-Norfolk | 1,008 | Soft CHD | Intermediat e Risk | 12.9 | 0.1 | 10.8 | 0.2 | NR | -2.1
Hosmer-Lemeshow test | Rodondi, 2010^81^ | Model development: FRS variables | Health ABC | 1,515 | Soft CHD | All Participants | 4.23 | 0.90 | 13.86 | 0.13 | NR | 9.63
Likelihood ratio X^2^ | Sattar, 2007^108^ | Model development: FRS variables | PROSPER | 3,165 | Hard CVD | All Participants | NR^**^ | NR^**^ | NR^**^ | NR^**^ | NR^**^ | --
Likelihood ratio X^2^ | Rodondi, 2010^81^ | Model development: FRS variables | Health ABC | 1,515 | Hard CHD | All Participants | 27.48 | <0.001 | 29.62 | 0.002 | NR | 2.14
Likelihood ratio X^2^ | Kavousi, 2012 | Model development: FRS variables | Rotterdam | 3,029 | Hard CHD | All Participants | 230.49^††^ | NR | 4.8^††^ | NR | <0.05^††^ | -225.69^††^
Likelihood ratio X^2^ | Cook, 2006^83^ | Model development: FRS variables (ATP III Full Recalibration) | WHS | 26,927 | Soft CVD | All Participants | 542.54 | NR | 558.69 | NR | <0.001 | 16.15
Likelihood ratio X^2^ | Cook, 2006^83^ | Model development: FRS variables (WHS Model) | WHSǁ | 15,048 | Soft CVD | All Participants | 541.44 | NR | 556.75 | NR | <0.001 | 15.31
Likelihood ratio X^2^ | Rodondi, 2010^81^ | Model development: FRS variables | Health ABC | 1,515 | Soft CHD | All Participants | 35.31 | <0.001 | 41.87 | <0.001 | NR | 6.56
-2 log likelihood | Rana, 2009^104^ | Published coefficient: FRS | EPIC-Norfolk | 2,550 | Soft CHD | All Participants | 3284.6 | NR | 3242.7 | NR | NR | -41.9
-2 log likelihood | Rana, 2009^104^ | Published coefficient: FRS | EPIC-Norfolk | 1,008 | Soft CHD | Intermediate Risk | 1253.6 | NR | 1225.9 | NR | NR | -27.7
R^2^ | Cook, 2006^83^ | Model development: FRS variables (ATP III Full Recalibration) | WHS | 26,927 | Soft CVD | All Participants | 8.84 | NR | 8.97 | NR | NR | 0.13
R^2^ | Cook, 2006^83^ | Model development: FRS variables (WHS Model) | WHSǁ | 15,048 | Soft CVD | All Participants | 8.92 | NR | 9.05 | NR | NR | 0.13

* Figure 1 reports ratio of predicted:observed events by quintile. Predicted:observed ratio for base model, by quintile: 1.30, 0.96, 0.98, 1.05, 0.97. Predicted:observed ratio for extended model, by quintile: 1.31, 0.81, 1.26, 0.90, 0.99

† FRS entered categorically, not continuously; 3-category model abstracted

‡ AIC difference between models was 13 using FRS with 5 risk categories.

§ Figure 1 reports ratio of predicted:observed events by quintile. Predicted:observed ratio for base model, by quintile: 0.93, 1.00, 1.21, 1.24, 0.86. Predicted:observed ratio for extended model, by quintile: 0.85, 1.20, 1.28, 1.00, 0.92.

ǁ Calibration plot shown but O:E NR. Calibration plot shows that the model without CRP overpredicts risk in the 14-15% risk group and calibration is improved with addition of CRP. In the 16-17% risk group; overprediction appears to worsen in the model with CRP. Other risk groups look reasonably similar.

¶ Hosmer-Lemeshow test based on deciles.

# Hosmer-Lemeshow test based on 10 categories defined by 2-percentage point increments in predicted risk (from 0-2% risk to 18% or greater risk).

** Reports probability values for likelihood ratio test for inclusion of term representing deciles of predicted risk into the model (based on models either including or excluding log CRP); the corresponding p-value is unclear but authors report "no significant miscalibration in the models either before or after addition of CRP."

†† P-value indicates statistically significant improvement in model fit. Base model is "model likelihood chi-square" Extended model statistic is "increase in model fit after extending the base model." Power not enough to perform sex-specific analyses for CRP.

‡‡ Hard CVD defined as fatal or nonfatal MI or CVA or CVD mortality; hard CHD defined as fatal or nonfatal MI or CHD mortality; soft CVD could additionally include angina, revascularization, TIA or claudication in composites defined by the study. Similarly, hard CHD could additionally include angina or coronary revascularization in composites defined by the study.

Abbreviations: ABI = ankle-brachial index; AIC = Akaike information criterion; ARIC = Atherosclerosis Risk in Communities study; BIC = Bayesian information criterion; CAC = coronary artery calcium; CHD = coronary heart disease; CVD = cardiovascular disease; EPIC = European Prospective Investigation into Cancer and Nutrition; ERFC IPD MA = Emerging Risk Factors Collaboration individual participant data meta-analysis; FRS = Framingham Risk Score; F/U = follow up; Health ABC = Health, Aging, and Body Composition study; HNR = Heinz Nixdorf Recall study; HRT = hormone replacement therapy; hsCRP = high sensitivity C-reactive protein; HTN = hypertension; MESA = Multi-Ethnic Study of Atherosclerosis; mg/L = milligrams per Liter; MONICA = MONItoring of trends and determinants in CArdiovascular disease; NPHS = Northwick Park Heart Study; NR = not reported; PROSPER = Prospective Study of Pravastatin in the Elderly at Risk; SHIP = the Study of Health in Pomerania; WHS = Women’s Health Study; WOSCOPS = the West of Scotland Coronary Prevention Study

Published coefficient models. Three published coefficient models reported measures of calibration or overall performance (Table 20).^84,^ ^96,^ ^104^ Overall performance measures suggested smaller (i.e., improved) differences between observed and predicted outcomes when hsCRP was added to the model, but these measures capture both calibration and discrimination.

The Hosmer-Lemeshow test, which addresses calibration more directly, was reported in just one published coefficient analysis. In this nested-case control analysis of the EPIC-Norfolk study, calibration appeared to improve with the addition of hsCRP to the model (as evaluated by an increase in p-value, and decrease in test value), when assessed in the subset of intermediate-risk participants, but the addition of hsCRP resulted in poorer fit when assessed in all analyzed participants. However, the base model itself signaled poor fit (p=0.02); the p-value for the extended model was 0.009. Results of the Hosmer-Lemeshow test are sensitive to how populations are grouped for analysis, so comparison of overall results to those of the intermediate-risk subset should be interpreted with caution. Additionally, the higher p-value in the intermediate group could occur because of a smaller sample, so it is not possible to determine whether apparent improvement is consistent with the whole cohort.

Model development studies. Two model development studies, reporting results from three cohorts, presented calibration plots, and one reported the O:E ratio (Table 20).^78,^ ^83^ Shah and colleagues^78^ reported calibration plots and the O:E ratio by quintile of risk for their analyses of the Northwick Park Heart Study II (NPHSII) and the Edinburgh Artery Study (EAS), that had 162 and 147 events, respectively. For NPHSII, the addition of hsCRP to Framingham variables worsened the O:E ratio (i.e., moved away from 1) for the lower three quintiles of risk, and improved (i.e., got closer to 1) for the higher two quintiles of risk. Results showed a similar pattern for the EAS analysis, but the O:E ratio improved for only the highest-risk quintile, and in this group the base model was already well calibrated. For both base and extended models, there was not a consistent trend of over- or underprediction across the two studies; overprediction occurred in the middle-risk quintiles in NPHSII and in the lowest-risk quintile in EAS. However, the small number of events in these studies substantially limits the reliability of such an assessment, particularly in low-risk strata in which very few events occur. For most risk quintiles, base models were reasonably well calibrated, which is consistent with this being a model development study in which model performance is being evaluated in the same population from which it was derived.

A calibration plot is also reported for the Women’s Health Study (WHS) model development study that shows predicted and observed risks for 2-percentage-point increments in predicted 10-year risk of soft CVD outcomes; O:E ratios are not reported.^83^ Visual inspection of the calibration plots shows that predicted and observed risk is reasonably concordant for low- and high-risk levels but less concordant for intermediate-risk women (12 to 18%), with predicted risk being higher than observed risk. Within this intermediate-risk group, the addition of hsCRP to the WHS model had little impact for the 12- to 13-percent risk increment, markedly improved calibration in the 14- to 15-percent risk increment, and worsened in calibration in the 16- to 17-percent risk increment. In the WHS analysis, the Hosmer-Lemeshow test, R^2^, and Brier score all showed improvement in model fit when hsCRP was added to base models.

In most studies, overall performance measures generally suggested improvement when hsCRP was added to models.^78,^ ^81-83,^ ^108^ The calibration-specific Hosmer-Lemeshow test suggested that the addition of hsCRP to the base model of traditional cardiovascular disease risk factors worsened model fit in the Health ABC study; the AIC and BIC measures of overall performance were consistent with this finding.^81^ Of note, multivariate-adjusted associations of hsCRP with soft CHD events were not statistically significant in this study. The Health ABC cohort is an intermediate- to high-risk cohort, with a mean FRS of 16.6 percent and average age of over 73. Hosmer-Lemeshow test results in other studies were mixed. In analyses by Shah and colleagues,^78^ the Hosmer-Lemeshow test showed no change in the EAS with the addition of hsCRP to the base model and a small improvement in the NPHSII.

##### Discrimination

All of the included studies reported change in discrimination (i.e., AUC or c-statistic) by adding hsCRP to traditional cardiovascular risk assessment (Table 21). The discrimination of base models using traditional cardiovascular risk factors ranged widely in both published coefficient models and model development studies, from 0.58 to 0.898 collectively. The addition of hsCRP to published coefficient models showed mixed results, ranging from no change in discrimination in recalibrated models evaluating the PCE and FRS to small improvement in discrimination (0.03), although higher estimates likely represent an upper bound owing to study design limitations. For model development studies, the most expansive evidence comes from the Emerging Risk Factors Collaboration IPD meta-analysis, which found very small but statistically significant improvement in discrimination for hard CVD (0.0039) and for hard CHD (0.0051); interaction testing in exploratory analyses provides some evidence that men achieve a greater predictive improvement than women, but these changes are nonetheless very small. Evidence from the nine model-development studies of cohorts not included in the IPD meta-analysis were also inconsistent, although comparisons are limited by sparse reporting of statistical significance and confidence intervals. At best, improvement in discrimination from the addition of hsCRP to traditional cardiovascular risk assessment is small and more likely to occur in the context of a poorly discriminating base model, but the clinical meaning of these small changes in discrimination is unknown.

Table 21 Discrimination Outcomes in Included hsCRP Risk Prediction Studies (KQ2)

Model type: Base model | Author, Year | Study name | Outcome ††† | Subgroup | N | Base model c-statistic (95% CI) | Extended model c-statistic (95% CI) | Change in discrimination (95% CI)^*^ | Change P-Value
Published coefficient: PCE^†^ | Yeboah, 2016^90^ | MESA | Hard CVD | All Participants | 5,185 | 0.74 (NR to NR) | 0.74 (NR to NR) | 0 (NR to NR) | 0.25
Published coefficient: FRS | Lyngbaek, 2013^96^ | MONICA - Copenhagen | Hard CVD | Women | 1,168 | 0.717 (0.674 to 0.759) | 0.724 (0.679 to 0.769) | 0.007 (NR to NR) | 0.262
Published coefficient: FRS | Lyngbaek, 2013^96^ | MONICA - Copenhagen | Hard CVD | Men | 1,147 | 0.722 (0.686 to 0.757) | 0.734 (0.699 to 0.769) | 0.012 (NR to NR) | 0.037
Published coefficient: FRS | Yeboah, 2016^90^ | MESA^†^ | Hard CHD | All Participants | 5,185 | 0.74 (NR to NR) | 0.74 (NR to NR) | 0 (NR to NR) | 0.925
Published coefficient: FRS | Koenig, 2004^84^ | MONICA - Augsburg^‡^ | Hard CHD | All Participants | 3,435 | 0.713 (NR to NR)^§^ | 0.740 (NR to NR)^§^ | 0.027 (NR to NR) | 0.0077
Published coefficient: FRS | Zhou, 2013^97^ | Framingham Offspring | Soft CVD | All Participants | 1,687 | 0.776 (NR to NR) | 0.778 (NR to NR) | 0.002^*^ (-0.005^*^ to 0.01^*^) | NR
Published coefficient: FRS | Zhou, 2013^97^ | Framingham Offspring | Soft CVD | Intermediate Risk | 193 | NR | NR | 0.037^*^ (-0.054^*^ to 0.13^*^) | NR
Published coefficient: FRS | Hamer, 2009^105^ | Scottish Health Survey | Soft CVD | All Participants | 5,944 | 0.777 (0.754 to 0.800) | 0.781 (0.758 to 0.804) | 0.004 (NR to NR) | NR
Published coefficient: FRS | Rana, 2009^104^ | EPIC-Norfolk | Soft CHD | All Participants | 2,550 | 0.59 (0.57 to 0.61) | 0.65 (0.59 to 0.64) | 0.03^*^ (0.01^*^ to 0.05^*^) | 0.005
Published coefficient: FRS | Rana, 2009^104^ | EPIC- Norfolk | Soft CHD | Intermediate Risk | 1,008 | 0.54 (0.50 to 0.57) | 0.61 (0.57 to 0.65) | 0.08^*^ (0.03^*^ to 0.12^*^) | <0.001
Published coefficient: FRS | Hamer, 2009^105^ | Scottish Health Survey | Soft CHD | All Participants | 5,944 | 0.766 (0.740 to 0.792) | 0.768 (0.742 to 0.793) | 0.002 (NR to NR) | NR
Model development: FRS variables | Wannamethee, 2011^102^ | British Regional Heart Study | Hard CVD | All Participants | 2,893 | 0.686 (NR to NR) | 0.695 (NR to NR) | 0.009 (NR to NR) | 0.06
Model development: FRS variables | ERFC, 2012^65^ | ERFC IPD MA | Hard CVD | All Participants | 166,596 | 0.7139 (0.7097 to 0.7182) | 0.7179 (0.7136 to 0.7221) | 0.0039^*^ (0.0028^*^ to 0.0050^*^) | <0.0001
Model development: FRS variables | ERFC, 2012^65^ | ERFC IPD MA | Hard CVD | Women | 4,535 cases^¶^ | NR | NR | 0.0007^*^ (-0.0007^*^ to 0.0021^*^) | Interaction p<0.001 vs Men^***^
Model development: FRS variables | ERFC, 2012^65^ | ERFC IPD MA | Hard CVD | Men | 5,755 cases^¶^ | NR | NR | 0.0077^*^ (0.0058^*^ to 0.0096^*^) | Interaction p<0.001 vs Women^***^
Model development: FRS variables | ERFC, 2012^65^ | ERFC IPD MA | Hard CVD | With diabetes | 1,580 cases^¶^ | NR | NR | 0.0026^*^ (-0.0015^*^ to 0.0067^*^) | Interaction p=0.48 vs without diabetes^***^
Model development: FRS variables | ERFC, 2012^65^ | ERFC IPD MA | Hard CVD | Without diabetes | 11,418 cases^¶^ | NR | NR | 0.0042^*^ (0.0029^*^ to 0.0055^*^) | Interaction p=0.48 vs with diabetes^***^
Model development: FRS variables | ERFC, 2012^65^ | ERFC IPD MA | Hard CVD | Non-Whites | 539 cases^¶^ | NR | NR | -0.0008^*^ (-0.0056^*^ to 0.0039^*^) | Interaction p=0.274 vs Whites^***^
Model development: FRS variables | ERFC, 2012^65^ | ERFC IPD MA | Hard CVD | Whites | 3,544 cases^¶^ | NR | NR | 0.0021^*^ (-0.0002^*^ to 0.0044^*^) | Interaction p=0.274 vs Non-whites^***^
Model development: FRS variables | Wilson, 2005^85^ | FHS and Framingham offspring | Hard CVD | All Participantsǁ | 4,446 | 0.78 (0.76 to 0.80) | 0.78 (0.75 to 0.80) | 0 (NR to NR) | NR
Model development: FRS variables | Sattar, 2007^108^ | PROSPER | Hard CVD | All Participants | 3,165 | 0.58 (NR to NR) | 0.69 (NR to NR) | 0.11 (NR to NR) | NR
Model development: FRS variables | Sattar, 2007^108^ | PROSPER | Hard CVD | Placebo group only | 1,654^#^ | 0.630 (NR to NR) | 0.637 (NR to NR) | 0.007 (NR to NR) | 0.020
Model development: FRS variables | Wannamethee, 2011^102^ | British Regional Heart Study | Hard CHD | All Participants | 2,893 | 0.686 (NR to NR) | 0.690 (NR to NR) | 0.004 (NR to NR) | 0.49
Model development: FRS variables | Shah, 2009^78^ | Edinburgh Artery Study | Hard CHD | All Participants | 962 | 0.68 (0.64 to 0.71)^**^ | 0.67 (0.63 to 0.71)^**^ | -0.01 (NR to NR)^**^ | NR
Model development: FRS variables | ERFC, 2012^65^ | ERFC IPD MA | Hard CHD | All Participants | 165,586 | NR | NR (NR to NR) | 0.0051^*^ (0.0035^*^ to 0.0066^*^) | NR
Model development: FRS variables | Wilson, 2005^85^ | FHS and Framingham offspring | Hard CHD | All Participants | 4,446 | 0.80 (0.77 to 0.83) | 0.80 (0.77 to 0.83) | 0 (NR to NR) | NR
Model development: FRS variables | Wilson, 2008^107^ | Framingham Offspring | Hard CHD | All Participants | 3,006 | 0.863 (NR to NR) | 0.865 (NR to NR) | 0.002 (NR to NR) | NR
Model development: FRS variables | Rodondi, 2010^81^ | Health ABC | Hard CHD | All Participants | 1,515 | 0.600 (NR to NR) | 0.592 (NR to NR) | -0.008 (NR to NR) | NR
Model development: FRS variables | Mohlenkamp, 2011^103^ | Heinz Nixdorf Recall (HNR) | Hard CHD | All Participants | 3,966 | 0.719 (0.671 to 0.767) | 0.732 (0.684 to 0.780) | 0.013 (NR to NR) | 0.12
Model development: FRS variables | Shah, 2009^78^ | Northwick Park Heart Study ǁ | Hard CHD | All Participants | 2,479 | 0.62 (0.60 to 0.65)^**^ | 0.66 (0.63 to 0.68)^**^ | 0.04 (NR to NR)^**^ | NR
Model development: FRS variables | Sattar, 2007^108^ | PROSPER | Hard CHD | Placebo group only | 1,654^#^ | 0.655 (NR to NR) | 0.663 (NR to NR) | 0.008 (NR to NR) | 0.028
Model development: FRS variables | Danesh, 2004^87^ | Reykjavik | Hard CHD | All Participants | 6,428^††^ | 0.64 (0.63 to 0.65) | 0.65 (0.64 to 0.67) | 0.01 (NR to NR) | NR
Model development: FRS variables | Elias-Smale, 2010^76^ | Rotterdam | Hard CHD | All Participants | 2,028 | 0.72 (NR to NR) | 0.72 (NR to NR) | 0 (NR to NR) | 0.31
Model development: FRS variables | Kavousi, 2012^82^ | Rotterdam | Hard CHD | All Participants | 3,029 | 0.73 (0.71 to 0.75) | NR | 0.00^*^ (-0.01^*^ to 0.00^*^) | NR
Model development: FRS variables | Salim, 2016^109^ | Singapore Chinese Health Study | Hard CHD | Women | 528 | 0.778 (0.729 to 0.827) | 0.780 (0.731 to 0.829) | 0.002 (NR to NR) | NR
Model development: FRS variables | Salim, 2016^109^ | Singapore Chinese Health Study | Hard CHD | Men | 965 | 0.679 (0.644 to 0.714) | 0.689 (0.654 to 0.724) | 0.01 (NR to NR) | NR
Model development: FRS variables | Rana, 2012^99^ | EISNER | Soft CVD | All Participants | 1,286 | 0.73 (0.66 to 0.82) | 0.73 (0.65 to 0.82) | 0 (NR to NR) | 0.95
Model development: FRS variables | Wilson, 2005^85^ | FHS and Framingham offspring | Soft CVD | All Participants | 4,446 | 0.78 (0.76 to 0.80) | 0.78 (0.76 to 0.80) | 0 (NR to NR) | NR
Model development: FRS variables | Wilson, 2008^107^ | Framingham Offspring | Soft CVD | All Participants | 3,006 | 0.795 (NR to NR) | 0.799 (NR to NR) | 0.004 (NR to NR) | NR
Model development: FRS variables | Seven, 2015^92^ | Inter99 | Soft CVD^‡‡^ | All Participants | 6,138^§§^ | 0.697 (NR to NR) | 0.701 (NR to NR) | 0.004 (NR to NR) | 0.26
Model development: FRS variables | Yeboah, 2012^75^ | MESA | Soft CVD | Intermediate Risk | 1,330 | 0.623 (NR to NR) | 0.640 (NR to NR) | 0.017 (NR to NR) | 0.03
Model development: FRS variables | Cook, 2006^83^ | WHS (WHS model)ǁǁ | Soft CVD | All Participants | 15,048 | 0.811 (NR to NR) | 0.813 (NR to NR) | 0.002 (NR to NR) | NR
Model development: FRS variables | Cook, 2006^83^ | WHS (ATP III full recalibration)¶¶ | Soft CVD | All Participants | 26,927 | 0.809 (NR to NR) | 0.810 (NR to NR) | 0.001 (NR to NR) | NR
Model development: FRS variables | Welsh, 2013^98^ | WOSCOPS | Soft CVD | All Participants | 4,128 | 0.582 (0.57 to 0.60)^##^ | 0.588 (0.57 to 0.60)^##^ | 0.006 (NR to NR)^##^ | <0.001
Model development: FRS variables | Folsom, 2006^110^ | ARIC | Soft CHD | All Participants | 1,511 | 0.767 (NR to NR) | 0.770 (NR to NR) | 0.003^*^ (NR to NR) | >0.05
Model development: FRS variables | Rodondi, 2010^81^ | Health ABC | Soft CHD | All Participants | 1,515 | 0.611 (NR to NR) | 0.622 (NR to NR) | 0.011 (NR to NR) | NR
Model development: FRS variables | Yeboah, 2012^75^ | MESA | Soft CHD | Intermediate Risk | 1,330 | 0.623 (NR to NR) | 0.640 (NR to NR) | 0.017 (NR to NR) | 0.03
Model development: FRS variables | Schneider, 2012^100^ | Study of Health in Pomerania | Fatal CVD | All participants | 3,602 | 0.898 (0.873 to 0.923) | 0.906 (0.881 to 0.93) | 0.008 (NR to NR) | NR

* Calculated as Extended-Base except where noted; asterisk indicates reported (not calculated) change

† Recalibrated by including the PCE in the Cox model predicting Hard CVD and used baseline survival estimated from MESA data; similar procedure used for FRS model predicting hard CHD events

‡ FRS entered categorically, not continuously. 3-category model abstracted.

§ Authors also report AUC and p-value for FRS model stratified into 5 risk categories: base model AUC=0.735, extended model AUC=0.750; p=0.0163.

ǁ Table 7, which calculates FRS as published by D’Agostino, shows that tertiles of CRP were able to discriminate in low-risk individuals (<10% 10-yr risk) but not intermediate or high-risk individuals.

¶ Only studies with information on all subgroups used.

# Reported in Table 3 of Shepherd, 2002.

** Sensitivity analyses conducted using AUC instead of Harrell’s c gave similar results.

†† No change in findings when 376 (5.8%) of participants with baseline ECG abnormalities or angina were excluded from analysis (data not shown)

‡‡ Assumed since primary outcome

§§ Assumed from Table 5

ǁǁ For generalizability, predicted probabilities were calibrated to observed risk from the Framingham Heart Study.

## C-statistics take into account competing risk of non-CVD death

*** Exploratory subgroup analyses

††† Hard CVD defined as fatal or nonfatal MI or CVA or CVD mortality; hard CHD defined as fatal or nonfatal MI or CHD mortality; soft CVD could additionally include angina, revascularization, TIA or claudication in composites defined by the study. Similarly, hard CHD could additionally include angina or coronary revascularization in composites defined by the study.

Abbreviations: ABI = ankle-brachial index; AIC = Akaike information criterion; ARIC = Atherosclerosis Risk in Communities study; BIC = Bayesian information criterion; CAC = coronary artery calcium; CHD = coronary heart disease; CI = confidence interval; CVD = cardiovascular disease; EPIC = European Prospective Investigation into Cancer and Nutrition; ERFC IPD MA= Emerging Risk Factors Collaboration individual participant data meta-analysis; FRS = Framingham Risk Score; F/U = follow up; Health ABC = Health, Aging, and Body Composition study; HNR = Heinz Nixdorf Recall study; HRT = hormone replacement therapy; hsCRP = high sensitivity C-reactive protein; HTN = hypertension; MESA = Multi-Ethnic Study of Atherosclerosis; mg/L = milligrams per Liter; MONICA = MONItoring of trends and determinants in CArdiovascular disease; NPHS = Northwick Park Heart Study; NR = not reported; PROSPER = Prospective Study of Pravastatin in the Elderly at Risk; SHIP = the Study of Health in Pomerania; WHS = Women’s Health Study; WOSCOPS = the West of Scotland Coronary Prevention Study

Published coefficient models. The one published coefficient model evaluating the addition of hsCRP to the PCE had a base model discrimination of 0.74.^90^ Base model discrimination in published coefficient models for the FRS ranged from 0.59 to 0.777.^105^ The one published coefficient model evaluating the addition of hsCRP to the PCE in the multiethnic MESA cohort showed no change in discrimination when hsCRP was added; this model was recalibrated to the local population.^90^ Similarly, when hsCRP was added to a recalibrated FRS base model in the MESA population, no change in discrimination was detected. Of note, participants taking statins were excluded in this analysis; therefore, about 95 percent of the population was at low risk, defined as 10-year CHD risk of 10 percent or less. In other studies using a published coefficient FRS as a base model, the change in c-statistic showed mixed results. The largest improvements occurred in the EPIC-Norfolk case-control analysis (0.03 [95% CI, 0.01 to 0.05])^104^ and MONICA-Augsburg (0.027, p=0.0077).^84^ Because of study design considerations, these could be considered upper bounds of change in discrimination. The case-control design of the EPIC-Norfolk analysis likely reduced the base model c-statistics (because of reduced variation from the process and matching for sex and age), and thus likely overstated the change from the addition of hsCRP to the model.^128^ The MONICA-Augsburg analysis entered the FRS categorically instead of continuously in prediction models, which will underestimate the prognostic value of the FRS and overestimate the value of hsCRP.^63^

The MONICA-Copenhagen analysis showed a very small but statistically significant improvement in discrimination of 0.012 (p=0.037) in men, but improvement was not statistically significant in women (0.007, p=0.262).^96^ An analysis of only women from the Framingham Offspring Study showed similar results.^97^ An analysis from the Scottish Health Survey showed that the addition of hsCRP to published coefficient FRS base models resulted in very small improvements in discrimination for all outcomes evaluated, ranging from 0.002 to 0.004, but neither statistical significance nor confidence intervals were reported. Two studies reported discrimination for intermediate-risk subgroups, both defined by 10-year CHD risk of 10 to 20 percent.^97,^ ^104^ In both studies, the statistical significance of results in intermediate-risk groups were concordant with that of the overall population in the study (i.e., significant for EPIC-Norfolk in the context of a poorly discriminating base model and not significant in women from the Framingham Offspring cohort), but showed a markedly larger change in c-statistic.

Model development studies. Similar to published coefficient models, base model discrimination in model development studies showed a wide range. In the Emerging Risk Factors Collaboration IPD meta-analysis, which involved 166,596 participants and 13,568 hard CVD events, base model discrimination was 0.714.^65^ In other model development studies, discrimination ranged from 0.58 to 0.863 in models predicting hard CHD or hard CVD.

In the Emerging Risk Factors Collaboration IPD meta-analysis models, the addition of hsCRP to the base model increased discrimination by 0.0039 (95% CI, 0.0028 to 0.0050) for hard CVD and by 0.0051 (95% CI, 0.0035 to 0.0066) for hard CHD. Exploratory subgroup analyses suggest effect modification by sex, where the improvement in discrimination of hsCRP is greater in men than women. This analysis showed a very small, statistically significant improvement in men and no change in women; the p-value for heterogeneity was less than 0.001. Analyses by diabetes status suggested no effect modification, and analyses by 10-year risk for CVD suggested that the intermediate-risk group (defined as 10-20% 10-year risk) may have a larger change in the c-statistic when compared with the low-risk group (less than 10% 10-year risk), but confidence intervals overlapped.

Of the 11 cohorts not represented in the Emerging Risk Factors Collaboration IPD meta-analysis, 9 were model development studies.^78,^ ^81,^ ^85,^ ^92,^ ^99,^ ^100,^ ^102,^ ^103,^ ^109^ Changes in discrimination in these studies ranged from -0.008 for a model predicting hard CHD in the Health ABC study of older adults^81^ to 0.04 for hard CHD in the Northwick Park Heart Study, which exclusively recruited men.^78^ Statistical significance or confidence intervals were rarely reported; when they were, no improvements in discrimination were statistically significant. Concordant with findings from the IPD meta-analysis, a nested case-control study from the Singapore Chinese Health Study suggested that the improvement in discrimination from the addition of hsCRP to risk prediction models was larger in men (but still very small) than women (0.01 vs 0.002); however, confidence intervals for change in c-statistic were not reported.^109^ The base model had poorer initial discrimination in men than women (0.679 vs 0.778), allowing for more opportunity for improvement. Yeboah and colleagues^75^ evaluated a subset of intermediate-risk participants from MESA (defined as those between 5 and 20% 10-year CHD risk) and found a very small, statistically significant improvement in discrimination for both soft CVD and soft CHD outcomes (0.017; p=0.03); base model discrimination was 0.623.

##### Risk Reclassification

Fifteen of 25 studies evaluated reclassification from hsCRP when added to traditional cardiovascular risk factors, encompassing data from 33 cohorts (22 of which were represented in the Emerging Risk Factors Collaboration IPD meta-analysis) (Table 22). One study addressed the addition of hsCRP to a recalibrated PCE, which used a risk threshold of 7.5 percent or greater 10-year risk for hard CVD; this study showed no statistically significant reclassification. In FRS-based models, low risk was typically defined as less than 10 percent 10-year risk for a CVD or CHD event, although was sometimes defined as less than 6 percent. Intermediate risk was generally defined as 10 to 15 percent, or 10 to 20 percent 10-year risk, although it sometimes had a lower bound of 6 percent. High risk was usually defined as greater than 20 percent 10-year risk, and sometimes greater than 15 percent. The one PCE-based analysis used a risk threshold of 7.5 percent or greater 1-year risk for a hard CVD event. Findings for NRI were somewhat inconsistent. The Emerging Risk Factors Collaboration IPD meta-analysis represents the most expansive evidence and showed an NRI no greater than 0.02. The IPD meta-analysis and several smaller studies suggest that improvement in risk reclassification occurs in men but not women, and is driven by improvement in those having events being reclassified to higher-risk categories. When a bias-corrected NRI_int_ could be calculated, NRI_int_ were usually slightly higher than the NRI for overall population, and statistical significance was sometimes maintained.

Table 22 Reclassification Outcomes in Included hsCRP Risk Prediction Studies (KQ2)

Model type: Base model | Author, Year | Study name | N | Outcome ### | Subgroup | Total NRI (95% CI) | Event NRI (95% CI) | Nonevent NRI (95% CI) | Risk categories (High, Intermediate, Low) 10 yr-risk
Published coefficient: PCE | Yeboah, 2016^90^ | MESA | 5,185 | Hard CVD | All Participants | 0.024 (-0.015 to 0.067)^*^ | 0.028 (-0.013 to 0.077)^*^ | -0.005 (-0.015 to 0.003)^*^ | ≥7.5%, <7.5%
Published coefficient: FRS | Lyngbaek, 2013^96^ | MONICA - Copenhagen | 1,168 | Hard CVD | Women | -0.083 (-0.354 to 0.189) | NR | NR | Continuous NRI
Published coefficient: FRS | Lyngbaek, 2013^96^ | MONICA - Copenhagen | 1,147 | Hard CVD | Men | 0.308 (0.081 to 0.534) | NR | NR | Continuous NRI
Published coefficient: FRS | Yeboah, 2016^90^ | MESA | 5,185 | Hard CHD | All Participants | 0.003 (-0.028 to 0.026) | 0.005 (-0.027 to 0.027) | -0.002 (-0.007 to 0.001) | >20%, 10-20%, <10%
Published coefficient: FRS | Yeboah, 2016^90^ | MESA | 204 | Hard CHD | Intermediate Risk | -0.003 (-0.138 to 0.132)^‡^ | NR | NR | >20%, 10-20%, <10%
Published coefficient: FRS | Rana, 2009^104^ | EPIC-Norfolk | 2,550 | Soft CHD | All Participants | 0.120 (NR to NR) | 0.021 (NR to NR) | 0.099 (NR to NR) | >20%, 10-20%, <10%
Published coefficient: FRS | Rana, 2009^104^ | EPIC-Norfolk | 1,008 | Soft CHD | Intermediate Risk | 0.284 (NR to NR) | 0.129 (NR to NR) | 0.155 (NR to NR) | >20%, 10-20%, <10%
Model development: FRS variables | Wannamethee, 2011^102^ | British Regional Heart Study | 2,854 | Hard CVD | All Participants | 0.063 (0.019 to 0.108)^§^ | 0.056 (0.014 to 0.097) | 0.008 (-0.008 to 0.023) | ≥20%, 10-19%, <10%^***^
Model development: FRS variables | Wannamethee, 2011^102^ | British Regional Heart Study | 1,005 | Hard CVD | Intermediate Risk | 0.094 (0.003 to 0.185)^‡^ | NR | NR | ≥20%, 10-19%, <10%^***^
Model development: FRS variables | ERFC, 2012^65^ | ERFC IPD MA ǁ | 72,574 | Hard CVD | All Participants | 0.0152 (0.0078 to 0.0227) | 0.0146 (0.0073 to 0.0219) | 0.0006 (-0.0009 to 0.0022) | ≥20%, 10-20%, <10%^***^
Model development: FRS variables | ERFC, 2012^65^ | ERFC IPD MA | 10,412 | Hard CVD | Intermediate Risk | 0.027 (0.007 to 0.047)^‡^ | NR | NR | ≥20%, 10-20%, <10%^***^
Model development: FRS variables | ERFC, 2012^65^ | ERFC IPD MA ǁ | 25,157 | Hard CVD | Women | 0.0036 (-0.007 to 0.0142) | NR | NR | ≥20%, 10-20%, <10%^***^
Model development: FRS variables | ERFC, 2012^65^ | ERFC IPD MA ¶ | 19,467 | Hard CVD | Men | 0.0124 (-0.002 to 0.0269) | NR | NR | ≥20%, 10-20%, <10%^***^
Model development: FRS variables | Shah, 2009^78^ | Edinburgh Artery Study | 919 | Hard CHD | All Participants | 0.088 (-0.013 to 0.189) | 0.035 (-0.594 to 0.130)^#^ | 0.053 (0.016 to 0.089)^#^ | ≥15%, 10-15%, 5-10%, 0-<5%
Model development: FRS variables | Shah^78^, 2009 | Edinburgh Artery Study | 919 | Hard CHD | All Participants | 0.03 (-0.030 to 0.092) | 0.042 (-0.016 to 0.101)^#^ | -0.012 (-0.029 to 0.006)^#^ | ≥15%, 0-15%
Model development: FRS variables | Shah, 2009^78^ | Edinburgh Artery Study | 532 | Hard CHD | Intermediate Risk | 0.103 (-0.038 to 0.243)^‡^ | NR | NR | ≥15%, 10-15%, 5-10%, 0-<5%
Model development: FRS variables | Wilson, 2008^107^ | Framingham Offspring | 3,006 | Hard CHD | All Participants | 0.1177 (0.030 to 0.205)^**^ | 0.1091 (0.022 to 0.196)^**^ | 0.0086 (0.0003 to 0.017)^**^ | ≥20%, 6-20%, 0-6%^†††^
Model development: FRS variables | Wlson, 2008^107^ | Framingham Offspring | 448 | Hard CHD | Intermediate Risk | 0.130 (-0.005 to 0.265)^‡^ | NR | NR | ≥20%, 6-20%, 0-6%^†††^
Model development: FRS variables | Mohlenkamp, 2011^103^ | Heinz Nixdorf Recall (HNR) | 3,966 | Hard CHD | All Participants | 0.105 (NR to NR); p=0.026 | NR | NR | >20%, 10-20%, <10%
Model development: FRS variables | Shah, 2009^78^ | Northwick Park Heart Study ǁ | 2,412 | Hard CHD | All Participants | 0.085 (-0.013 to 0.183) | 0.088 (-0.007 to 0.184)^#^ | -0.003 (-0.025 to 0.020)^#^ | ≥15%, 10-15%, 5-10%, 0-<5%
Model development: FRS variables | Shah, 2009^78^ | Northw ick Park Heart Study ǁ | 2,412 | Hard CHD | All Participants | 0.049 (0.008 to 0.090) | 0.057 (0.016 to 0.098)^#^ | -0.008 (-0.014 to -0.001)^#^ | ≥15%, 0-15%
Model development: FRS variables | Shah, 2009^78^ | Northwick Park Heart Study ǁ | 1,235 | Hard CHD | Intermediate Risk | 0.076 (-0.065 to 0.216)^‡^ | NR | NR | ≥15%, 10-15%, 5-10%, 0-<5%
Model development: FRS variables | Kavousi, 2012^82^ | Rotterdam | 3,029 | Hard CHD | All Participants | 0.020 (-0.023 to 0.064) | NR | NR | ≥20%, 10-20%, <10%
Model development: FRS variables | Kavousi, 2012^82^ | Rotterdam | NR | Hard CHD | Intermediate Risk | 0.092 (0.002 to 0.180) | 0.019 (NR to NR)^‡‡^ | 0.073 (NR to NR)^‡‡^ | ≥20%, 10-20%, <10%
Model development: FRS variables | Salim, 2016^109^ | Singapore Chinese Health Study | 528 | Hard CHD | Women | NR | 0.015 (NR to NR); p=0.157^§§^ | 0.000 (NR to NR); p=1.0^§§^ | ≥20%, 10-20%, <10%
Model development: FRS variables | Salim, 2016^109^ | Singapore Chinese Health Study | 965 | Hard CHD | Men | NR | 0.032 (NR to NR); p=0.020^§§^ | 0.002 (NR to NR); p=0.759^§§^ | ≥20%, 10-20%, <10%
Model development: FRS variables | Wilson, 2008^107^ | Framingham Offspring | 3,006 | Soft CVD | All Participants | 0.0559 (0.011 to 0.100)ǁ | 0.0498 (0.007 to 0.093)ǁǁ | 0.0061 (-0.005 to 0.018)ǁǁ | ≥20%, 6-20%, 0-6%^†††^
Model development: FRS variables | Wilson, 2008^107^ | Framingham Offspring | 1,042 | Soft CVD | Intermediate Risk | 0.058 (-0.015 to 0.131)^‡^ | NR | NR | ≥20%, 6-20%, 0-6%^†††^
Model development: FRS variables | Seven, 2015^92^ | Inter99 | 6,138 | Soft CVD^¶¶^ | All Participants | 0.039 (NR to NR); p=0.012 | NR | NR | >15%, 5-15%, <5%^§§§^
Model development: FRS variables | Yeboah, 2012^75^ | MESA | 1,330 | Soft CVD | Intermediate Risk | 0.037 (NR to NR) | 0.016 (NR to NR) | 0.021 (NR to NR) | <3.4%, 3.4 to 21.1%, >21.1%ǁǁǁ
Model development: FRS variables | Welsh, 2013^98^ | WOSCOPS | 4,128 | Soft CVD | All Participants | 0.010 (0.002 to 0.018) | NR | NR | ≥20%, <20%^***^
Model development: FRS variables | Welsh, 2013^98^ | WOSCOPS | 4,128 | Soft CVD | All Participants | 0.065 (-0.001 to 0.129) | 0.017 (NR to NR) | 0.048 (NR to NR) | Continuous NRI of improvements across integer % thresholds for >0% risk
Model development: FRS variables | Rodondi, 2010^81^ | Health ABC | NA | Soft CHD | All Participants | NR^##^ | NR^##^ | NR^##^ | ≥20%, 10 to <20%, <10%
Model development: FRS variables | Yeboah, 2012^75^ | MESA | 1,330 | Soft CHD | Intermediate Risk | 0.079 (NR to NR) | 0.043 (NR to NR) | 0.036 (NR to NR) | <2.0%, 2.0 to 15.4%, >15.4%ǁǁǁ
Model development: FRS variables | Schneider, 2012^100^ | Study of Health in Pomerania | 3,602 | Fatal CVD | All Participants | 0.0471 (-0.0270 to 0.1592) | NR | NR | SCORE >9%, 2-9%, <2%^¶¶¶^

* Sensitivity analysis using 3 categories (0-5%, 5-7.5%, >7.5%) produced similar results

† Category-free NRI

‡ Bias-corrected NRI_INT_ calculated using simple variance method

§ Using calculated overall NRI instead of reported NRI because there are internal inconsistencies and % calculation errors in the reclassification table (reported NRI=0.038, p=0.07).

ǁ Reclassification data is from 22 studies with >10 yrs F/U reporting both fatal and nonfatal CVD events.

¶ Based on 15 studies with at least 10 years of followup in both men and women (2784/19467 first CV events in men; 2323/25157 first CV events in women). Discussion states that subpopulation analyses were exploratory.

# CIs calculated for event and nonevent NRI.

** CIs were calculated for overall, event, and nonevent NRI using simple variance method. Reported NRI are statistically adjusted from 12 years to 10 years of followup interval which resulted in smaller number of events, n=110 (instead of 129 events at 12-years).

‡‡ Event and nonevent NRI calculated

§§ Reported as ‘case NRI’ and ‘noncase NRI’; because of case-control design we did not combine to calculate total NRI

ǁǁ CIs were calculated for overall, event, and nonevent NRI using simple variance method. Reported NRI are statistically adjusted from 12 years to 10 years of followup interval which resulted in smaller number of events, n=241 (instead of 286 events at 12-years).

¶¶ Assumed since the primary outcome

## Not reported because CRP was not strongly related with CHD events and did not improve global measures of predictive accuracy.

*** 10-yr CVD risk

††† 10-yr CHD risk

§§§ time horizon NR

ǁǁǁ 7.5-yr risk

¶¶¶ 10-yr risk of fatal CVD

### Hard CVD defined as fatal or nonfatal MI or CVA or CVD mortality; hard CHD defined as fatal or nonfatal MI or CHD mortality; soft CVD could additionally include angina, revascularization, TIA or claudication in composites defined by the study. Similarly, hard CHD could additionally include angina or coronary revascularization in composites defined by the study.

Abbreviations: ABI = ankle-brachial index; ARIC = Atherosclerosis Risk in Communities study; CAC = coronary artery calcium; CHD = coronary heart disease; CI = confidence interval; CVD = cardiovascular disease; EPIC = European Prospective Investigation into Cancer and Nutrition; ERFC IPD MA= Emerging Risk Factors Collaboration individual participant data meta-analysis; FRS=Framingham Risk Score; F/U = follow up; Health ABC = Health, Aging, and Body Composition study; HNR = Heinz Nixdorf Recall study; hsCRP = high sensitivity C-reactive protein; HRT = hormone replacement therapy; hsCRP = high sensitivity C-reactive protein; HTN = hypertension; MESA = Multi-Ethnic Study of Atherosclerosis; mg/L = milligrams per Liter; MONICA = MONItoring of trends and determinants in CArdiovascular disease; NPHS = Northwick Park Heart Study; NR = not reported; NRI = net reclassification improvement; PROSPER = Prospective Study of Pravastatin in the Elderly at Risk; SHIP = the Study of Health in Pomerania; WHS = Women’s Health Study; WOSCOPS = the West of Scotland Coronary Prevention Study; yr = year

Published coefficient models. Three published coefficient studies evaluating four models offer inconsistent evidence about the added value of hsCRP to improve reclassification of risk compared to the FRS or PCE. The published coefficient analyses of recalibrated PCE and FRS models by Yeboah and colleagues^90^ showed no statistically significant improvement in NRI for either model (PCE: 0.024 [95% CI, -0.015 to 0.067], FRS: 0.003 [95% CI, -0.028 to 0.026]). We calculated a bias-corrected NRI_int_ for the FRS intermediate-risk group, which similarly showed no significant improvement. Similar to findings for discrimination outcomes in MONICA-Copenhagen, men achieved a statistically significant improvement in continuous NRI, whereas women did not (men: 0.308 [95% CI, 0.081 to 0.534]; women: -0.083 [95% CI, -0.354 to 0.189]).^96^ Continuous NRI should not be directly compared to NRI using defined risk strata. The case-control analysis of the EPIC-Norfolk study suggests that hsCRP can reclassify individuals (NRI 0.120) but did not report statistical significance or confidence intervals.^104^ IDI was reported only in the MONICA-Copenhagen analysis, and the sex-specific findings of improvement in men but not women were consistent (Appendix E Table 2).

While two studies using published coefficients report NRI for individuals at intermediate risk for CHD or CVD events, one study did not allow for calculation of a bias-corrected NRI_int_ (and did not report statistical significance),^104^ and the other study found nonstatistically significant results. However, this study had only 27 hard CHD events in the intermediate-risk group.^90^

Model development. The Emerging Risk Factors Collaboration IPD meta-analysis calculated NRI in 22 of 38 included cohorts that had 10 or more years of followup and that reported data for both fatal and nonfatal CVD events.^65^ The overall NRI was 0.0152 (95% CI, 0.0078 to 0.0227) and was driven by improvement in event NRI (0.0146 [95% CI, 0.0073 to 0.0219]). Sex-specific analyses were conducted in 15 studies that included both men and women, and provide some confirmatory evidence for the MONICA-Copenhagen published coefficient study showing that the benefit in risk reclassification from the addition of hsCRP accrues in men but not in women. In the IPD meta-analysis, the NRI for men was 0.0124 (95% CI, -0.0020 to 0.0269) and for women was 0.0036 (95% CI, -0.0070 to 0.0142); neither result was statistically significant and subgroup analyses were exploratory (no formal interaction testing was reported).

Additional reclassification data are available from nine model development studies in cohorts not analyzed in the Emerging Risk Factors Collaboration analyses of NRI (cohorts included in IPD MA analyses of reclassification are a subset of included cohorts, restricted to those with greater than 10 years of followup and recording both fatal and nonfatal events).^75,^ ^78,^ ^92,^ ^98,^ ^100,^ ^102,^ ^103,^ ^107,^ ^109^ Overall, these studies had mixed findings. The smallest NRI of 0.010 (95% CI, 0.002 to 0.018) was from a two-category analysis with a risk threshold of 20 percent or greater, reported in a primary prevention subgroup of exclusively men from a statin RCT.^98^ The largest reclassification, NRI 0.1177 (95% CI, 0.030 to 0.205), was seen in an analysis of the Framingham Offspring cohort of which 82.5 percent of the population were low risk (defined as less than 6% 10-year risk).^107^ The Health ABC cohort of older adults evaluated the additional predictive value of hsCRP added to traditional risk factors, but reclassification was not reported because hsCRP was not statistically significantly associated with soft CHD events after adjustment for traditional cardiovascular risk factors.^81^ The case-control analysis from the Singapore Chinese Health Study is concordant with findings from the Emerging Risk Factors Collaboration IPD meta-analysis in that event NRI was substantially larger than nonevent NRI, and that reclassification improved significantly in men, but not women.^109^ One study, NHPSII, had a statistically significant negative nonevent NRI (-0.008 [95% CI, -0.014 to -0.001), meaning that more participants not having events were reclassified inappropriately upward; this analysis is based on a 10-year risk threshold of 15 percent.^78^ We explored whether results varied by predicted outcome, definitions of risk strata, or case mix. These variables did not appear to explain differences in across studies; however, such comparisons are limited by several concurrent sources of heterogeneity. Four model development studies reported IDI (Appendix E Table 2). The IDI was statistically significant in 2 of 4 studies, and where significant, was no greater than 0.02.

NRI_int_ is available in six model development studies, including the Emerging Risk Factors Collaboration IPD meta-analysis. In the IPD meta-analysis, a bias-corrected NRI_int_ was slightly larger than for the overall population and retained statistical significance: NRI_int_ 0.027 (95% CI, 0.007 to 0.047) and NRI 0.0152 (95% CI, 0.0078 to 0.0227).^65^ Other model development studies where a bias correction could be performed showed larger NRI_int_ than in the Emerging Risk Factors Collaboration IPD meta-analysis, and larger reclassification when evaluated to the overall population in each respective study: NRI_int_ for hard events ranged from 0.076 to 0.130.^78,^ ^102,^ ^107^ Statistical significance was only maintained in some studies, likely due to greatly reduced power when evaluating a smaller subset of participants. The NRI_int_ in the Rotterdam study could not be bias-corrected based on reported information.

### Detailed Results for CAC

#### Description of Cohorts

We included 19 unique studies that examined whether CAC added to traditional CVD risk assessment could improve calibration, discrimination, or risk reclassification (Table 23). These studies include data from 10 different cohorts. In total, 24 different models were evaluated (Table 24). Six studies evaluated eight different models using published coefficients for the PCE or FRS. Thirteen studies reported the results of newly developed models based on FRS variables (three studies using the MESA cohort evaluated models which included race/ethnicity as a predictor^77,^ ^101,^ ^113^), and two studies reported the results of newly developed models based on PCE variables. Ten models predicted CVD outcomes and 17 predicted CHD. Sixteen models predicted hard outcomes (CVD or CHD), 7 models predicted soft outcomes (CVD or CHD), and 1 model predicted only fatal CVD outcomes.

Table 23 Study Design and Participant Characteristics in Included CAC Risk Prediction Studies (KQ2)

Author,Year | Model type: Base model | Study name | Country | N | F/U, mean (yrs); Range | Mean Age | % Women | % White | % DM | % HTN (% treated) | % Hyperlipidemia % treated) | % Current smoker | Mean CAC score | Ele vated CAC score threshok (% elevated CAC score)
Yeboah, 2016^†^,^90^ | Published coefficient: PCE | MESA | United States | 5,185 | 10; NR | 61.2 | 53.1 | 38 | 9.8 | NR (32.5) | NR (0) | 13.6 | 0^§^ | NR (NR)
Fudim, 2016^112^ | Published coefficient: PCE | MESA | United States | 6,742 | 7.5^§^; NR | 62.0 | 52.7 | 38.5 | NR | NR (NR) | NR (NR) | NR | NR | NR (NR)
Geisel, 2017^114^ | Published coefficient: FRS | HNR | Germany | 3,108 | 10.3; NR | 59.2 | 52.9 | NR | 11.5 | NR (31.6) | NR (9.2) | 22.6 | 11.3^§^ | ≥100 (26.5)
Yeboah, 2016^†^,^90^ | Published coefficient: FRS | MESA | United States | 5,185 | 10; NR | 61.2 | 53.1 | 38 | 9.8 | NR (32.5) | NR (0) | 13.6 | 0^§^ | NR (NR)
Erbel, 2010^74^ | Published coefficient: FRS | HNR | Germany | 4,129 | 5.1; NR | 59.4 | 52.7 | NR | 7.4 | 38.2 (32.1) | 45.6^#^ (9) | 22.8 | 168.3 | ≥400 (10.2)
Wong, 2009^106^ | Published coefficient: FRS | EISNER + Cardiac Research Databaseǁǁǁǁ | United States | 2,303 | 4.4; 0.8 to 7.8 | 55.7 | 38 | NR^‡‡^ | 7 | NR (NR) | NR (NR) | 7 | NR | ≥400 (8.2)
Greenland, 2004^86^ | Published coefficient: FRS | South Bay Heart Watch | United States | 1,029 | 6.3; 0.12 to 8.5 | 65.7 | 9.9 | 84.9 | 0 | 41.4 (NR) | NR (NR) | 17.7 | NR | ≥301 (21.5)
Kavousi, 2016^111^ | Model development: PCE variables | Pooled Analysis of 5 Cohorts ¶¶¶ of Low Risk Women (<7.5% 10-yr PCE risk) | United States, Germany, Netherlands | 6,739 | 10 5*****; 7.0 to 11.6 | 54.1 | 100 | NR | 4.8 | NR (17.2) | NR (0) | 13.7 | 0.24^§^ | >0 (36.1)
Bos, 2015^89^ | Model development: PCE variables | Rotterdam | Netherlands | 2,408 | 6.6^***^;NR | 69.5 | 52.4 | NR | 12.5 | 73.8 (39.3) | 48.6^#^ (22.8) | 15.4 | 52.3^§,†††^ | Prevalence of any CAC (82.1)
Polak, 2017^113^ | Model development: FRS variables | MESA | United States | 6,500 | 10.2^§^; 97 to 10.7 (IQR) | 62.1 | 52.6 | 38.9 | 9.5 | NR (36.5) | NR (16.1) | 13.1 | NR | >0 (50.1)
Kavousi, 2016^111^ | Model development: FRS variables | Pooled Analysis of 5 Cohorts ¶¶¶ of Low Risk Women (<10% 10-yr FRS risk) | United States, Germany, Netherlands | 7,772 | 10 5*****; 7.0 to 11.6 | 54.1 | 100 | NR | 4.8^####^ | NR (17.2) | NR (0) | 13.7 | 0.24^§^ | >0 (36.1)
Hoffmann, 2016^88^ | Model development: FRS variables | Framingham Heart Study Offspring and 3rd Generation | United States | 3,486ǁǁ | 8; NR | 50 | 50.9 | 100 | 5.3 | 42.9 (16.2) | 21.4 (11.5) | 12.5 | 0^§,¶¶^ | >300^¶¶^ (8.1)
Chang, 2015^93^ | Model development: FRS variables ‡‡‡ | Houston Methodist DeBakey Heart and Vascular Center cohort | United States | 946^§§§^ | 6.9^§^; 4.7-8.8 (IQR) | 57.5 | 24.7 | NR | 9.6 | 49.6(NR) | 57.1(NR) | 46.5 | 118^§^ | >400 (25.2)
Yeboah, 2014ǁǁǁ^94^ | Model development: FRS variables | MESA and HNR | United States and Germany | 1,343 | 8.5; NR | 63 | 44 | 53 | 100 | NR (59) | NR (23) | 16 | 272 | >400 (NR)
Yeboah, 2012^75,†^ | Model development: FRS variables | MESA | United States | 1,330 | 7.6^§^; 7.3-7.8 (IQR) | 63.8 | 33.3 | 35.7 | 0 | NR (38.2) | NR (14.1) | 16.5 | 7.0^§^ | NR (NR)
Kavousi, 2012^†^,^82^ | Model development: FRS variables | Rotterdam | Netherlands | 3,678 | 6.8^§^; 5.8-8.1 (IQR) | 69.1 | 59.4 | NR | 12.9 | NR (23.5) | NR (10.2) | 17.5 | 65.8^§^ | NR (NR)
Rana, 2012^###^,^99^ | Model development: FRS variables | BSNER | United States | 1,286 | 4.1; NR | 58.6 | 47.2 | NR | 8.1 | 57.9 (NR) | NR (NR) | 5.4 | 116.3 | NR (NR)
Malik, 2011^101^ | Model development: FRS variables | MESA | United States | 6,603 | 6.4^§^; 0-7.8 | 62.9 | 52.6 | 38.4 | 13.3 †††† | 44.7 (37) | 37.0 (15.8) | 13 | 146.8 | ≥400 (10)
Mohlenkamp, 2011^###^,^103^ | Model development: FRS variables | HNR | Germany | 3,966 | 5.1; NR | 59.3 | 52.8 | NR | 7.2 | 54.2 (31.7) | NR (9.1) | 22.6 | 14.9^§^ | ≥100 (26.6)
Erbel, 2010^74^ | Model development: FRS variables | HNR | Germany | 4,129 | 5.1; NR | 59.4 | 52.7 | NR | 7.4 | 38.2 (32.1) | 45.6^#^ (9) | 22.8 | 168.3 | ≥400 (10.2)
Elias-Smale, 2010^###^,^76^ | Model development: FRS variables | Rotterdam | Netherlands | 2,028 | 9.2^§^; 8.3-10.0 (IQR) | 69.6 | 57.4 | NR | NR | NR (27.6) | NR (14) | 16.8 | 84^§^ | Prevalence of any CAC (89.5)
Polonsky, 2010^77^ | Model development: FRS variables | MESA | United States | 5,878 | 5.8^§^; 5.6-5.9 (IQR) | 62 | 54 | NR | 0 | NR(33) | NR (16) | 50 | NR | NR (NR)

† Also a study of ABI and CRP

§ Median

# Defined as TC ≥240 mg/dL or lipid-lowering drugs

‡‡ Reported as “mainly Caucasian”

ǁǁ Baseline participant characteristics are for 3217 participants without CVD

¶¶ Modified Agatston score

*** Estimated from 15773 p-y F/U and N of 2408

††† CAC volume (mm^3^); calcium density not measured

‡‡‡ Authors attempted to calculate FRS as published, but continuous BP and cholesterol measurements not available so these pr edictors were dichotomized (hyperlipidemia defined as TC 200-239 mg/dL and HTN defined as SBP 140-159 mm Hg)

§§§ 16.5% had atypical chest pain

ǁǁǁ ABI and CRP also considered as part of predictor selection during model development, but variables were ultimately not included in the final model based on a priori thresholds, so analyses of these NTRFs not reported

### Also a study of CRP

†††† 25% of population with MetS

ǁǁǁǁ 43% (N=999) of participants from EISNER RCT; 57% (N=1,304) from cardiac research database of physician - or self-referred clinical patients

¶¶¶ Five pooled cohorts: DHS, FHS, HNR, MESA, and Rotterdam

#### Participants with diabetes excluded from the FRS analysis

***** Estimated from median and interquartile range

Abbreviations: ABI = ankle-brachial index; BP = blood pressure; CAC = coronary artery calcium; CHD = coronary heart disease; CI = confidence interval; CVD = cardiovascular disease; DHS = Dallas Heart Study; DM = diabetes mellitus; EISNER = Early Identification of Subclinical Atherosclerosis by Noninvasive Imaging Research; FHS = Framingham Heart Study; FRS = Framingham Risk Score; F/U = follow up; HNR = Heinz Nixdorf Recall study; hsCRP = high sensitivity C-reactive protein; HTN = hypertension; IQR = interquartile range; MESA = Multi-Ethnic Study of Atherosclerosis; MetS = metabolic syndrome; mg/dL = Milligrams per Deciliter; mg/L = milligrams per Liter; NR = not reported; NRI = net reclassification improvement; NTRF = non-traditional risk factor; RCT = randomized controlled trial; SBP = systolic blood pressure; TC = total cholesterol

Table 24 Base Models for Included CAC Risk Prediction Studies (KQ2)

Author, Year | Base model | Study name | Age | Sex | Race/ ethnicity | Smoking | SBP | Anti-HTNTx | TC | HDL | DM | Predicted outcomeǁǁǁ: N (%) | Handling of CAC in extended model
Yeboah, 2016^*^,^90^ | Published coefficient: PCE (Goff, 2014)^†^ | MESA | × | × | × | × | × | × | × | × | × | Hard CVD: 320 (6.2) | Log-transformed; log (CAC+1)
Fudim, 2016^112^ | Published coefficient: PCE | MESA | × | × | × | × | × | × | × | × | × | Hard CVD: 296 (4.4) | Log-transformed; log (CAC+1)
Yeboah, 2016^*^,^90^ | Published coefficient: FRS (D’Agostino, 2001)^†^ | MESA | × | × | | × | ×^†^ | | × | × | × | Hard CHD: 194 (3.7) | Log-transformed; log (CAC+1)
Geisel, 2017^114^ | Published coefficient: FRS | HNR | × | × | | × | × | × | × | × | × | Hard CVD: 223 (7.2) | Log-transformed; log (CAC+1) for discrimination analyses; Categorical: ≥100, <100 for reclassification analyses
Erbel, 2010^74^ | Published coefficient: FRS (Wilson, 1998) | HNR | × | × | | × | ×^‡^ | | | ×^§^ | × | Hard CHD: 93 (2.2) | Log-transformed; log (CAC+1)ǁ
Erbel, 2010^74^ | Published coefficient: FRS (NCEP ATP ǁǁ, 2002)^¶^ | HNR | × | × | | × | × | × | × | × | | Hard CHD: 93 (2.2) | Log-transformed; log (CAC+1)ǁ
Wong, 2009^106^ | Published coefficient: FRS (NCEP ATP ǁǁ, 2002)^#^ | EISNER + Cardiac Research Database | × | × | | × | × | × | × | × | | Hard CHD: 16 (0.7) Soft CVD: 47 (2.0) Soft CHD: 41 (1.8) | Categorical: 0-9, 10-99, 100-399, ≥400^**^
Greenland, 2004^86^ | Published coefficient: FRS (NCEP ATP ǁǁ, 2002) | South Bay Heart Watch | × | × | | × | × | × | × | × | | Hard CHD: 84 (8.2) | Continuous
Kavousi, 2016^111^ | Model development: PCE variables | Pooled analysis of 5 cohorts^§§§^ of low risk womer (<7.5% 10-yr PCE risk) | × | | | × | × | × | × | × | × | Hard CVD: 165 (2.4) | Log-transformed; log (CAC+1)
Bos, 2015^89^ | Model development: PCE variables | Rotterdam | × | × | × | × | × | × | × | × | × | Fatal CVD: 84 (3.5) | Log-transformed; ln (CAC+1)
Polak, 2017^113^ | Model development: FRS variables | MESA | × | × | × | × | × | | × | × | × | Soft CHD: 429 (6.6) | Categorical: 0, >0
Kavousi, 2016^111^ | Model development: FRS variables | Pooled analysis of 5 cohorts^§§§^ of low risk womer (<10%10-yr FRS risk) | × | | | × | × | × | × | × | | Hard CHD: 150 (1.9) | Log-transformed; ln (CAC+1)
Hoffmann, 2016^88^ | Model development: FRS variables (categorical and continuous models) | Framingham Heart Study Offspring and 3rd Generation | × | × | | × | × | × | × | × | × | Hard CHD: 59 (1.7) Hard CVD: 107 (3.1) | Primary analysis: categorical (0, 1-100, 101-300, >300); secondary analysis: log-transformed
Chang, 2015^93^ | Model development: FRS variables^§§^ | Houston Methodist DeBakey Heart and Vascular Center cohort | × | × | | × | × | | × | | × | Soft CHD: 106 (11.2) | Log-transformed
Yeboah, 2014^¶¶^,^94^ | Model development: FRS variables^##^ | MESA and HNR | × | × | | × | × | | × | × | × | Hard CHD: 85 (6.3) | Log-transformed; log(CAC+25)
Yeboah, 2012^75,*^ | Model development: FRS variables | MESA | × | × | × | × | × | × | × | × | | Soft CVD: 123 (9.2) Soft CHD: 94 (7.1) | Log-transformed; ln (CAC+1)
Kavousi, 2012^*^,^82^ | Model development: FRS variables^***^ | Rotterdam | × | × | | × | × | × | × | × | × | Hard CHD: 347 (5.8) | Log-transformed; ln (CAC+1)
Rana, 2012^†††^,^99^ | Model development: FRS variables | EISNER | × | × | | × | × | × | × | × | × | Soft CVD: 35 (2.7) | Log-transformed; log (CAC+1)
Malik, 2011^101^ | Model development: FRS variables | MESA | × | × | × | × | × | × | × | × | | Soft CVD: 410 (6.2) Soft CHD: 299 (4.5) | Continuous^‡‡‡^
Mohlenkamp, 2011^†††^,^103^ | Model development: FRS variables | HNR | × | × | | × | × | | | ×^§^ | × | Hard CHD: 91 (2.3) | Log-transformed; log (CAC+1)
Erbel, 2010^74^ | Model development: FRS variables | HNR | × | × | | × | × | | | ×^§^ | × | Hard CHD: 93 (2.2) | Log-transformed; log (CAC+1)
Elias-Smale, 2010^†††^,^76^ | Model development: FRS variables | Rotterdam | × | × | | × | × | × | × | × | × | Hard CHD: 135 (6.6) | Log-transformed; ln (CAC+1)
Polonsky, 2010^77^ | Model development: FRS variables | MESA | × | × | × | × | × | × | × | × | | Soft CHD: 209 (3.6) | Log-transformed; ln (CAC+1)

* Also a study of ABI and CRP

† Recalibration accomplished by including the PCE (or FRS in that corresponding model) in the Cox model predicting hard CVD events (or hard CHD in FRS model); created a calibrated PCE which used the BL survival estimated from MESA data

‡ BP categories as defined in JNC-V; includes DBP

§ Also included LDL

¶ Analyzed as ATP III categories where persons with risk equivalents (symptomatic carotid stenosis, stroke, PAD, or diabetes) allocated to high-risk group

# Participants with diabetes automatically assigned a risk score of 20% (or higher if so calculated)

** Limited results reported for sensitivity analyses using log-transformed CAC

§§ Authors attempted to calculate FRS as published, but continuous BP and cholesterol measurements not available so these predictors were dichotomized (hyperlipidemia defined as TC 200-239 mg/dL and HTN defined as SBP 140-159 mm Hg)

ǁǁ Assumed log-transformed for relevant analyses, though categorical data used elsewhere in analysis. Patients were classified as having normal (≤10), mild (11 to 100), moderate (101 to 400), or severe (>400) calcification.

¶¶ ABI and CRP also considered as part of predictor selection during model development, but variables were ultimately not included in the final model based on a priori thresholds, so analyses of these NTRFs not reported

## Base model discrimination reported for FRS as published; but not for an extended model of FRS+CAC. Because of poor calibration using the FRS as published in this population, the model was entirely refit with new coefficients.

*** Model additionally included adjustment for CAC scanner type

††† Also a study of CRP

‡‡‡ Assumed that CAC was included as a continuous variable for relevant analyses using “zCAC” which was calculated by subtraction of the mean and division by the SD of each measurement. Categorical CAC included in other analyses (categories defined by 0, 1-99, 100-399, ≥400)

§§§ Five pooled cohorts: DHS, FHS, HNR, MESA, and Rotterdam

ǁǁǁ Hard CVD defined as fatal or nonfatal MI or CVA or CVD mortality; hard CHD defined as fatal or nonfatal MI or CHD mortality; soft CVD could additionally include angina, revascularization, TIA or claudication in composites defined by the study. Similarly, hard CHD could additionally include angina or coronary revascularization in composites defined by the study.

Abbreviations: ABI = ankle-brachial index; BP = blood pressure; CAC = coronary artery calcium; CHD = coronary heart disease; CI = confidence interval; CVD = cardiovascular disease; DHS = Dallas Heart Study; DM = diabetes mellitus; EISNER = Early Identification of Subclinical Atherosclerosis by Noninvasive Imaging Research; FHS = Framingham Heart Study; FRS = Framingham Risk Score; F/U = follow up; HDL = high-density lipoprotein; HNR = Heinz Nixdorf Recall study; hsCRP = high sensitivity C-reactive protein; HTN = hypertension; IQR = inter-quartile range; LDL = low-density lipoprotein; MESA = Multi-Ethnic Study of Atherosclerosis; MetS = metabolic syndrome; mg/dL = Milligrams per Deciliter; mg/L = milligrams per Liter; NR = not reported; NRI = net reclassification improvement; NTRF = non-traditional risk factor; PCE = Pooled Cohort Equations; RCT = randomized controlled trial; SBP = systolic blood pressure; SD = standard deviation; TC = total cholesterol; Tx = treatment

Study cohorts were generally smaller than those contributing to the ABI and hsCRP evidence base, and no IPD meta-analysis was available. Analyzed cohorts ranged from 946 to 7,772 participants. Seven of the cohorts represented were prospective population-based cohorts (MESA, Heinz-Nixdorf Recall, Framingham Offspring Study, Framingham 3^rd^ Generation, Dallas Heart Study, Rotterdam, South Bay Heart Watch), and the other three were derived from randomized control trial participants (EISNER) or selective samples of asymptomatic people getting a CAC scan (Houston Methodist DeBakey Heart and Vascular Center, Cardiac Research Database). With the exception of analyses from the MESA cohort,^90,^ ^113^ Heinz Nixdorf Recall,^114^ and a pooled analysis of five cohorts of low-risk women,^111^ all studies had less than 10 years of followup. With the exception of the MESA, Rotterdam, and Heinz Nixdorf Recall cohorts, studies had fewer than 100 hard CHD or CVD events. The studies using a cohort from the EISNER RCT had a very limited number of events (35 soft CVD events and 47 soft CVD events [EISNER RCT supplemented by a Cardiac Research Database]). Studies included a mix of both men and women, with a mean age ranging from 50 to 69.5 years. Only two cohorts (South Bay Heart Watch, MESA) reported including any non-White participants. Two studies (South Bay Heart Watch,^86^ MESA^77^) explicitly excluded participants with diabetes. One study using the MESA cohort included only participants with diabetes.^94^ All but three of the models included diabetes as a variable in the risk prediction model, if individuals with diabetes were included in the cohorts.^74,^ ^101,^ ^106^ In one analysis from the MESA cohort, people already taking statins (approximately a quarter of the population) were removed from the analysis; therefore, about 81 percent of the included participants had a less than 7.5 percent 10-year risk for a hard CVD event.^90^ Otherwise, when reported, cohorts typically included a more even distribution of CHD/CVD risk, but notably, a 2016 analysis by Kavousi and colleagues pooled low-risk women from 5 population-based cohorts.^111^ Differences in definitions of risk strata and type of CHD or CVD event being predicted limits direct comparison across studies and cohorts.

We did not include studies in which the CAC score was derived from CT angiography. In the included studies, there was some variation in how CAC scores were obtained. Studies either used electron beam or multidetector CT (EBCT or multidetector computer tomography [MDCT]) with varying protocols. In some instances in which EBCT is used, the protocol specified electrocardiograph (ECG)-gated EBCT. Estimated radiation exposure from CT imaging is discussed in the harms of screening section (KQ3). A CAC score (also referred to as Agatston score) is calculated based on a person’s age, sex, and sum of coronary artery calcification (density x volume) seen. The CAC score is often interpreted categorically; for example: no coronary calcification (score of 0), mild (<100), moderate (≥100 to 399), severe (≥400 to 999), and extensive (≥1000) coronary calcification. When reported in the included studies, thresholds defining an elevated CAC score varied widely from the presence of any CAC (>0) to thresholds of above 100, and more commonly above 300 or 400. In the convenience sample (as opposed to population-based) cohort, the prevalence of abnormal CAC scores was higher. For example, the prevalence of a CAC score of greater than 400 was approximately 25 percent in the Houston Methodist DeBakey Heart & Vascular Center cohort, as compared to approximately 10 percent or less in the Heinz Nixdorf Recall, Framingham Offspring, and MESA cohorts.

Most studies excluded or are assumed to have excluded people with missing data for CAC or traditional cardiovascular risk factors; some analyses using the Rotterdam and MESA plus Heinz Nixdorf Recall cohorts used imputation.^76,^ ^82,^ ^89,^ ^94^ CAC was most commonly log-transformed when included in risk prediction models. In four instances, CAC was entered categorically in risk prediction models with a varying number of strata used, with different definitions.

All the studies were assessed as fair quality. Limitations of studies are described above. Fair-quality as opposed to good-quality studies did not conduct any recalibration in the setting of using published coefficients for PCE or FRS models, had followup time equivalent to the time horizon predicted, had fewer than 20 outcome events per variable, did not report any calibration or goodness-of-fit measures, and/or did not report confidence intervals or statistical significance of changes in measures of discrimination or risk reclassification.

#### Model Performance (Calibration, Discrimination, Risk Reclassification)

For model performance, we will first discuss results of calibration, then discrimination, and finally risk reclassification. Of the 19 studies (10 cohorts) included, 8 articles (4 cohorts) reported some measure of calibration, all articles and cohorts reported discrimination, and 15 articles (9 cohorts) reported risk reclassification. To guide the reader, each section is formatted similarly with a discussion of results from models using the published coefficients first, then model development studies.

##### Calibration

Limited evidence from four cohorts and primarily model development studies suggests that the addition of CAC to the FRS can improve calibration; however, the magnitude and clinical significance of this improvement are not certain (Table 25). Calibration plots and O:E ratios are not available.

Table 25 Calibration and Overall Performance Measures in Included CAC Risk Prediction Studies (KQ2)

Measure | Author, Year | Model type: Base model | Study name | N | Outcome^§^ | Subgroup | Base model | Base model p-value | Extended model | Extended model p-value | Between model p-value | Calculated change between models
AIC | Bos, 2015^89^ | Model development: PCE variables | Rotterdam | 2,408 | Fatal CVD | All Participants | 1195.57 | -- | 1176.93 | -- | -- | -18.64
BIC | Fudim, 2016^112^ | Published coefficient: PCE | MESA | 3,556 | Hard CVD | Women | NR | NR | Very Strong^‡^ | NR | NR | NR
BIC | Fudim, 2016^112^ | Published coefficient: PCE | MESA | 3,186 | Hard CVD | Men | NR | NR | Very Strong^‡^ | NR | NR | NR
BIC | Fudim, 2016^112^ | Published coefficient: PCE | MESA | 1,850 | Hard CVD | African American | NR | NR | Very Strong^‡^ | NR | NR | NR
BIC | Fudim, 2016^112^ | Published coefficient: PCE | MESA | 2,599 | Hard CVD | Caucasian | NR | NR | Very Strong^‡^ | NR | NR | NR
BIC | Fudim, 2016^112^ | Published coefficient: PCE | MESA | 801 | Hard CVD | Chinese American | NR | NR | Positive^‡^ | NR | NR | NR
BIC | Fudim, 2016^112^ | Published coefficient: PCE | MESA | 1,492 | Hard CVD | Latino | NR | NR | Very Strong^‡^ | NR | NR | NR
Hosmer-Lemeshow test | Fudim, 2016^112^ | Published coefficient: PCE | MESA | 3,556 | Hard CVD | Women | NR | NR | 16.715 | 0.033 | NR | NR
Hosmer-Lemeshow test | Fudim, 2016^112^ | Published coefficient: PCE | MESA | 3,186 | Hard CVD | Men | NR | NR | 8.587 | 0.38 | NR | NR
Hosmer-Lemeshow test | Fudim, 2016^112^ | Published coefficient: PCE | MESA | 1,850 | Hard CVD | African American | NR | NR | 11.0 | 0.20 | NR | NR
Hosmer-Lemeshow test | Fudim, 2016^112^ | Published coefficient: PCE | MESA | 2,599 | Hard CVD | Caucasian | NR | NR | 11.9 | 0.16 | NR | NR
Hosmer-Lemeshow test | Fudim, 2016^112^ | Published coefficient: PCE | MESA | 801 | Hard CVD | Chinese American | NR | NR | 4.9 | 0.77 | NR | NR
Hosmer-Lemeshow test | Fudim, 2016^112^ | Published coefficient: PCE | MESA | 1,492 | Hard CVD | Latino | NR | NR | 12.3 | 0.14 | NR | NR
Hosmer-Lemeshow test | Bos, 2015^89^ | Model development: PCE variables | Rotterdam | 2,408 | Fatal CVD | All Participants | 6.27 | 0.71 | 2.84 | 0.97 | -- | -3.43
Hosmer-Lemeshow test | Erbel, 2010^74^ | Model development: FRS variables | HNR | 4,129 | Hard CHD | All Participants | 15.5 | 0.05 | 9.1 | 0.33 | -- | -6.4
Hosmer-Lemeshow test | Mohlenkamp, 2011^103^ | Model development: FRS variables | HNR | 3,966 | Hard CHD | All Participants | 11.5 | 0.18 | NR | NR | -- | --
Hosmer-Lemeshow test | Polonsky, 2010^77^ | Model development: FRS variables | MESA | 5,878 | Soft CHD | All Participants | 6.72 | 0.46 | 9.15 | 0.24 | | 2.43
Likelihood ratio X^2^ | Elias-Smale, 2010^76^ | Model development: FRS variables | Rotterdam | 2,028 | Hard CHD | All Participants | 83.93 | NR | 120.32 | NR | <0.001 | 36.39
Likelihood ratio X^2^ | Kavousi, 2012^82^ | Model development: FRS variables | Rotterdam | 3,678 | Hard CHD | All Participants | 230.49^*^ | NR | 60.9^†^ | NR | <0.05 | -169.59
Likelihood ratio X^2^ | Kavousi, 2012^82^ | Model development: FRS variables | Rotterdam | NR | Hard CHD | Women | NR | NR | 22.6^†^ | NR | <0.05 | --
Likelihood ratio X^2^ | Kavousi, 2012^82^ | Model development: FRS variables | Rotterdam | NR | Hard CHD | Men | NR | NR | 41.2^†^ | NR | <0.05 | --
Global X^2^ | Chang, 2015^93^ | Model development: FRS variables | Houston Methodist DeBakey Heart and Vascular Center | 946 | Soft CHD | All Participants | 11.72 | NR | 45.33 | NR | <0.0001 | 33.61

* Model likelihood chi-square

† Extended model statistic is “increase in model fit after extending the base model.”

‡ Reported as “BIC support for model with CAC”. From correspondence with Fudim, improvement in BIC are defined: 0 -2 = negligible; 2-6 = positive; 6-10 = strong; and >10 = very strong.

§ Hard CVD defined as fatal or nonfatal MI or CVA or CVD mortality; hard CHD defined as fatal or nonfatal MI or CHD mortality; soft CVD could additionally include angina, revascularization, TIA or claudication in composites defined by the study. Similarly, hard CHD could additionally include angina or coronary revascularization in composites defined by the study.

Abbreviations: AIC = Akaike information criterion; CAC = coronary artery calcium; CHD = coronary heart disease; CI = confidence interval; CVD = cardiovascular disease; FRs = Framingham Risk Score; HNR = Heinz NixdorfRecall study; MESA = Multi-Ethnic Study of Atherosclerosis; NR = not reported; PCE = Pooled Cohort Equations

Published coefficient models. One published coefficient analysis using the PCE as a base model reported the Hosmer-Lemeshow test and the overall performance measure of the BIC for sex and race/ethnicity subgroups.^112^ The Hosmer-Lemeshow test showed no evidence of miscalibration in the extended model for all subgroups except women; the publication does not report calibration for the base model. The overall performance measure of the BIC, which captures both calibration and discrimination, suggested improvement, which was characterized as “very strong” for all groups except Asians.

Model development studies. No studies reported calibration plots or O:E ratio. Only one model development study, using the Rotterdam cohort, reported calibration or overall performance measures for the addition of CAC to PCE variables.^89^ Overall performance measures (i.e., AIC, likelihood ratio χ^2^ and global χ^2^) consistently showed improvement in performance with the addition of CAC to base models.^76,^ ^82,^ ^89,^ ^93^ However, because of the integrated nature of these measures, we are unable to draw conclusions about whether calibration, discrimination, or both improved due to the addition of CAC. The one study evaluating a base model of PCE variables found no evidence of miscalibration in the base model based on the Hosmer-Lemeshow test and an improvement in calibration with the addition of CAC; however, this study predicted fatal CVD outcomes as opposed to hard CVD outcomes (Table 25).^89^ There were fewer than 100 fatal CVD outcomes in this analysis. Three studies, two using the Heinz Nixdorf Recall cohort and one using MESA, only report the Hosmer-Lemeshow test (Table 25).^74,^ ^77,^ ^103^ Two of the three models suggest improvement in calibration with the addition of CAC to the base model; however, the Hosmer-Lemeshow test is not a sensitive test.

##### Discrimination

All of the included studies reported the improvement in discrimination, as measured by a change in AUC or c-statistic, by adding CAC to traditional cardiovascular risk assessment (Table 26). The discrimination of base models using traditional cardiovascular risk factors ranged widely in both published coefficient models and model development studies, from 0.63 to 0.80 in all participants. The addition of CAC to published coefficient models and model development studies consistently resulted in at least small and sometimes large improvements in discrimination. Four studies evaluated the addition of CAC to the PCE. One of these studies, using the MESA cohort, also evaluated the FRS and findings suggest that improvement in discrimination was higher for CAC in addition to the FRS (0.04) than to the PCE (0.02).

Table 26 Discrimination Outcomes in Included CAC Risk Prediction Studies (KQ2)

Model type: Base model | Author, Year | Study name | Outcome^¶¶^ | Subgroup | N | Base model c-statistic (95% CI) | Extended model c-statistic (95% CI) | Change in discrimination (95% CI)^*^ | Change P-Value
Published coefficient: PCE | Yeboah, 2016^90,†^ | MESA | Hard CVD | All Participants | 5,185 | 0.74 (NR to NR) | 0.76 (NR to NR) | 0.02 (NR to NR) | 0.04
Published coefficient: PCE | Fudim, 2016^112^ | MESA | Hard CVD | Women | 3,556 | 0.766 (NR to NR) | 0.784 (NR to NR) | 0.018^*^ (NR to NR) | 0.19
Published coefficient: PCE | Fudim, 2016^112^ | MESA | Hard CVD | Men | 3,186 | 0.705 (NR to NR) | 0.730 (NR to NR) | 0.025^*^ (NR to NR) | 0.047
Published coefficient: PCE | Fudim, 2016^112^ | MESA | Hard CVD | African American | 1,850 | 0.707 (NR to NR) | 0.740 (NR to NR) | 0.033^*^ (NR to NR) | 0.11
Published coefficient: PCE | Fudim, 2016^112^ | MESA | Hard CVD | Caucasian | 2,599 | 0.734 (NR to NR) | 0.753 (NR to NR) | 0.019^*^ (NR to NR) | 0.18
Published coefficient: PCE | Fudim, 2016^112^ | MESA | Hard CVD | Chinese American | 801 | 0.734 (NR to NR) | 0.747 (NR to NR) | 0.013^*^ (NR to NR) | 0.66
Published coefficient: PCE | Fudim, 2016^112^ | MESA | Hard CVD | Latino | 1,492 | 0.800 (NR to NR) | 0.809 (NR to NR) | 0.009^*^ (NR to NR) | 0.45
Published coefficient: FRS | Geisel, 2017^114^ | HNR | Hard CVD | All Participants | 3,108 | 0.693 (0.661 to 0.726) | 0.731 (0.699 to 0.763) | 0.038 (NR to NR) | 0.02
Published coefficient: FRS | Geisel, 2017^114^ | HNR | Hard CVD | Low risk (<10%) | 1,694 | 0.658 (0.602 to 0.713) | 0.738 (0.684 to 0.792) | 0.08 (NR to NR) | 0.01
Published coefficient: FRS | Geisel, 2017^114^ | HNR | Hard CVD | Intermediate risk (10-20%) | 1,022 | 0.575 (0.520 to 0.629) | 0.665 (0.610 to 0.720) | 0.09 (NR to NR) | 0.004
Published coefficient: FRS | Geisel, 2017^114^ | HNR | Hard CVD | High risk (>20%) | 392 | 0.556 (0.482 to 0.629) | 0.617 (0.534 to 0.700) | 0.061 (NR to NR) | 0.18
Published coefficient: FRS | Erbel, 2010^74^ | HNR | Hard CHD (Wilson, 1998) | All Participants | 4,129 | 0.681 (0.629 to 0.733) | 0.749 (0.682 to 0.8) | 0.068 (NR to NR) | 0.003
Published coefficient: FRS | Erbel, 2010^74^ | HNR | Hard CHD (ATPIII model) | All Participants | 4,129 | 0.653 (0.606 to 0.7) | 0.755 (0.705 to 0.805) | 0.102 (NR to NR) | 0.0001
Published coefficient: FRS | Erbel, 2010^74^ | HNR | Hard CHD (Wilson, 1998) | Women | 2,177 | 0.671 (0.582 to 0.76) | 0.711 (0.621 to 0.8) | 0.04 (NR to NR) | 0.25
Published coefficient: FRS | Erbel, 2010^74^ | HNR | Hard CHD (ATPIII model) | Women | 2,177 | 0.668 (0.606 to 0.731) | 0.729 (0.654 to 0.804) | 0.061 (NR to NR) | 0.23
Published coefficient: FRS | Erbel, 2010^74^ | HNR | Hard CHD (Wilson, 1998) | Men | 1,952 | 0.628 (0.558 to 0.698) | 0.730 (0.667 to 0.802) | 0.102 (NR to NR) | 0.0003
Published coefficient: FRS | Erbel, 2010^74^ | HNR | Hard CHD (ATPIII model) | Men | 1,952 | 0.583 (0.523 to 0.644) | 0.727 (0.665 to 0.788) | 0.144 (NR to NR) | <0.0001
Published coefficient: FRS | Yeboah, 2016^90^ | MESA | Hard CHD^†^ | All Participants | 5,185 | 0.74 (NR to NR) | 0.78 (NR to NR) | 0.04 (NR to NR) | 0.001
Published coefficient: FRS | Greenland, 2004^86^ | South Bay Heart Watch | Hard CHD | All Participants | 1,029 | 0.63 (0.628 to 0.632)^‡^ | 0.68 (0.678 to 0.682)^‡^ | 0.05 (NR to NR) | <0.001
Published coefficient: FRS | Wong, 2009^106^ | EISNER + Cardiac Research Database | Hard CHD | All Participants | 2,303 | 0.757 (NR to NR)^§^ | 0.834 (NR to NR)^§^ | 0.077 (NR to NR) | 0.1
Published coefficient: FRS | Wong, 2009^106^ | EISNER + Cardiac Research Database | Soft CVD | All Participants | 2,303 | 0.763 (NR to NR)ǁ | 0.851 (NR to NR)ǁ | 0.088 (NR to NR)ǁ | 0.006
Published coefficient: FRS | Wong, 2009^106^ | EISNER + Cardiac Research Database | Soft CHD | All Participants | 2,303 | 0.748 (NR to NR)^¶^ | 0.857 (NR to NR)^¶^ | 0.109 (NR to NR)^¶^ | 0.004
Model development: PCE variables | Kavousi, 2016^111^ | Pooled analysis of 5 cohorts ǁǁ of low risk women (<7.5% 10-yr PCE risk) | Hard CVD | All Participants | 6,739 | 0.73 (0.69 to 0.77) | 0.77 (0.74 to 0.81) | 0.02^*^ (0.0 to 0.05) | 0.08
Model development: PCE variables | Bos, 2015^89^ | Rotterdam | Fatal CVD | All Participants | 2,408 | 0.78 (0.73 to 0.83) | 0.81 (0.76 to 0.86) | 0.03 (NR to NR) | NR
Model development: FRS variables | Kavousi, 2016^111^ | Pooled analysis of 5 cohorts ǁǁ of low risk women (<10% 10-yr FRS risk) | Hard CHD | All Participants (DM excluded) | 7,772 | 0.79 (0.70 to 0.88) | 0.83 (0.73 to 0.93) | 0.04^*^ (0.01 to 0.07) | NR
Model development: FRS variables | Hoffmann, 2016^88^ | Framingham Heart Study Offspring and 3rd Generation | Hard CVD | All Participants | 3,319^#^ | 0.8 (NR to NR)^**^ | 0.82 (NR to NR)^**^ | 0.02 (NR to NR)^**^ | >0.05^**^
Model development: FRS variables | Erbel, 2010^74^ | HNR | Hard CHD | All Participants | 4,129 | 0.712 (0.664 to 0.76) | 0.763 (0.714 to 0.812) | 0.051 (NR to NR) | 0.004
Model development: FRS variables | Eias-Smale, 2010^76^ | Rotterdam | Hard CHD | All Participants | 2,028 | 0.72 (NR to NR) | 0.76 (NR to NR) | 0.04 (NR to NR) | <0.001
Model development: FRS variables | Kavousi, 2012^82^ | Rotterdam | Hard CHD | All Participants | 3,678 | 0.73 (0.71 to 0.75) | NR | 0.05* (0.02* to 0.06*) | NR
Model development: FRS variables | Hoffmann, 2016^88^ | Framingham Heart Study Offspring and 3rd Generation | Hard CHD | All Participants | 3,340^#^ | 0.78 (NR to NR)^††^ | 0.82 (NR to NR)^††^ | 0.04 (NR to NR)^††^ | <0.05
Model development: FRS variables | Mohlenkamp, 2011^103^ | HNR | Hard CHD | All Participants | 3,966 | 0.719 (0.671 to 0.767) | 0.763 (0.715 to 0.812) | 0.044 (NR to NR) | 0.0067
Model development: FRS variables | Kavousi, 2012^82^ | Rotterdam | Hard CHD | Women | NR | NR | NR | 0.05* (0.03* to 0.07*) | NR
Model development: FRS variables | Kavousi, 2012^82^ | Rotterdam | Hard CHD | Men | NR | NR | NR | 0.06* (0.03* to 0.09*) | NR
Model development: FRS variables | Yeboah, 2014^94^ | MESA and HNR | Hard CHD | With diabetes | 1,343 | 0.6964 (0.64 to 0.75)^‡‡^ | 0.7575 (NR to NR) | 0.061 (NR to NR) | NR
Model development: FRS variables | Rana, 2012^99^ | EISNER | Soft CVD | All Participants | 1,286 | 0.73 (0.66 to 0.82) | 0.84 (0.78 to 0.91) | 0.11 (NR to NR) | 0.003
Model development: FRS variables | Yeboah, 2012^75^ | MESA | Soft CVD | Intermediate risk | 1,330 | 0.623 (NR to NR) | 0.784 (NR to NR) | 0.161 (NR to NR) | <0.001
Model development: FRS variables | Malik, 2011^101^ | MESA | Soft CVD | With diabetes, MetS, or neither^§§^ | 4,036 | NR | NR | NR | <0.0001
Model development: FRS variables | Chang, 2015^93^ | Houston Methodist DeBakey Heart and Vascular Center | Soft CHD | All Participants | 946 | 0.63 (NR to NR) | 0.7 (NR to NR) | 0.07 (NR to NR) | 0.01
Model development: FRS variables | Polonsky, 2010^77^ | MESA | Soft CHD | All Participants | 5,878 | 0.76 (0.72 to 0.79) | 0.81 (0.78 to 0.84) | 0.05 (NR to NR) | <0.001
Model development: FRS variables | Yeboah, 2012^75^ | MESA | Soft CHD | Intermediate risk | 1,330 | 0.623 (NR to NR) | 0.784 (NR to NR) | 0.161 (NR to NR) | <0.001
Model development: FRS variables | Malik, 2011^101^ | MESA | Soft CHD | No diabetes or MetS | 4,036 | 0.73 (NR to NR) | 0.8 (NR to NR) | 0.07 (NR to NR) | <0.0001
Model development: FRS variables | Malik, 2011^101^ | MESA | Soft CHD | With diabetes | 881 | 0.72 (NR to NR) | 0.78 (NR to NR) | 0.06 (NR to NR) | <0.0001

* Calculated as Extended-Base except where noted; asterisk indicates reported (not calculated) change

† Recalibrated by including the PCE in the Cox model predicting Hard CVD and used baseline survival estimated from MESA data; similar procedure used for FRS model Predicting hard CHD events

‡ CIs calculated from standard deviations

§ For categorical CAC analyses; p=0.08 for LogCAC analyses (AUCs NR); p=0.07 for LogCAC volume analyses (AUCs NR).

ǁ For categorical CAC analyses; p=0.004 for LogCAC analyses (AUCs NR); p<0.01 for LogCAC volume analyses (AUCs NR).

¶ For categorical CAC analyses; p=0.002 for LogCAC analyses (AUCs NR); p=0.02 for LogCAC volume analyses (AUCs NR).

# N assumed based on NRI analyses

** Same results obtained for entry of CAC continuously in the model (log transformed) and when entered categorically in the model (0, 1-100, 101-300, >300)

†† CAC entered continuously in the model (log-transformed). Results were similar when CAC entered categorically in the model (0, 1-100, 101-300, >300): base model 0.78 (Nr to NR); extended model 0.83 (NR to NR); change in discrimination: 0.05 (NR to NR).

‡‡ AUC for published coefficient FRS in this population was 0.6797; CAC not added to published coefficient FRS. AUC for published coefficient PCE was 0.637; CAC not added to published coefficient PCE.

§§ For all analyzed groups (diabetes, MetS, neither), C-statistics improved from 0.73-0.74 to 0.78-0.79 (all p<0.0001) but which c-statistics belong to which groups NR.

ǁǁ Five pooled cohorts: DHS, FHS, HNR, MESA, and Rotterdam

¶¶ Hard CVD defined as fatal or nonfatal MI or CVA or CVD mortality; hard CHD defined as fatal or nonfatal MI or CHD mo rtality; soft CVD could additionally include angina, revascularization, TIA or claudication in composites defined by the study. Similarly, hard CHD could additionally include angina or coronary revascularization in composites defined by the study.

Abbreviations: ABI = ankle-brachial index; ATP III = Adult Treatment Panel III; AUC = area under the concentrated curve; CAC = coronary artery calcium; CHD = coronary heart disease; CI = confidence interval; CVD = cardiovascular disease; DHS = Dallas Heart Study; DM = diabetes mellitus; EISNER = Early Identification of Subclinical Atherosclerosis by Noninvasive Imaging Research; FHS = Framingham Heart Study; FRS = Framingham Risk Score; F/U = follow up; HNR = Heinz Nixdorf Recall study; MESA = Multi-Ethnic Study of Atherosclerosis; MetS = metabolic syndrome; NR = not reported; NRI = net reclassification improvement; PCE = Pooled Cohort Equations

Published coefficient models. Two published coefficient analyses, both using the MESA cohort, evaluated a PCE base model. One is an analysis by Yeboah and colleagues,^90^ which excluded people already taking statins and therefore represents a population at lower risk for CVD; the other analysis by Fudim and colleagues^112^ explored the addition of CAC in sex and racial/ethnic subpopulations, and, as such, results are exclusively reported by subpopulation. The base model discrimination of the PCE to predict hard CVD events in the analysis by Yeboah and colleagues was 0.74; the addition of CAC resulted in an improvement of 0.02 (p=0.04).^90^ However, as this was a model that recalibrated the PCE to the MESA population, estimates of improvement in discrimination may be conservative. The analysis by Fudim and colleagues showed a PCE base model discrimination of 0.705 in men and 0.766 in women; c-statistics varied across racial and ethnic groups, with the poorest performance in African Americans (0.707) and the best performance in Latinos (0.800). Improvements in discrimination were very small to small in all subpopulations but were statistically significant only in men, who were the group with the poorest base model performance (improvement of 0.025, p=0.047); neither confidence intervals nor statistical significance are reported. Subgroup analyses by race/ethnicity may not be adequately powered to detect statistically significant differences (i.e., smaller n’s and number of events for African Americans, Latinos, and Asians/Chinese). The MESA analysis by Yeboah and colleagues also evaluates the addition of CAC to a published coefficient FRS base model to predict hard CHD events; base model discrimination was also 0.74 and the addition of CAC resulted in an improvement of 0.04 (p=0.001). In other studies using the FRS to predict hard CHD, the base model discrimination ranged from 0.63 to 0.757.^74,^ ^86,^ ^106,^ ^114^ In these studies, the addition of CAC resulted in an improvement in discrimination of 0.038 to 0.102; however, results in the analysis of EISNER combined with the Cardiac Research Database were not statistically significant due to the limited number of events.^106^ Presumably due to the low number of hard CHD events in this cohort, this study also conducted analyses with soft CHD and soft CVD outcomes, in which similar improvements in discrimination were statistically significant. In one study using the Heinz Nixdorf Recall cohort, sex-stratified analyses suggest a greater improvement in discrimination using CAC in addition to the FRS, for men (compared to women), owing to the poorer performance of the base model in men (compared to women).^74^

Model development studies. Two model development studies evaluated the addition of CAC to PCE variables. One study was a pooled analysis of low-risk (<7.5%) women in five population-based cohorts which had a base model discrimination of 0.73 (95% CI, 0.69 to 0.77) and a very small to small improvement in discrimination with the addition of CAC (0.02 [95% CI, 0.0 to 0.05]).^111^ The other model development study, using the Rotterdam cohort, evaluated the addition of CAC to PCE variables used fatal (as opposed to hard) CVD events.^89^ This study’s base model discrimination was 0.78 (95% CI, 0.73 to 0.83) and with the addition of CAC was 0.81 (95% CI, 0.76 to 0.86), with overlapping 95% CI in which the CI of the base model includes the point estimate of discrimination of the extended model with CAC (p-value not reported).

The remaining 12 model development studies used FRS variables in their base model; the pooled analysis of low-risk women by Kavousi and colleagues evaluated the addition of CAC to FRS variables as well as PCE variables. The discrimination in five studies using a base model of FRS variables to predict hard CHD events in all participants ranged from 0.712 to 0.79.^74,^ ^76,^ ^82,^ ^88,^ ^103,^ ^111^ In these studies, CAC led to small statistically significant improvements in discrimination (0.04 to 0.05). Only one study, which used the Rotterdam cohort, conducted sex-stratified analyses, and found similar improvements in discrimination in both men and women.^82^ One study that used MESA included only participants with diabetes; while the base model discrimination may be lower (difficult to compare across studies as confidence intervals were not reported), improvement in discrimination using CAC was similar in magnitude.^94^ Three additional studies using a model of FRS variables to predict soft CHD events generally found similar improvements in discrimination with CAC in all participants.^77,^ ^93,^ ^101^ The lower base model performance of FRS variables in the Houston Methodist DeBakey Heart and Vascular Center cohort, may have something to do with the more selected (higher risk) population studied. One of these studies, using MESA, conducted sensitivity analyses with and without those with diabetes (as their base model did not include diabetes as a risk factor); both these analyses yielded similar results.^101^ One additional study, using MESA, included only intermediate-risk people, defined as 2.0 to 15.4 percent 7.5-year risk of having a soft CHD event; this study found the base model discrimination was 0.623, and the improvement in discrimination with CAC was 0.161 (p<0.001).^75^ Last, results from one study, using the EISNER RCT, only reported discrimination using soft CVD events and generally found concordant results.^99^

##### Risk Reclassification

Most of the included studies (k=15) reported risk reclassification using NRI with or without IDI (Table 27). Although population risk, outcomes predicted, and definitions of risk strata vary across studies, CAC added to traditional cardiovascular risk factors consistently improves risk reclassification as measured by the total NRI. Four studies evaluated the addition of CAC to the PCE, and these studies demonstrate that CAC can improve risk reclassification, albeit with some study limitations. CAC appears to improve reclassification across a spectrum of risk and in both men and women. Improvements in the total NRI were consistently driven by event NRIs much larger than nonevent NRIs, yet nonevents were considerably more common (less than about 8% of participants in each included study had a hard event) and the total NRI is not weighted by event prevalence. It was not uncommon in the CAC literature for nonevent NRIs to be negative (sometimes statistically significant), indicating than on net, more participants were inappropriately reclassified upward.

Table 27 Reclassification Outcomes in Included CAC Risk Prediction Studies (KQ2)

Model type: Base model | Author, Year | Study name | N | Outcome^‡‡^ | Subgroup | Total NR (95% CI) | Event NR (95% CI) | Nonevent NRI (95% CI) | 10-Year risk categories (High, Intermediate, Low)
Published coefficient: PCE | Yeboah, 2016^90^ | MESA | 5,185 | Hard CVD | All Participants | 0.119 (0.08 to 0.256)^*^ | 0.178 (0.08 to 0.256)^*^ | -0.059 (-0.075 to 0.03)^*^ | ≥7.5%, <7.5%
Published coefficient: PCE | Fudim, 2016^112^ | MESA | 3,556 | Hard CVD | Women | 0.095 (NR to NR); p=0.039 | NR | NR | ≥5.25%, <5.25% 7-year risk
Published coefficient: PCE | Fudim, 2016^112^ | MESA | 3,556 | Hard CVD | Women | 0.488 (NR to NR); p<0.001 | NR | NR | Continuous NRI
Published coefficient: PCE | Fudim, 2016^112^ | MESA | 3,186 | Hard CVD | Men | 0.080 (NR to NR); p=0.037 | NR | NR | ≥5.25%, <5.25% 7-year risk
Published coefficient: PCE | Fudim, 2016^112^ | MESA | 3,186 | Hard CVD | Men | 0.437 (NR to NR); p<0.001 | NR | NR | Continuous NRI
Published coefficient: PCE | Fudim, 2016^112^ | MESA | 1,850 | Hard CVD | African American | 0.111 (NR to NR); p=0.082 | NR | NR | ≥5.25%, <5.25% 7-year risk
Published coefficient: PCE | Fudim, 2016^112^ | MESA | 1,850 | Hard CVD | African American | 0.500 (NR to NR); p<0.001 | NR | NR | Continuous NRI
Published coefficient: PCE | Fudim, 2016^112^ | MESA | 2,599 | Hard CVD | Caucasian | 0.111 (NR to NR); p=0.02 | NR | NR | ≥5.25%, <5.25% 7-year risk
Published coefficient: PCE | Fudim, 2016^112^ | MESA | 2,599 | Hard CVD | Caucasian | 0.587 (NR to NR); p<0.001 | NR | NR | Continuous NRI
Published coefficient: PCE | Fudim, 2016^112^ | MESA | 801 | Hard CVD | Chinese American | -0.121 (NR to NR); p=0.11 | NR | NR | ≥5.25%, <5.25% 7-year risk
Published coefficient: PCE | Fudim, 2016^112^ | MESA | 801 | Hard CVD | Chinese American | 0.701 (NR to NR); p=0.003 | NR | NR | Continuous NRI
Published coefficient: PCE | Fudim, 2016^112^ | MESA | 1,492 | Hard CVD | Latino | 0.024 (NR to NR); p=0.61 | NR | NR | ≥5.25%, <5.25% 7-year risk
Published coefficient: PCE | Fudim, 2016^112^ | MESA | 1,492 | Hard CVD | Latino | 0.472 (NR to NR); p<0.001 | NR | NR | Continuous NRI
Published coefficient: FRS | Geisel, 2017^114^ | HNR | 3,108 | Hard CVD | All Participants | 0.551 (0.416 to 0.686) | NR | NR | Continuous NRI
Published coefficient: FRS | Geisel, 2017^114^ | HNR | 1,694 | Hard CVD | Low risk (<10%) | 0.414 (0.177 to 0.652) | NR | NR | Continuous NRI
Published coefficient: FRS | Geisel, 2017^114^ | HNR | 1,022 | Hard CVD | Intermediate risk (10-20%) | 0.446 (0.246 to 0.646) | NR | NR | Continuous NRI
Published coefficient: FRS | Geisel, 2017^114^ | HNR | 392 | Hard CVD | High risk (<20%) | 0.181 (-0.100 to 0.462) | NR | NR | Continuous NRI
Published coefficient: FRS | Yeboah, 2016^90^ | MESA | 5,185 | Hard CHD | All Participants | 0.084 (0.024 to 0.196) | 0.119 (0.045 to 0.239) | -0.034 (-0.053 to 0.017) | >20%, 10-20%, <10%
Published coefficient: FRS | Yeboah, 2016^90^ | MESA | 211 | Hard CHD | Intermediate Risk | 0.041 (-0.197 to 0.28)f | NR | NR | >20%, 10-20%, <10%
Model development: PCE variables | Kavousi, 2016^111^ | Pooled analysis of 5 cohorts^##^ of low risk women (<7.5% 10-yr PCE risk) | 6,739 | Hard CVD | All Participants | 0.20 (0.09 to 0.31) | NR | NR | Continuous NRI
Model development: PCE variables | Bos, 2015^89^ | Rotterdam | 2,408 | Fatal CVD | All Participants | 0.55 (0.33 to 0.76) | 0.417 (NR to NR) | 0.137 (NR to NR) | Continuous NRI
Model development: FRS variables | Hoffmann, 2016^88^ | Framingham Heart Study Offspring and 3rd Generation | 3,319 | Hard CVD | All Participants | 0.213 (0.088 to 0.337)^‡,§^ | 0.232 (0.109 to 0.356)^‡,§^ | -0.02 (-0.032 to -0.008)^‡,§^ | ≥10%, 6.5 to <10%, 2.5 to <6.5%, 0 to <2.5%^§§^
Model development: FRS variables | Hoffmann, 2016^88^ | Framingham Heart Study Offspring and 3rd Generation | 3,319 | Hard CVD | All Participants | 0.2 (0.03 to 0.37)ǁ | 0.21 (NR to NR)ǁ | -0.01 (NR to NR)ǁ | ≥10%, 6.5 to <10%, 2.5 to <6.5%, 0 to <2.5%^§§^
Model development: FRS variables | Hoffmann, 2016^88^ | Framingham Heart Study Offspring and 3rd Generation | 589 | Hard CVD | Intermediate Risk | 0.274 (0.058 to 0.491)†‡ | NR | NR | ≥10%, 6.5 to <10%, 2.5 to <6.5%, 0 to <2.5%^§§^
Model development: FRS variables | Kavousi, 2016^111^ | Pooled analysis of 5 cohorts^##^ of low risk women (<10% 10-yr FRS risk) | 7,772 | Hard CHD | All Participants (excluded DM) | 0.28 (0.18 to 0.39) | NR | NR | Continuous NRI
Model development: FRS variables | Hoffmann, 2016^88^ | Framingham Heart Study Offspring and 3rd Generation | 3,340 | Hard CHD | All Participants | 0.22 (0.01 to 0.42)ǁ | 0.24 (NR to NR)ǁ | -0.02 (NR to NR)ǁ | ≥10%, 5 to <10%, 2.5 to <5%, 0 to <2.5%^§§^
Model development: FRS variables | Hoffmann, 2016^88^ | Framingham Heart Study Offspring and 3rd Generation | 3,340 | Hard CHD | All Participants | 0.319 (0.141 to 0.497)^‡,¶^ | 0.333 (0.156 to 0.511)^‡,¶^ | -0.014 (-0.026 to -0.003)^‡,¶^ | ≥10%, 5 to <10%, 2.5 to <5%, 0 to <2.5%^§§^
Model development: FRS variables | Hoffmann, 2016^88^ | Framingham Heart Study Offspring and 3rd Generation | 347 | Hard CHD | Intermediate Risk | 0.457 (0.093 to 0.821)^†,‡^ | NR | NR | ≥10%, 5 to <10%, 2.5 to <5%, 0 to <2.5%^§§^
Model development: FRS variables | Erbel, 2010^74^ | HNR | 4,129 | Hard CHD | All Participants | 0.224 (0.091 to 0.356)^#^ | 0.226 (0.094 to 0.357)^#^ | -0.002 (-0.019 to 0.015)^#^ | >20%, 10-20%, <10%
Model development: FRS variables | Erbel, 2010^74^ | HNR | 1,126 | Hard CHD | Intermediate Risk | 0.226 (-0.07 to 0.522)^†^; | NR | NR | >20%, 10-20%, <10%^**^
Model development: FRS variables | Mohlenkamp, 2011^103^ | HNR | 3,966 | Hard CHD | All Participants | 0.238 (NR to NR); p=0.0007 | NR | NR | >20%, 10-20%, <10%
Model development: FRS variables | Elias-Smale, 2010^76^ | Rotterdam | 2,028 | Hard CHD | All Participants | 0.14 (NR to NR); p<0.01 | NR | NR | >20%, 10-20%, <10%
Model development: FRS variables | Kavousi, 2012^82^ | Rotterdam | 3,678 | Hard CHD | All Participants | 0.193 (0.125 to 0.262) | 0.235 (0.168 to 0.301)^††^ | -0.041 (-0.058 to -0.024)^††^ | >20%, 10-20%, <10%
Model development: FRS variables | Kavousi, 2012^82^ | Rotterdam | NR | Hard CHD | Women | 0.134 (0.039 to 0.229) | NNR | NR | >20%, 10-20%, <10%
Model development: FRS variables | Kavousi, 2012^82^ | Rotterdam | NR | Hard CHD | Women, Intermediate Risk | 0.252 (0.064 to 0.44) | 0.045 (NR to NR)^††^ | 0.207 (NR to NR)^††^ | >20%, 10-20%, <10%
Model development: FRS variables | Kavousi, 2012^82^ | Rotterdam | 919 | Hard CHD | Intermediate Risk | 0.165 (0.041 to 0.29)^†^ | NR | NR | >20%, 10-20%, <10%
Model development: FRS variables | Kavousi, 2012^82^ | Rotterdam | NR | Hard CHD | Men | 0.241 (0.144 to 0.338) | NR | NR | >20%, 10-20%, <10%
Model development: FRS variables | Kavousi, 2012^82^ | Rotterdam | NR | Hard CHD | Men, Intermediate Risk | 0.509 (0.337 to 0.681) | 0.329 (NR to NR)^††^ | 0.18 (NR to NR)^††^ | >20%, 10-20%, <10%
Model development: FRS variables | Rana, 2012^99^ | EISNER | 1,279 | Soft CVD | All Participants | 0.35 (0.11 to 0.58) | 0.286 (0.035 to 0.536)^††^ | 0.06 (0.028 to 0.092)^††^ | >8%, 2.4 to 8%, <2.4%ǁǁ
Model development: FRS variables | Rana, 2012^99^ | EISNER | 411 | Soft CVD | Intermediate Risk | 0.196 (-0.236 to 0.628)^†^ | NR | NR | >8%, 2.4 to 8%, <2.4%ǁǁ
Model development: FRS variables | Yeboah, 2012^75^ | MESA | 1,330 | Soft CVD | Intermediate Risk | 0.466 (NR to NR) | 0.106 (NR to NR) | 0.36 (NR to NR) | >21.1%, 3.4 to 21.1%, <3.4%^¶¶^
Model development: FRS variables | Polak, 2017^113^ | MESA | 6,500 | Soft CHD | All Participants | 0.111 (0.064 to 0.159)^†††^ | 0.126 (0.080 to 0.172)^†††^ | -0.015 (-0.027 to -0.002)^†††^ | ≥20%, 6-20%, <6%
Model development: FRS variables | Polak, 2017^113^ | MESA | 2,634 | Soft CHD | Intermediate Risk | 0.073 (0.024 to 0.121)^†^ | NR | NR | ≥20%, 6-20%, <6%
Model development: FRS variables | Chang, 2015^93^ | Houston Methodist DeBakey Heart and Vascular Center | 946 | Soft CHD | All Participants | 0.302 (NR to NR); p<0.0001 | NR | NR | >20%, 6-20%, <6%
Model development: FRS variables | Chang, 2015^93^ | Houston Methodist DeBakey Heart and Vascular Center | 655 | Soft CHD | Intermediate Risk | 0.286 (NR to NR); p<0.0001 | NR | NR | >20%, 6-20%, <6%
Model development: FRS variables | Polonsky, 2010^77^ | MESA | 5,878 | Soft CHD | All Participants | 0.25 (0.16 to 0.34)^‡‡^ | 0.225 (0.134 to 0.316)^‡‡^ | 0.024 (0.01 to 0.037)^‡‡^ | ≥10%, 3% to <10%, 0% to <3%^§§^
Model development: FRS variables | Polonsky, 2010^77^ | MESA | 1,847 | Soft CHD | Intermediate Risk | 0.19 (0.05 to 0.33)^†^ | NR | NR | ≥10%, 3% to <10%, 0% to <3%^§§^
Model development: FRS variables | Polonsky, 2010^77^ | MESA | 5,038 | Soft CHD | Sensitivity analysis excluding 840 on lipid meds at baseline | 0.26 (0.16 to 0.37) | NR | NR | ≥10%, 3% to <10%, 0% to <3%
Model development: FRS variables | Yeboah, 2012^75^ | MESA | 1,330 | Soft CHD | Intermediate Risk | 0.659 (NR to NR) | 0.255 (NR to NR) | 0.404 (NR to NR) | >15.4%, 2.0 to 15.4%, <2.0%

* Sensitivity analysis using 3 categories (0-5%, 5-7.5%, >7.5%) produced similar results

† Bias-corrected NRI_INT_ calculated using simple variance method

‡ CAC entered continuously in the model (log-transformed).

§ Calculated values in order to derive CIs for event and nonevent NRIs and there were small differences compared with reported values (method of CI calculation in paper NR). Study reported NRI (95% CI) w/ log CAC: 0.25 (0.08-0.41); event NRI: 0.27; and nonevent NRI: -0.02.

ǁ CAC entered categorically in the model: 0, 1-100, 101-300, >300

¶ Calculated values in order to derive CIs for event and nonevent NRIs and there were small differences compared with reported values (method of CI calculation in paper NR). Study reported NRI (95% CI) w/ log CAC: 0.33 (0.11-0.53); Event NRI: 0.33; and Nonevent NRI: -0.02.

# Calculated Total NRI CIs, and event and nonevent NRIs. NRI was 0.196 (p=0.004) using categories of <6%, 6-20%, >20%. Also reports NRI for intermediate group where CAC scores <100 move an individual into low risk and CAC scores ≥400 move an individual to high risk (0.217 for 10 -20% intermediate-risk group; 0.306 for 6-20% intermediate-risk group).

** Results for intermediate-risk group defined by 6-20% also available

†† Calculated event and nonevent NRI

‡‡ Sensitivity analysis including 883 with diabetes had NRI 0.27 (0.19 to 0.34)

§§ 5-year risk

ǁǁ 4-year risk

¶¶ 7.5-year risk

## Five pooled cohorts: DHS, FHS, HNR, MESA, and Rotterdam

††† Calculated event and nonevent NRI Cis

‡‡‡ Hard CVD defined as fatal or nonfatal MI or CVA or CVD mortality; hard CHD defined as fatal or nonfatal MI or CHD mortality; soft CVD could additionally include Angina, revascularization, TIA or claudication in composites defined by the study. Similarly, hard CHD could additionally include angina or coronary revascularization in composites defined by the study.

Abbreviations: AUC = area under the concentrated curve; CAC = coronary artery calcium; CHD = coronary heart disease; CI = confidence interval; CVD = cardiovascular disease; DHS = Dallas Heart Study; EISNER = Early Identification of Subclinical Atherosclerosis by Noninvasive Imaging Research; FHS = Framingham Heart Study; FRS = Framingham Risk Score; F/U = follow up; HNR = Heinz Nixdorf Recall study; MESA = Multi-Ethnic Study of Atherosclerosis; NR = not reported; NRI = net reclassification improvement; PCE = Pooled Cohort Equations

Published coefficient models. Three studies of two cohorts using published coefficients reported measures of risk reclassification. Analyses of a PCE base model were restricted to just one cohort, MESA.^90^ Again, the MESA analysis by Yeboah and colleagues excluded people already taking statins, and therefore represents a population at lower risk for CVD. For the PCE analysis, the study defined low risk as having less than 7.5 percent 10-year risk of a hard CVD event, and high risk as 7.5 percent or greater risk. This study found an NRI of 0.119 (95% CI, 0.08 to 0.256), with a greater proportion of those having a CVD event (vs. not having an event) reclassified to higher-risk categories with the addition of CAC to the PCE; the nonevent NRI was negative but not statistically significant (-0.059 [95% CI, -0.075 to 0.03]). The MESA analysis by Fudim and colleagues^112^ reported statistically significant NRI for both men and women (0.080 and 0.095, respectively), but event and nonevent NRI were not reported and could not be calculated; the risk threshold was 5.25 percent 7-year risk which corresponds to 7.5 percent 10-year risk. Subgroup analyses by race/ethnicity showed that the NRI was statistically significant only for Whites (0.111), which was also the largest group in the study; other NRIs ranged from 0.121 (p=0.11) for Asians to 0.111 (p=0.082) for African Americans. Again, subgroup analyses by race/ethnicity had limited samples and number of events. For the FRS analysis by Yeboah and colleagues,^90^ the study defined low risk as less than 10 percent 10-year risk of a hard CHD event, intermediate risk as 10 to 20 percent risk, and high risk as greater than 20 percent risk. This study found an NRI 0.084 (95% CI, 0.024 to 0.196), again with a greater proportion of those having a CVD event reclassified, with the addition of CAC to the FRS; again, the nonevent NRI was negative but not statistically significant. The bias-corrected NRI_int_ was lower and not statistically significant. An analysis of the Heinz Nixdorf Recall cohort showed a statistically significant NRI for all analyzed participants, as well as for participants defined as low risk (<10%) and intermediate risk (10-20%); however, continuous NRIs are reported and are not comparable in scale to the categorical NRIs reported above.^114^ Event and nonevent NRIs were not reported and the intermediate-risk NRI was not bias-corrected and could not be calculated.

Model development studies. Two model development studies evaluated the addition of CAC to PCE variables.^89,^ ^111^ An analysis by Kavousi and colleagues pooled low-risk women (<7.5% 10-year risk) from five population-based cohorts and found a statistically significant continuous NRI of 0.20 (95% CI, 0.09 to 0.31); event and nonevent NRIs were not reported and could not be calculated. The other study in the Rotterdam cohort evaluated fatal (as opposed to hard) CVD events, and because there are no accepted risk categories for fatal events, this study used continuous NRI. This study found an NRI 0.55 (95% CI 0.33 to 0.76), with a greater proportion of those having a fatal event (vs. not having an event) reclassified with the addition of CAC to PCE variables. This NRI should not be directly compared to NRI using categorical risk strata. The IDI is also reported but not discussed further (Appendix E Table 3).

The remaining 11 model development studies used FRS variables in their base model; the pooled analysis by Kavousi and colleagues evaluated the addition of CAC to both FRS variables and PCE variables.^111^ Six studies included analyses using FRS variables to predict hard CHD events for all participants.^74,^ ^76,^ ^82,^ ^88,^ ^103^ With the exception of the analysis by Hoffmann and colleagues, which predicted 5-year risk and used four instead of three risk categories, these studies used similar risk categorizations, with low risk defined as less than 10 percent 10-year risk of a hard CHD event, intermediate risk as 10 to 20 percent risk, and high risk as greater than 20 percent risk. In these studies, categorical NRI ranged from 0.14 to 0.319 and one study reported a continuous NRI of 0.28. For those studies reporting or allowing for calculation of event and nonevent NRI, a greater proportion of those having a hard CHD event (versus not having an event) were reclassified with the addition of CAC to FRS variables. In half of these studies, the nonevent NRI was negative and was statistically significant in two studies;^82,^ ^88^ it was also negative and statistically significant in one study reporting soft CHD outcomes.^113^ The IDI, reported in two of these studies, was congruent with findings using NRI as a measure of reclassification (Appendix E Table 3).^74,^ ^103^ One study, which used the Rotterdam cohort, conducted sex-stratified analyses and found greater reclassification in men than women.^82^ Bias-corrected NRI_int_ was calculated for three of these studies.^74,^ ^82,^ ^88^ One of these studies, which used the Framingham Offspring cohort, found slightly greater reclassification for the intermediate-risk group as compared to all participants.^88^ The other two studies found a similar magnitude in NRI in the intermediate-risk group as compared to all participants.^74,^ ^82^ The reasons for the differences in findings among these three studies comparing intermediate versus all-risk participants is not clear.

Three additional studies using FRS variables to predict soft CHD events generally found similar improvements in reclassification with CAC in all participants.^77,^ ^93,^ ^113^ These studies use different categorization of risk (different from one another and different from studies predicting hard CHD events); nonetheless, NRI and IDI results in these two studies are similar to findings using hard CHD events. One of these studies, which used MESA, conducted sensitivity analyses with and without individuals with diabetes (as their base model did not include diabetes as a risk factor); this analysis yielded similar results.^77^ In two of these studies, both which used MESA and in which we could calculate a bias-corrected NRI_int,_ the NRI_int_ was smaller than the NRI for all participants.^77,^ ^113^ One additional study that used MESA included only intermediate-risk people, but a bias-corrected NRI_int_ could not be calculated.^75^ Last, results from one study that used the EISNER RCT included soft CVD events as an outcome, presumably to increase power; reclassification results were generally concordant to other studies using hard CHD or CVD events, and results for bias-corrected NRI_int_ were no longer statistically significant.^99^

## KQ3 What Are the Harms of Nontraditional Risk Factor Assessment?

### Summary

We included eight studies that evaluated the harms of nontraditional risk factor assessment, all of which focused on harms of CAC;^11,^ ^88,^ ^89,^ ^115-119^ we found no studies evaluating potential harms of ABI or hsCRP. Four studies reported radiation exposure for CT imaging to obtain CAC (Table 28), and five studies reported other potential adverse events from CAC (i.e., psychological outcomes, adverse cardiovascular events, and health care utilization) (Tables 29-31). We did not find any studies that met our inclusion criteria that reported incidental findings (or subsequent testing/procedures from incidental finding) on CT imaging to obtain CAC. Overall, the radiation exposure or effective radiation dose per CT exam is low, ≤2 mSv. Based on two studies, risk assessment with CAC does not appear to cause any short-term (up to 1 year) mental distress. Based on two additional studies, risk assessment with CAC did not appear to paradoxically increase CVD events. Studies evaluating the impact of CAC on downstream health-care utilization have mixed findings. Two studies suggest CAC for CVD risk assessment is not associated with increased testing from 6 months up to 4 years. One large study using administrative Medicare claims data suggest that CAC in asymptomatic people was associated with increased use of cardiac tests and procedures compared to people receiving hsCRP or lipid screening. It is unclear whether the increase in testing or procedures among those receiving a CAC score represents a true harm because there was a trend (not statistically significant) for improved MI, CVA, and mortality outcomes at a median of 3 years of followup in people who had a CAC screen versus those who had hsCRP testing; there was but no difference in clinical outcomes between people who received CAC versus lipid screening alone.

Table 28 Radiation Exposure in Included CAC Harms Studies (KQ3)

Author, Year Quality | Cohort Year(s) of recruitment | N analyzed | Scanner type | Radiation exposure
Bos, 2015^89^ Fair | Rotterdam 2003-2006 | 2,408 | Eectron-beam or Multi-detector CT | Estimated radiation dose: ≤2.1 mSv
Hoffmann, 2016^88^ Fair | Framingham Offspring and 3^rd^ Generation 1998-2001 or 2002-2005 | 3,486 | Multi-detector CT | Effective radiation exposure range: 1.0 to 1.25 mSv
Messenger, 2016^115^ Fair | MESA 2009 | 3,442 | Multi-detector CT | Mean effective dose: 1.05 ± 0.45 mSv Effective dose range: 0.74-1.26 mSV
Rozanski, 2011^11^ Fair | EISNEr RCT 2001-2005 | 2,137 | Eectron-beam or multislice CT | Estimated radiation dose range: 1 to 2 mSv

Abbreviations: CT = computed tomography; EISNER = Early Identification of Subclinical Atherosclerosis by Noninvasive Imaging Research; MESA = Multi-Ethnic Study of Atherosclerosis; mSv = Millisievert; RCT = randomized controlled trial

### Detailed Results

#### Description of Studies

Four studies reported radiation exposure for CT imaging to obtain CAC,^11,^ ^88,^ ^89,^ ^115^ three of which were included studies for KQs 1 And 2 (Table 28). These studies report the radiation exposure or effective radiation dose range from obtaining CAC in three population-based cohorts (Rotterdam, Framingham Offspring, MESA) and the EISNER RCT. Two articles that reported ranges of radiation exposure or effective radiation dose from CAC using nonsystematic literature reviews were not included but are summarized in the discussion.^129,^ ^130^ There was some variation in how CAC scores were obtained across included studies. These four studies each had multiple sites with varying protocols across sites. Studies used electron beam or multidetector CT (EBCT or MDCT) scanners. Only the MESA study explicitly mentioned ECG-triggered or gated acquisition of images using EBCT and reported how the effective radiation dose was calculated. Only two studies explicitly state that they calculated the effective radiation dose,^88,^ ^115^ while the other two studies did not specify “effective” radiation dose^11,^ ^89^ and generically refer to an estimated radiation dose. The effective dose specifically refers to the tissue-weighted sum of equivalent doses.

Five studies reported other potential adverse events from CAC, including: mental distress, adverse cardiovascular events, and health care utilization (Tables 29^-^31). One of these studies was the EISNER RCT included for KQ1.^11^ Two studies reported measures of mental distress from CAC obtained for CVD risk assessment.^118,^ ^119^ One of these studies (n=1,169) was a subsample selected from two centers participating in DanRisk, a population-based cohort in Denmark to study CAC progression and the incidence of CVD events.^118^ Participants were men and women ages 50 or 60 years. Approximately 10 percent of responders were on lipid-lowering medications, 20 percent were on antihypertensive medications, and 25 percent were current smokers. About 8 percent of responders reported taking some type of medication for depression, anxiety, or other mental health condition. The other study (n=450) was a U.S.-based RCT of CAC as a motivational factor in intensive CVD screening versus usual care among people in active military duty.^119^ Participants were ages 39 to 45 years, mostly men, and about 22 percent were African American. Approximately 4 percent of participants were taking statins, 6 percent were taking antihypertensive medications, and 8 percent were current smokers. About 5 percent of participants reported taking antidepressant medication. Both studies used validated scales to measure depression; the RCT also measured anxiety and overall mental health functioning. The observational study reported depression scores before and 6 months after CAC screening in 539 of 591 people offered a depression questionnaire. The RCT reported depression, anxiety, and mental health functioning scores between groups who did and did not receive CAC information in 406 of the 450 participants at 1 year of followup.

Three studies reported adverse cardiovascular outcomes and/or health care utilization associated with CAC.^11,^ ^116,^ ^117^ Again, one of these studies was the EISNER RCT included for KQ1.^11^ Two observational studies used claims data geographically representative of the entire United States.^116,^ ^117^ One study by Chi and colleagues used a research database and identified participants ages 18 to 64 years old who received CAC (n=2,679), and downstream utilization was analyzed for non-high-risk people (n=2,139), defined as those people without known diabetes or CVD in the 12 months preceding CAC. A comparator group (n=867) comprised people whose physicians requested CAC but were denied because the procedure was not covered by their health plan benefits. Subsequent cardiac imaging, revascularization, and cardiovascular medications were assessed in the 6 months following CAC. This study also assessed CVD events, with a median followup of about 22 months for the group that received CAC and about 17 months for the group that did not receive CAC. The other observational study by Shreibati and colleagues used Medicare data and identified asymptomatic participants who received CAC (n=4,184), and assessed downstream utilization and clinical outcomes after CAC. Two reference groups were used for comparison: one propensity-matched group that received hsCRP (n=261,356) and one that received lipid screening (n=118,093). Subsequent cardiac imaging, revascularization, and hospitalization were assessed in the180 days following CAC, as well as clinical CVD outcomes, mortality, and cost (not reported here) in the 3 years following CAC. In addition to limitations of using claims data, both studies have limitations in their assembly of comparator groups, although the study by Shreibati and colleagues state they used propensity scores to help match controls. The EISNER trial randomized middle-aged volunteers from a single medical center who had CVD risk factors but no known CVD to receive CAC or not. Subsequent cardiac imaging, revascularization, cardiovascular medications, and cost (not reported here) were assessed in the 4 years following randomization.

##### Radiation Dose

The radiation exposure reported ranged from an effective dose of 0.74 to 1.26 mSv in the MESA and Framingham Offspring cohorts^88,^ ^115^ to radiation dose (did not specify effective dose) of ≤2.1 mSv in the Rotterdam and EISNER cohorts (Table 28).^11,^ ^89^ The radiation exposure was not reported separately for EBCT versus MDCT.

##### Psychological Outcomes

Neither of the two included studies suggested any adverse mental health effects from CAC (Table 29). The observational study found a statistically significant improvement in depression, as measured by the Major Depression Inventory (MDI), from before CAC to 6 months after CAC. The clinical meaningfulness of this small change (-1.4, p<0.0001) on a scale of 0 to 50 is not clear. A score of 0 to 20 on the MDI indicates no depression; the mean before-and-after scores in this cohort were 5.3 and 3.9, respectively.^118^ The RCT found no statistically significant difference in depression or anxiety (as measured by PRIME-MD) or overall mental health functioning (as measured by the SF-36) at 1 year followup between the group that received CAC scores versus the group which did not.^119^ Changes in these measures were small, and baseline scores in depression, anxiety, and overall mental health functioning were not reported.

Table 29 Psychological Outcomes in Included Harms Studies (KQ3)

Author, Year Quality | Cohort Year(s) of recruitment | N analyzed | Age | % Women | F/U | Outcome/instrument | IG Mean change (SE) | CG Mean change (SE) | p-value for between group difference
Nielsen, 2012^118^ Fair | DanRisk 2009 | 1,169 | 50% were 50 yrs 50% were 60 yrs | 53% | 6 mo | Depression/MDI Score (range 0-50) | -1.4 (NR); p<0.0001^*^ | NA | NA
O’Malley, 2003^119^ Fair | US Active-Duty Army Personnel (RCT) Jan 1999 – Mar 2001 | 450 IG: 208 CG: 197 | 39-45 yrs Mean age: 42 yrs | 21% | 12 mo | Depression score/PRIME-MD^†^ | -0.04 (0.21) | -0.13 (0.22) | 0.75ǁ
O’Malley, 2003^119^ Fair | US Active-Duty Army Personnel (RCT) Jan 1999 – Mar 2001 | 450 IG: 208 CG: 197 | 39-45 yrs Mean age: 42 yrs | 21% | 12 mo | Anxiety score/PRIME-MD^†^ | -0.19 (0.18) | -0.38 (0.21) | 0.50ǁ
O’Malley, 2003^119^ Fair | US Active-Duty Army Personnel (RCT) Jan 1999 – Mar 2001 | 450 IG: 208 CG: 197 | 39-45 yrs Mean age: 42 yrs | 21% | 12 mo | Mental health functional status/SF-36^§^ | 0.44 (0.55) | 1.01 (0.48) | 0.44ǁ

# Severity of depression estimated: 0 to 20 points (no depression); 21 to 25 points (mild depression); 26 to 30 points (moderate depression); >30 points (severe depression).

* Statistically significant at the 5% level after adjustment for multiple testing using the Bonferroni-Holm method.

† Continuous scores for depression and anxiety were obtained using the PRIME-MD based on the number and severity of symptoms reported in each domain. Higher scores indicate poorer mental health

‡ Stress was measured by the number and severity of responses to measures of 9 different domains of live (work, finances, relationships, caregiving burden, body image, sexuality, psychological support, health, and traumatic life experiences).

§ Mental health function status was measured with the Short Form-36

ǁ Calculated from analysis of variance for between-group comparisons of change after 1 -year followup

Abbreviations: CG = control group; DanRisk = the Danish Risk Score study; F/U = followup; IG = intervention group; Jan = January; Mar = March; MDI = Major Depression Inventory; mo = month(s); PRIME-MD = Primary Care Evaluation of Mental Disorders; RCT = randomized controlled trial; SF-36 = Short Form-36; yrs = years

##### Cardiovascular Outcomes

Neither of the two included studies suggested any paradoxical increase in adverse CVD events (Table 30). Both studies used administrative data. One study by Chi and colleagues found no difference in MI, CVA, or hospital admission for unstable angina in the 22 months for the group that received CAC versus 17 months for the group that did not receive CAC.^116^ The other study by Shreibati and colleagues found no statistically significant difference in MI, CVA, or all-cause mortality up to a median of 3 years between those who received CAC versus those who received hsCRP or lipid screening.^117^ This study observed a trend, but not statistically significant, for fewer MI events in the group that received CAC versus that which received hsCRP.

Table 30 Adverse Cardiac Events and Outcomes in Included Harms Studies (KQ3)

Author, Year Quality | Cohort Year(s) of recruitment | N analyzed | Age | % Women | F/U | Outcome | | IG N (%) | CG N (%) | Between group difference HR (95% CI); p-value
Chi, 2014^116^ Fair | Administrative data Jan 2005–Aug 2011 | 3,006^†^ IG: 2,139 CG: 867 | 18-64 yrs Mean (SD) = 52.76 (7.72) | 40.5% | 16-22 mo^††^ | Adverse cardiac events during the entire f/u period | MI^*^ | 8 (0.49) | 2 (0.37) | NR; 0.73^†^
Chi, 2014^116^ Fair | Administrative data Jan 2005–Aug 2011 | 3,006^†^ IG: 2,139 CG: 867 | 18-64 yrs Mean (SD) = 52.76 (7.72) | 40.5% | 16-22 mo^††^ | Adverse cardiac events during the entire f/u period | Ischemic stroke^§^ | 4 (0.24) | 0 | NR; 0.58^‡^
Chi, 2014^116^ Fair | Administrative data Jan 2005–Aug 2011 | 3,006^†^ IG: 2,139 CG: 867 | 18-64 yrs Mean (SD) = 52.76 (7.72) | 40.5% | 16-22 mo^††^ | Adverse cardiac events during the entire f/u period | Hospital admission for unstable anginaǁ | 4 (0.24) | 3 (0.56) | NR; 0.42^‡^
Shreibati, 2014^117^ Fair | Medicare Administrative data 2006-2011 | 8,358 CAC: 4,179 hs-CRP: 4,179 | Mean (SD) = 73.2 yrs (6.05) | CAC: 59.1% hs-CRP: 60.6% | 36 mo^#^ | Outcomes for matched cohorts CAC and CRP | MI | 40 (0.35)^**^ | 52 (0.46)^**^ | 0.68 (0.44-1.04)^‡‡^; 0.073
Shreibati, 2014^117^ Fair | Medicare Administrative data 2006-2011 | 8,358 CAC: 4,179 hs-CRP: 4,179 | Mean (SD) = 73.2 yrs (6.05) | CAC: 59.1% hs-CRP: 60.6% | 36 mo^#^ | Outcomes for matched cohorts CAC and CRP | Ischemic stroke | 63 (0.56)^**^ | 88 (0.79)^**^ | 0.75 (0.54-1.04)^‡‡^; 0.092
Shreibati, 2014^117^ Fair | Medicare Administrative data 2006-2011 | 8,358 CAC: 4,179 hs-CRP: 4,179 | Mean (SD) = 73.2 yrs (6.05) | CAC: 59.1% hs-CRP: 60.6% | 36 mo^#^ | Outcomes for matched cohorts CAC and CRP | ACM | 27 (0.24)^**^ | 31 (0.27)^**^ | 0.91 (0.48-1.70)^‡‡^; 0.77
Shreibati, 2014^117^ Fair | Medicare Administrative data 2006-2011 | 6,250 CAC: 3,125 Lipid Scrn: 3,125 | Mean (SD) = 72.5 (5.85) | CAC: 59.1% Lipid Scrn: 57.9% | 36 mo^#^ | Outcomes for matched cohorts CAC and Lipid Screening | MI | 36 (0.40)^**^ | 43 (0.48)^**^ | 0.81 (0.50-1.31)^‡‡^; 0.39
Shreibati, 2014^117^ Fair | Medicare Administrative data 2006-2011 | 6,250 CAC: 3,125 Lipid Scrn: 3,125 | Mean (SD) = 72.5 (5.85) | CAC: 59.1% Lipid Scrn: 57.9% | 36 mo^#^ | Outcomes for matched cohorts CAC and Lipid Screening | Ischemic stroke | 54 (0.61)^**^ | 66 (0.75)^**^ | 0.85 (0.58-1.23)^‡‡^; 0.39
Shreibati, 2014^117^ Fair | Medicare Administrative data 2006-2011 | 6,250 CAC: 3,125 Lipid Scrn: 3,125 | Mean (SD) = 72.5 (5.85) | CAC: 59.1% Lipid Scrn: 57.9% | 36 mo^#^ | Outcomes for matched cohorts CAC and Lipid Screening | ACM | 21 (0.23)^**^ | 23 (0.25)^**^ | 0.91 (0.50-1.64)^‡‡^; 0.76

* Acute myocardial infarction is defined as hospitalization with ICD-9-CMdiagnosis codes 410.x0 or 410.x1 and a length of stay between 3 and 183 days

† Patients were followed from the index date to the end of study period, end of plan enrollment, or first occurrence of any adverse cardiac event, whichever occurred first. Continuous eligibility following index date was not required for this analysis. Patients classified as high risk were excluded.

‡ Categorical variables: χ^2^ or Fisher tests; mean followup time: 2-sample t tests; median followup time: Wilcoxon rank-sum tests

§ Ischemic stroke is defined as hospitalization with ICD-9-CM diagnosis code 433.x1 or 434.x1, and a length of stay between 3 and 183 days

ǁ Unstable angina pectoris was identified by ICD-9-CM diagnosis code 411.1x

# median 3-year followup (interquartile range, 1.4-4.3 years).

** Number of events (Incidence rate per 100 person-years).

†† Median followup periods were 689 days for CAC and 501 days for Reference.

‡‡ Cox Proportional Hazards Regression; Univariate proportional hazards models account for matched data

Abbreviations: ACM = all-cause mortality; Aug = August; CAC = coronary artery calcium; CI = confidence interval; HR = hazard ratio; hs-CRP = high-sensitivity C-reactive protein; Jan = January; MI = myocardial infarction; mo = months NR = not reported; Scrn = Screening

##### Health Care Utilization

Three studies that reported health care utilization following CAC had mixed findings (Table 31). The EISNER RCT found no statistically significant increase in cardiac imaging or revascularization at up to 4 years after CAC screening compared to those who did not receive CAC screening.^11^ People who were randomized to CAC screening had a trend for increased nuclear stress testing (12.9%) compared to those who did not (10.0%), but this increase was not statistically significant (p=0.06). Two studies using administrative data evaluated downstream health care utilization following CAC. One study found no difference in cardiac imaging or revascularization in people without known diabetes or CVD who received CAC versus those who were denied CAC.^116^ However, one study using Medicare claims data found greater number of subsequent cardiac imaging tests and revascularization in asymptomatic people who received CAC compared to people receiving hsCRP or lipid screening.^117^ While the EISNER RCT had a superior study design, the findings may be less applicable to clinical practice. On the other hand, whilst the administrative data reflects clinical practice, the limitations of administrative data and the assembly of control groups limit our confidence as to how much, if any, increase in downstream testing may occur following CAC in asymptomatic adults for CVD risk prediction.

Table 31 Health Care Utilization Outcomes in Included Harms Studies (KQ3)

Author, Year Quality | Cohort Year(s) of recruitment | N analyzed | Age | % Women | F/U | Outcome | | IG N (%) | CG N (%) | HR (95% CI); p-value
Chi, 2014^116^ Fair | Administrative data Jan 2005 – Aug 2011 | 3,006^†^ IG: 2,139 CG: 867 | 18-64 yrs Mean (SD) = 52.76 (7.72) | 40.5% | 6 mo^**^ | Cardiac imaging tests | None | 1496 (76.80) | 585 (76.17) | NR; 0.52^‡^
Chi, 2014^116^ Fair | Administrative data Jan 2005 – Aug 2011 | 3,006^†^ IG: 2,139 CG: 867 | 18-64 yrs Mean (SD) = 52.76 (7.72) | 40.5% | 6 mo^**^ | Cardiac imaging tests | 1 type of test | 364 (18.69) | 152 (19.79) | NR
Chi, 2014^116^ Fair | Administrative data Jan 2005 – Aug 2011 | 3,006^†^ IG: 2,139 CG: 867 | 18-64 yrs Mean (SD) = 52.76 (7.72) | 40.5% | 6 mo^**^ | Cardiac imaging tests | 2 types of test | 81 (4.16) | 26 (3.39) | NR
Chi, 2014^116^ Fair | Administrative data Jan 2005 – Aug 2011 | 3,006^†^ IG: 2,139 CG: 867 | 18-64 yrs Mean (SD) = 52.76 (7.72) | 40.5% | 6 mo^**^ | Cardiac imaging tests | ≥3 types of test | 7 (0.36) | 5 (0.65) | NR
Chi, 2014^116^ Fair | Administrative data Jan 2005 – Aug 2011 | 3,006^†^ IG: 2,139 CG: 867 | 18-64 yrs Mean (SD) = 52.76 (7.72) | 40.5% | 6 mo^**^ | Cardiac imaging tests | Stress echocardiography | 257 (13.19) | 112 (14.58) | NR; 0.34^‡^
Chi, 2014^116^ Fair | Administrative data Jan 2005 – Aug 2011 | 3,006^†^ IG: 2,139 CG: 867 | 18-64 yrs Mean (SD) = 52.76 (7.72) | 40.5% | 6 mo^**^ | Cardiac imaging tests | Myocardial nuclear imaging | 187 (9.60) | 64 (8.33) | NR; 0.30^‡^
Chi, 2014^116^ Fair | Administrative data Jan 2005 – Aug 2011 | 3,006^†^ IG: 2,139 CG: 867 | 18-64 yrs Mean (SD) = 52.76 (7.72) | 40.5% | 6 mo^**^ | Cardiac imaging tests | Cardiac magnetic resonance imaging | 3 (0.15) | 3 (0.39) | NR; 0.36^‡^
Chi, 2014^116^ Fair | Administrative data Jan 2005 – Aug 2011 | 3,006^†^ IG: 2,139 CG: 867 | 18-64 yrs Mean (SD) = 52.76 (7.72) | 40.5% | 6 mo^**^ | Cardiac imaging tests | Diagnostic cardiac cauterization | 40 (2.05) | 23 (2.99) | NR; 0.14^‡^
Chi, 2014^116^ Fair | Administrative data Jan 2005 – Aug 2011 | 3,006^†^ IG: 2,139 CG: 867 | 18-64 yrs Mean (SD) = 52.76 (7.72) | 40.5% | 6 mo^**^ | Cardiac imaging tests | Cardiac positron emission tomography | 7 (0.36) | 1 (0.13) | NR; 0.45^‡^
Chi, 2014^116^ Fair | Administrative data Jan 2005 – Aug 2011 | 3,006^†^ IG: 2,139 CG: 867 | 18-64 yrs Mean (SD) = 52.76 (7.72) | 40.5% | 6 mo^**^ | Cardiac imaging tests | Coronary CT angiography | 43 (2.21) | 13 (1.69 | NR; 0.40^‡^
Chi, 2014^116^ Fair | Administrative data Jan 2005 – Aug 2011 | 3,006^†^ IG: 2,139 CG: 867 | 18-64 yrs Mean (SD) = 52.76 (7.72) | 40.5% | 6 mo^**^ | Therapeutic intervention | Therapeutic intervention (CABG) | 6 (0.31) | 5 (0.65) | NR; 0.20^‡^
Chi, 2014^116^ Fair | Administrative data Jan 2005 – Aug 2011 | 3,006^†^ IG: 2,139 CG: 867 | 18-64 yrs Mean (SD) = 52.76 (7.72) | 40.5% | 6 mo^**^ | Therapeutic intervention | Therapeutic intervention (PCI) | 64 (3.29) | 34 (4.43) | NR; 0.15^‡^
Rozanski, 2011^11^ Fair | EISNEr RCT May 2001 – May 2005 | 1,840 IG: 1256 CG: 584 | 58.2 ± 8.4 | 47.5% | 48 mo | Performed procedures | Resting ECG | 767 (58.5) | 380 (61.0%) | NR; 0.30
Rozanski, 2011^11^ Fair | EISNEr RCT May 2001 – May 2005 | 1,840 IG: 1256 CG: 584 | 58.2 ± 8.4 | 47.5% | 48 mo | Performed procedures | Stress nuclear | 169 (12.9) | 62 (10.0%) | NR; 0.06
Rozanski, 2011^11^ Fair | EISNEr RCT May 2001 – May 2005 | 1,840 IG: 1256 CG: 584 | 58.2 ± 8.4 | 47.5% | 48 mo | Performed procedures | Stress echocardiography | 195 (14.9) | 102 (16.4%) | NR; 0.39
Rozanski, 2011^11^ Fair | EISNEr RCT May 2001 – May 2005 | 1,840 IG: 1256 CG: 584 | 58.2 ± 8.4 | 47.5% | 48 mo | Performed procedures | Any stress test^*^ | 454 (34.6) | 211 (33.9%) | NR; 0.74
Rozanski, 2011^11^ Fair | EISNEr RCT May 2001 – May 2005 | 1,840 IG: 1256 CG: 584 | 58.2 ± 8.4 | 47.5% | 48 mo | Performed procedures | Cardiac CT | 101 (7.7) | 44 (7.1%) | NR; 0.62
Rozanski, 2011^11^ Fair | EISNEr RCT May 2001 – May 2005 | 1,840 IG: 1256 CG: 584 | 58.2 ± 8.4 | 47.5% | 48 mo | Performed procedures | Carotid ultrasound | 167 (12.7) | 88 (14.1%) | NR; 0.40
Rozanski, 2011^11^ Fair | EISNEr RCT May 2001 – May 2005 | 1,840 IG: 1256 CG: 584 | 58.2 ± 8.4 | 47.5% | 48 mo | Performed procedures | Cardiac catheterization | 43 (3.35) | 18 (2.9%) | NR; 0.71
Rozanski, 2011^11^ Fair | EISNEr RCT May 2001 – May 2005 | 1,840 IG: 1256 CG: 584 | 58.2 ± 8.4 | 47.5% | 48 mo | Performed procedures | Coronary revascularization | 30 (2.3) | 11 (1.8%) | NR; 0.46
Shreibati, 2014^117^ Fair | Medicare Administrative data 2006-2011 | 8,358 CAC: 4.179 hs-CRP: 4.179 | Mean (SD) = 73.2 yrs (6.05) | CAC: 59.1% hsCRP: 60.6% | 6 mo^**^ | Outcomes for matched cohorts CAC and CRP | Myocardial perfusion scintigraphy (MPS) | 1014 (64.7)^§^ | 590 (33.7)^§^ | 2.15 (1.57-2.94)#; <0.001
Shreibati, 2014^117^ Fair | Medicare Administrative data 2006-2011 | 8,358 CAC: 4.179 hs-CRP: 4.179 | Mean (SD) = 73.2 yrs (6.05) | CAC: 59.1% hsCRP: 60.6% | 6 mo^**^ | Outcomes for matched cohorts CAC and CRP | Exercise treadmill test (ETT) | 292 (15.7)^§^ | 201 (10.6)^§^ | 2.04 (1.24-3.36)^#^; 0.005
Shreibati, 2014^117^ Fair | Medicare Administrative data 2006-2011 | 8,358 CAC: 4.179 hs-CRP: 4.179 | Mean (SD) = 73.2 yrs (6.05) | CAC: 59.1% hsCRP: 60.6% | 6 mo^**^ | Outcomes for matched cohorts CAC and CRP | Stress transthoracic echocardiography (TTE) | 160 (8.4)^§^ | 87 (4.5)^§^ | 3.00 (1.34-6.68)#; 0.007
Shreibati, 2014^117^ Fair | Medicare Administrative data 2006-2011 | 8,358 CAC: 4.179 hs-CRP: 4.179 | Mean (SD) = 73.2 yrs (6.05) | CAC: 59.1% hsCRP: 60.6% | 6 mo^**^ | Outcomes for matched cohorts CAC and CRP | Coronary CT angiography (CCTA) | 56 (2.9)^§^ | 40 (2.0)^§^ | 3.66 (1.02-13.14)^#^; 0.046
Shreibati, 2014^117^ Fair | Medicare Administrative data 2006-2011 | 8,358 CAC: 4.179 hs-CRP: 4.179 | Mean (SD) = 73.2 yrs (6.05) | CAC: 59.1% hsCRP: 60.6% | 6 mo^**^ | Outcomes for matched cohorts CAC and CRP | Any Testǁ | 1268 (86.1)^§^ | 474 (44.2)^§^ | 2.22 (1.68-2.93)^#^; <0.001
Shreibati, 2014^117^ Fair | Medicare Administrative data 2006-2011 | 8,358 CAC: 4.179 hs-CRP: 4.179 | Mean (SD) = 73.2 yrs (6.05) | CAC: 59.1% hsCRP: 60.6% | 6 mo^**^ | Outcomes for matched cohorts CAC and CRP | Coronary angiography (Cath) | 247 (13.2)^§^ | 112 (15.8)^§^ | 3.54 (1.91-6.55)^#^; <0.001
Shreibati, 2014^117^ Fair | Medicare Administrative data 2006-2011 | 8,358 CAC: 4.179 hs-CRP: 4.179 | Mean (SD) = 73.2 yrs (6.05) | CAC: 59.1% hsCRP: 60.6% | 6 mo^**^ | Outcomes for matched cohorts CAC and CRP | Percutaneous coronary intervention (PCI) | 90 (4.6)^§^ | 30 (1.5)^§^ | 8.5 (1.96-36.79)^#^; 0.004
Shreibati, 2014^117^ Fair | Medicare Administrative data 2006-2011 | 8,358 CAC: 4.179 hs-CRP: 4.179 | Mean (SD) = 73.2 yrs (6.05) | CAC: 59.1% hsCRP: 60.6% | 6 mo^**^ | Outcomes for matched cohorts CAC and CRP | CABG | 43 (2.2)^§^ | 17 (0.87)^§^ | 2.66 (0.70-10.05)^#^; 0.15
Shreibati, 2014^117^ Fair | Medicare Administrative data 2006-2011 | 8,358 CAC: 4.179 hs-CRP: 4.179 | Mean (SD) = 73.2 yrs (6.05) | CAC: 59.1% hsCRP: 60.6% | 6 mo^**^ | Outcomes for matched cohorts CAC and CRP | PCI/CABG | 128 (6.7)^§^ | 46 (2.4)^§^ | 4.80 (1.83-12.58)^#^; 0.001
Shreibati, 2014^117^ Fair | Medicare Administrative data 2006-2011 | 6,250 CAC: 3.125 Lipid Scrn: 3.125 | Mean (SD) = 72.5 (5.85) | CAC: 59.1% Lipid Scrn: 57.9% | 6 mo^**^ | Outcomes for matched cohorts CAC and Lipid Screening | Myocardial perfusion scintigraphy (MPS) | 711 (59.8)^§^ | 205 (14.7)^§^ | 4.81 (3.18-7.28)^#^; <0.001
Shreibati, 2014^117^ Fair | Medicare Administrative data 2006-2011 | 6,250 CAC: 3.125 Lipid Scrn: 3.125 | Mean (SD) = 72.5 (5.85) | CAC: 59.1% Lipid Scrn: 57.9% | 6 mo^**^ | Outcomes for matched cohorts CAC and Lipid Screening | Exercise treadmill test (ETT) | 224 (16.3)^§^ | 76 (5.3)^§^ | 2.83 (1.65-4.85)^#^; <0.001
Shreibati, 2014^117^ Fair | Medicare Administrative data 2006-2011 | 6,250 CAC: 3.125 Lipid Scrn: 3.125 | Mean (SD) = 72.5 (5.85) | CAC: 59.1% Lipid Scrn: 57.9% | 6 mo^**^ | Outcomes for matched cohorts CAC and Lipid Screening | Stress transthoracic echocardiography (TTE) | 120 (8.4)^§^ | 35 (2.4)^§^ | 2.60 (1.25-5.39)^#^; 0.010
Shreibati, 2014^117^ Fair | Medicare Administrative data 2006-2011 | 6,250 CAC: 3.125 Lipid Scrn: 3.125 | Mean (SD) = 72.5 (5.85) | CAC: 59.1% Lipid Scrn: 57.9% | 6 mo^**^ | Outcomes for matched cohorts CAC and Lipid Screening | Coronary Ct angiography (CCTA) | 33 (2.3)^§^ | 3 (0.21)^§^ | 7.00 (0.86-56.89)^#^; 0.069
Shreibati, 2014^117^ Fair | Medicare Administrative data 2006-2011 | 6,250 CAC: 3.125 Lipid Scrn: 3.125 | Mean (SD) = 72.5 (5.85) | CAC: 59.1% Lipid Scrn: 57.9% | 6 mo^**^ | Outcomes for matched cohorts CAC and Lipid Screening | Any Testll | 902 (81.8)^§^ | 268 (20.8)^§^ | 4.30 (3.04-6.06)^#^; <0.001
Shreibati, 2014^117^ Fair | Medicare Administrative data 2006-2011 | 6,250 CAC: 3.125 Lipid Scrn: 3.125 | Mean (SD) = 72.5 (5.85) | CAC: 59.1% Lipid Scrn: 57.9% | 6 mo^**^ | Outcomes for matched cohorts CAC and Lipid Screening | Coronary angiography (Cath) | 185 (13.3)^§^ | 57 (4.0)^§^ | 4.23 (2.31-7.74)^#^; <0.001
Shreibati, 2014^117^ Fair | Medicare Administrative data 2006-2011 | 6,250 CAC: 3.125 Lipid Scrn: 3.125 | Mean (SD) = 72.5 (5.85) | CAC: 59.1% Lipid Scrn: 57.9% | 6 mo^**^ | Outcomes for matched cohorts CAC and Lipid Screening | Percutaneous coronary intervention (PCI) | 67 (4.6)^§^ | 20 (1.4)^§^ | 3.25 (1.06-9.96)^#^; 0.039
Shreibati, 2014^117^ Fair | Medicare Administrative data 2006-2011 | 6,250 CAC: 3.125 Lipid Scrn: 3.125 | Mean (SD) = 72.5 (5.85) | CAC: 59.1% Lipid Scrn: 57.9% | 6 mo^**^ | Outcomes for matched cohorts CAC and Lipid Screening | CABG | 34 (2.3)^§^ | 8 (0.55)^§^ | 4.50 (0.97-20.93)^#^; 0.054
Shreibati, 2014^117^ Fair | Medicare Administrative data 2006-2011 | 6,250 CAC: 3.125 Lipid Scrn: 3.125 | Mean (SD) = 72.5 (5.85) | CAC: 59.1% Lipid Scrn: 57.9% | 6 mo^**^ | Outcomes for matched cohorts CAC and Lipid Screening | PCI/CABG | 96 (6.7)^§^ | 27 (1.9)^§^ | 3.50 (1.41-8.67)^#^; 0.007

* Stress nuclear, stress echocardiography, or treadmill exercise electrocardiography

† Only patients who had 6-month continuous medical eligibility from index date and were classified as non-high-risk for CHD were included in analysis, regardless of whether there was an occurrence of cardiovascular event after index date

‡ P value for utilization was based on χ^2^ / Fisher exact test; P value for cost was based on Wilcoxon rank-sum test

§ Number of events (Incidence rate per 1000 person-years).

ǁ indicate any noninvasive cardiac testing

# Cox Proportional Hazards Regression; Univariate proportional hazards models account for matched data.

** following index date

Abbreviations: CABG = Coronary artery bypass surgery; CAC = coronary artery calcium; CI = confidence interval; CRP = c-reactive protein; CT = computed tomography; ECG = electrocardiography; HR = hazard ratio; hsCRP = high-sensitivity C-reactive protein; MPS = myocardial perfusion scintigraphy

## KQ4 Does Treatment Guided by Nontraditional Risk Factors, in Addition to Traditional Risk Factors, Lead to Reduced Incidence of Cardiovascular Events and/or Mortality?

### Summary

We did not identify any trials examining nontraditional risk factor assessment in addition to the FRS or PCE to guide treatment and reduce cardiovascular events. We included four RCTs that evaluated whether pharmacologic treatment guided by nontraditional risk factor assessment alone (i.e., ABI, hsCRP, or CAC) lead to reduced CVD events and/or mortality.^120-124^ Two of these trials evaluated aspirin therapy in individuals with an abnormal ABI, one trial evaluated statin therapy in people with an abnormal hsCRP, and one trial evaluated statins in individuals with an abnormal CAC. Two good-quality trials (AAA and POPADAD) in asymptomatic adults (including one trial exclusively in participants with diabetes) with an abnormal ABI did not find any statistically significant benefit for low-dose aspirin (aspirin 100 mg daily) on reducing CVD outcomes or all-cause mortality compared to placebo after approximately 7 to 8 years of followup. One fair-quality trial (St. Francis Heart Study) in asymptomatic people with LDL <175 mg/dL and CAC at the 80^th^ percentile or greater for age and gender did not find any statistically significant benefit for moderate-intensity statin therapy (atorvastatin 20 mg daily) on reducing CVD outcomes compared to placebo after about 4 years of followup. However, this study had a lower than expected number of events and was terminated early. One good-quality trial, JUPITER, in asymptomatic people with LDL <130 mg/dL and hsCRP of 2.0 or greater mg/L found a rather large relative reduction in CVD events for high-intensity statin therapy (rosuvastatin 20 mg daily) compared to placebo (HR 0.56 [95% CI, 0.46 to 0.69]) at approximately 2 years (terminated early); however, absolute benefits were small.

### Detailed Results

#### Description of Studies

Two RCTs, Aspirin for Asymptomatic Atherosclerosis (AAA) (n=3,350) and Prevention of Progression of Arterial Disease and Diabetes (POPADAD) (n=1,276) evaluated the benefit of low-dose aspirin in asymptomatic people with abnormal ABI (Tables 32 and 33).^122,^ ^123^ Both trials were conducted in Scotland, with a mean age of participants of about 60 to 62 years. The AAA trial included a predominance of women (71.5%). The POPADAD trial was exclusively in people with known diabetes, approximately one-third of whom were treated with insulin. Only 2.6 percent of people in the AAA trial had diabetes. Approximately one-third of the participants in both trials were identified as current smokers. At baseline 4.2 percent of participants were taking a statin (25% at 5 years) in the AAA trial. The POPADAD trial did not report the proportion taking a statin. Neither trial used the conventional 0.90 threshold for an abnormal ABI; the AAA trial defined an abnormal ABI as ≤0.95, and the POPADAD trial defined an abnormal ABI as ≤0.99. Both trials randomized participants to take aspirin 100 mg daily or placebo; the POPADAD trial used a factorial design to also evaluate a combination antioxidant capsule (data not discussed). There was no evidence of an interaction between aspirin and the antioxidants. Both trials defined a composite CVD outcome (i.e., MI, CVA, revascularization or amputation for critical ischemia) as their primary endpoint, and were powered to detect a difference in this outcome. Average followup was 8.2 years for the AAA trial (terminated early due to futility) and 6.7 years for the POPADAD trial. Both of these trials were good-quality RCTs with good baseline comparability, intention to treat analyses, and minimal loss to followup, and were powered for composite CVD outcomes.

Table 32 Participant Characteristics of Included Treatment Studies (KQ4)

Trial name Author, Year | Quality | Country | N | Age, years (mean) | % Women | SBP/DBP, mm Hg (mean)^*^ | TC, mg/dL (mean) | LDL, mg/dL | HDL, mg/dL | % with DM | % Current smokers | % with elevated NTRF | Mean NTRF | Annual risk of CVD Events (%)^‡^
AAA Fowkes, 2010^122^ | Good | Scotland | 3,350 | 62.0 | 71.5 | 148/84 | 238^§^ | NR | NR | 2.6 | 33.0 | 100 with ABI ≤0.95 | ABI: 0.86 | 0.99
POPADAD Belch, 2008^123^ | Good | Scotland | 1,276 | 60.3 | 55.9 | 145/79 | 213^¶^ | 121^¶^ | 47^¶^ | 100^†^ | 31.1 | 100 with ABI ≤0.99 | ABI: 0.90 | 2.53
St. Francis Heart Study Arad, 2005^121^ | Fair | US | 1,005 | 59.0 | 26.5 | NR^**^ | 226 | 146 | 50 | 8.5 | 12.5 | 100 with CAC >80^th^ percentile | CAC: 545.4 | 2.30
JUPITER Ridker, 2008 120 | Good | 26 Countries | 17,802 | 66.0^¶^ | 38.2 | 134/80^¶^ | 186^¶^ | 108^¶^ | 49^¶^ | 0 | 15.8 | 100 with CRP ≥2.0 mg/L | CRP 4.2 mg/L^¶^ | 1.48

* In AAA, 15.2% were treated with a diuretic, 6.4% were treated with a nitrate or calcium channel blocker, 6.2% were treated with an angiotensin-converting enzyme inhibitor or angiotensin II receptor blocker, and 9.8% were treated with a beta blocker. Hypertension treatment was not reported in POPADAD.

† Mean HbA1c of 8.0%

‡ Data are from Berger 2011 meta-analysis^161^ or similarly calculated as percent with cardiovascular events in control group/years of followup. Mean FRS not reported in any trial. Approximately half of the JUPITER population had FRS <10% (Figure 2)

§ 4.2% were on lipid-lowering treatment at baseline and 25% were treated at 5 years; use of lipid-lowering treatment was not reported in POPADAD.

¶ Median

** 40.5% with hypertension

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ABI = ankle brachial index; CAC = coronary artery calcium score; CRP = c-reactive protein; CVD = cardiovascular disease; DBP = diastolic blood pressure; FRS - Framingham Risk Score; HbA1c = glycated hemoglobin; HDL = high-density lipoprotein cholesterol; JUPITER = Justification for the Use of Statins in Prevention: an Intervention Trial Evaluating Rosuvastatin; LDL = low-density lipoprotein cholesterol; N = number; NR = not reported; NTRF = nontraditional risk factor; PAD = peripheral arterial disease; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; SBP = systolic blood pressure; TC = total cholesterol

Table 33 Methodological and Intervention Characteristics of Included Treatment Studies (KQ4)

Trial name Author, year | N | Study design | Inclusion | Recruitment | Pharmacotherapy dose & formulation | Duration & Mean followup | Primary endpoint | Secondary endpoints | Adherence & crossover
AAA Fowkes, 2010^122^ | 3,350 | RCT | Men and women ages 50-75 years with no history of vascular disease and ABI ≤0.95 | Community Health registry and community volunteer | 100 mg daily, tablet, enteric coated | 8.2 years^*^ | Composite outcome: initial fatal or nonfatal coronary event or CVA or revascularization | 1) All initial vascular events, defined as a composite outcome: Primary end point event or angina, intermittent claudication, or TIA; 2) all-cause mortality | Participants adhered to study medication for 60% of p-y of F/U. Effect on primary end point did not differ between those taking and not taking medication at 5 years
POPADAD Belch, 2008^123^ | 1,276 | 2x2 RCT, Antioxidant | Men and women age ≥40 years with diabetes, no symptomatic CVD, and ABI ≤0.99 | Diabetes clinics | 100 mg daily, tablet, not enteric coated | 6.7 years^†^ | 2 composite end points: 1) death froM CHD or CVA, nonfatal MI or CVA, above ankle Amputation for critical limb ischemia; 2) death from CHD or CVA | All-cause mortality; nonfatal MI; and occurrence of other individual vascular events | At 1 year, 14% of participants stopped taking trial drugs; at 5 years, 50% (cumulative) of patients withdrew from trial therapy
St. Francis Heart Study Arad, 2005^121^ | 1,005 | RCT | Men and women ages 50-70 years with no history, symptoms or signs of ASCVD and CAC score >80^th^ percentile for age and gender | Mixed; population-based, health insurance, and community volunteer | Atorvastatin 20 mg daily, vitamin C 1 g daily, and vitamin E (alpha tocopherol), 1,000 U daily, and aspirin 81 mg daily (aspirin given to both groups) | 4.3 years^*^ | Composite of all first ASCVD events: coronary death, nonfatal MI, surgical or percutaneous coronary revascularization procedures, non-hemorrhagic CVA, and peripheral vascular surgery | All coronary events; the sum of nonfatal MI and coronary deaths; and all events occurring >90 days after randomization | Consumption of 285% of study medication Averaged 85% for atorvastatin or its matching placebo, 88% for vitamins C and E or their matching placebos and 79% for aspirin; 14% in control group began taking aspirin without a CVD event
JUPITER Ridker, 2008^120^ | 17,802 | RCT | Men ≥50 years and women 260 years with no history of CVD or DM and LDL-C <130 mg/dl and hs-CRP ≥2.0 mg/L | NR | Rosuvastatin 20 mg once daily | 1.9 years^*,†^ | First major CVD event, defined as nonfatal MI, nonfatal CVA, hospitalization for unstable angina, arterial revascularization, or confirmed death from CVD causes | Components of the primary end point considered individually–arterial revascularization or hospitalization for unstable angina, MI, CVA, or death froM CVD causes–and death from any cause | At the time the study was terminated, 75% of participants were taking their study pills

* Terminated early

† Median

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis; ABI = ankle brachial index; ASA = aspirin; ASCVD = atherosclerotic cardiovascular disease; CHD = coronary Heart disease; CVA = cardiovascular accident; F/U = followup; JUPITER = Justification for the Use of Statins in Prevention: an Intervention Trial Evaluating Rosuvastatin; MI = myocardial infarction; N = number; PAD = peripheral arterial disease; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; RCT = randomized controlled trial; p-y = patient years; TIA = transient ischemic attack

One RCT, Justification for the Use of Statins in Prevention: an Intervention Trial Evaluating Rosuvastatin (JUPITER) (n=17,802), evaluated the benefit of rosuvastatin 20 mg daily in persons with an elevated hsCRP but normal LDL (Tables 32 and 33).^120^ This trial was conducted across 26 countries. The median age of participants was 66 years old, approximately 38 percent of whom were women and approximately 25 percent of whom were African American or Latino. Participants had to have an LDL <130 mg/dL. People with known diabetes were excluded from the trial. Approximately 16 percent were current smokers and approximately 17 percent of participants were taking aspirin. An abnormal hsCRP was defined as ≥2.0 mg/L (as opposed to 3.0 mg/L which was most often employed in included KQ2 studies); the median hsCRP of participants was 4.2 mg/L. Half of trial participants had an FRS of 10 percent or less. The primary endpoint was a composite CVD outcome that included MI, CVA, hospitalization for unstable angina, and/or revascularization. This was a good-quality trial but terminated early because the stopping boundary was crossed at the first efficacy evaluation; thus, the trial had a median 1.9 years of followup.

One RCT, the St. Francis Heart Study (n=1,005), evaluated the benefit of atorvastatin 20 mg daily in individuals with elevated CAC (Tables 32 and 33).^121^ This trial was conducted in the United States. The mean age was 59 years old, and approximately 26 percent of participants were women. Participants had to have an LDL <175 mg/dL. Approximately 9 percent of participants had diabetes and 13 percent were current smokers. All participants were given low-dose aspirin as part of the trial. The mean hsCRP in participants was lower in this trial (about 2 mg/L) as compared to the JUPITER trial (about 4 mg/L). An abnormal CAC was defined as above the 80^th^ percentile for age and sex. This trial also evaluated vitamin C and E (data not discussed). The primary endpoint was a composite CVD outcome that included MI, CVA, and revascularization. This study did not report on adverse effects of atorvastatin. This was a fair-quality trial in that it was not powered for composite CVD outcomes due to a lower than expected event rate. Trial investigators terminated the study early, with mean 4.3 years of followup.

##### Cardiovascular Outcomes

AAA and POPADAD found no difference between low-dose aspirin and placebo in composite CVD outcomes (Tables 34 and 35). The AAA trial reported 10.8 percent CVD events in the aspirin and 10.5 percent events in the placebo group, with an adjusted HR of 1.0 (95% CI, 0.81 to 1.23) at 8.2 years of followup. The POPADAD trial reported 18.2 percent CVD events in the aspirin and 18.3 percent events in the placebo group (HR 0.98 [95% CI, 0.76 to 1.26]) at 6.7 years of followup. Both trials reported age- and sex-stratified analyses, again with no differences between randomized groups (Tables 36 and 37). Both trials also found no difference in all-cause mortality.

Table 34 Composite and Mortality Outcomes in Included Treatment Studies (KQ4)

Outcome | Trial name Author, Year | Mean F/U, years | IG N analyzed | IG N events (%) | CG N analyzed | CG N events (%) | IG vs. CG HR (95% CI)
Primary Composite CVD Outcome^*^ | AAA Fowkes, 2010^122^ | 8.2 | 1,675 | 181 (10.8%) | 1,675 | 176 (10.5%) | 1.00 (0.81 to 1.23)^†^
Primary Composite CVD Outcome^*^ | POPADAD Belch, 2008^123^ | 6.7^‡^ | 638 | 116 (18.2%) | 638 | 117 (18.3%) | 0.98 (0.76 to 1.26)
Primary Composite CVD Outcome^*^ | St. Francis Heart Study arad, 2005 ^121^ | 4.3 | 490 | 34 (6.9%) | 515 | 51 (9.9%) | 0.70 (0.44 to 1.10) §ǁ, p=0.08^¶,#^
Primary Composite CVD Outcome^*^ | JUPITER Ridker, 2008 ^120^ | 1.9^‡^ | 8,901 | 142 (1.6%) | 8,901 | 251 (2.8%) | 0.56 (0.46 to 0.69)
Composite Fatal Coronary Events + CVA + CVD Death | AAA Fowkes, 2010^122^ | 8.2 | 1,675 | 35 (2.1%)^§^ | 1,675 | 30 (1.8%)^§^ | 1.17 (0.72 to 1.89)^§^ǁ
Composite Fatal Coronary Events + CVA + CVD Death | POPADAD Belch, 2008^123^ | 6.7^‡^ | 638 | 43 (6.7%) | 638 | 35 (5.5%) | 1.23 (0.79 to 1.93)
Composite Nonfatal MI + CVA | AAA Fowkes, 2010^122^ | 8.2 | 1,675 | 99 (5.9%)^§^ | 1,675 | 106 (6.3%)^§^ | 0.93 (0.72 to 1.22)^§^ǁ
Composite Nonfatal MI + CVA | POPADAD Belch, 2008^123^ | 6.7^‡^ | 638 | 84 (13.2%)^§^ | 638 | 97 (15.2%)^§^ | 0.87 (0.66 to 1.14)^§^ǁ
Composite Nonfatal MI + CVA | JUPITER Ridker, 2008 ^120^ | 1.9^‡^ | 8,901 | 52 (0.6%)^§^ | 8,901 | 120 (1.3%)^§^ | 0.43 (0.31 to 0.60)^§^ǁ
All-Cause Mortality | AAA Fowkes, 2010^122^ | 8.2 | 1,675 | 176 (10.5%) | 1,675 | 186 (11.1%) | 0.95 (0.77 to 1.16)
All-Cause Mortality | POPADAD Belch, 2008^123^ | 6.7^‡^ | 638 | 94 (14.7%) | 638 | 101 (15.8%) | 0.93 (0.71 to 1.24)
All-Cause Mortality | JUPITER Ridker, 2008 ^120^ | 1.9^‡^ | 8,901 | 198 (2.2%) | 8,901 | 247 (2.8%) | 0.80 (0.67 to 0.97)

* Defined in AAA as: initial fatal or nonfatal coronary event or CVA or revascularization; defined in POPADAD as death from CHD or CVA, nonfatal MI or CVA, above ankle Amputation for critical limb ischemia; defined in St. Francis Heart Study as coronary death, nonfatal MI, surgical or percutaneous coronary revascularization procedures, non-hemorrhagic CVA, and peripheral vascular surgery; defined in JUPITER as nonfatal MI, nonfatal CVA, hospitalization for unstable angina, an arterial revascularization, or cardiovascular death.

† HR adjusted for baseline age, ankle-brachial index, cholesterol, systolic blood pressure, smoking, and socioeconomic status; unadjusted HR 1.03 (95% CI, 0.84 to 1.27)

‡ Median

§ Calculated

ǁ RR

¶ Adjusted for standard risk factors: age, elevated total cholesterol, hypertension, diabetes, smoking, and family history of premature coronary artery disease (Arad, 2000)

# All ASCVD events after 90 days also reported. IG: 30/486 (6.2%); CG 47/511 (9.2%); p=0.07

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis Trial; Adj = adjusted; CG = control group; CI = confidence interval; CVA = cardiovascular accident; CVD = cardiovascular disease; HR = hazard ratio; IG = intervention group; JUPITER = Justification for the Use of Statins in Prevention: an Intervention Trial Evaluating Rosuvastatin; MI = myocardial infarction; N = population; NR = not reported; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; RR = relative risk

Table 35 Myocardial Infarction and CVA Outcomes in Included Treatment Studies (KQ4)

Outcome | Trial name Author, Year | Mean F/U, years | IG N analyzed | IG N events (%) | CG N analyzed | CG N events (%) | IG vs. CG HR (95% CI)
Nonfatal MI + Fatal Coronary Events | AAA Fowkes, 2010^122^ | 8.2 | 1,675 | 90 (5.4%)^*^ | 1,675 | 86 (5.1%)^*^ | 1.05 (0.77 to 1.40)^*,†^
Nonfatal MI + Fatal Coronary Events | POPADAD Belch, 2008^123^ | 6.7^‡^ | 638 | 90 (14.1%)^*^ | 638 | 82 (12.9%)^*^ | 1.10 (0.83 to 1.45)^*,†^
Nonfatal MI + Fatal Coronary Events | St. Francis Heart Study arad, 2005 ^121^ | 4.3 | 490 | 9 (1.8%) | 515 | 17 (3.3%) | 0.56 (0.22 to 1.32)^*,†^, p=0.14
Nonfatal MI + Fatal Coronary Events | JUPITER Ridker, 2008ǁ ^120^ | 1.9^‡^ | 8,901 | 31 (0.3%) | 8,901 | 68 (0.8%) | 0.46 (0.30 to 0.70)
Fatal Coronary Events | AAA Fowkes, 2010^122^ | 8.2 | 1,675 | 28 (1.7%) | 1,675 | 18 (1.1%) | 1.56 (0.86 to 2.80)^*,†^
Fatal Coronary Events | POPADAD Belch, 2008^123^ | 6.7^‡^ | 638 | 35 (5.5%) | 638 | 26 (4.1%) | 1.35 (0.81 to 2.25)
Nonfatal MI | AAA Fowkes, 2010^122^ | 8.2 | 1,675 | 62 (3.7%) | 1,675 | 68 (4.1%) | 0.91 (0.65 to 1.28)^*,†^
Nonfatal MI | POPADAD Belch, 2008^123^ | 6.7^‡^ | 638 | 55 (8.6%) | 638 | 56 (8.8%) | 0.98 (0.68 to 1.43)
Nonfatal MI | JUPITER Ridker, 2008ǁ ^120^ | 1.9^‡^ | 8,901 | 22 (0.2%) | 8,901 | 62 (0.7%) | 0.35 (0.22 to 0.58)
Total CVA | AAA Fowkes, 2010^122^ | 8.2 | 1,675 | 44 (2.6%)^*^ | 1,675 | 50 (3.0%)^*^ | 0.88 (0.59 to 1.31)^*,†^
Total CVA | POPADAD Belch, 2008^123^ | 6.7^‡^ | 638 | 37 (5.8%)^*^ | 638 | 50 (7.8%)^*^ | 0.74 (0.49 to 1.12)^*,†^
Total CVA | JUPITER Ridker, 2008 ^120^ | 1.9^‡^ | 8,901 | 33 (0.4%) | 8,901 | 64 (0.7%) | 0.52 (0.34 to 0.79)
Fatal CVA | AAA Fowkes, 2010^122^ | 8.2 | 1,675 | 7 (0.4%) | 1,675 | 12 (0.7%) | 0.58 (0.23 to 1.48)^*,†^
Fatal CVA | POPADAD Belch, 2008^123^ | 6.7^‡^ | 638 | 8 (1.3%) | 638 | 9 (1.4%) | 0.89 (0.34 to 2.30)
Fatal CVA | JUPITER Ridker, 2008 ^120^ | 1.9^‡^ | 8,901 | 3 (0.03%)^*^ | 8,901 | 6 (0.07%)^*^ | 0.5 (0.08 to 2.34)^*,†^
Nonfatal CVA | AAA Fowkes, 2010^122^ | 8.2 | 1,675 | 37 (2.2%) | 1,675 | 38 (2.3%) | 0.97 (0.62 to 1.52)^*,†^
Nonfatal CVA | POPADAD Belch, 2008^123^ | 6.7^‡^ | 638 | 29 (4.6%) | 638 | 41 (6.4%) | 0.71 (0.44 to 1.14)
Nonfatal CVA | JUPITER Ridker, 2008 ^120^ | 1.9^‡^ | 8,901 | 30 (0.3%) | 8,901 | 58 (0.6%) | 0.52 (0.33 to 0.80)
Total ischemic CVA | AAA Fowkes, 2010^122^ | 8.2 | 1,675 | 30 (1.8%)^*^ | 1,675 | 37 (2.2%)^*^ | 0.81 (0.50 to 1.31)^*,†^
Fatal ischemic CVA | AAA Fowkes, 2010^122^ | 8.2 | 1,675 | 2 (0.1%) | 1,675 | 7 (0.4%) | 0.29 (0.06 to 1.37)^*,†^
Fatal ischemic CVA | POPADAD Belch, 2008^123^ | 6.7^‡^ | 638 | 3 (0.5%) | 638 | 5 (0.8%) | 0.60 (0.14 to 2.50)^*,†^
Nonfatal ischemic CVA | AAA Fowkes, 2010^122^ | 8.2 | 1,675 | 28 (1.7%) | 1,675 | 30 (1.8%) | 0.93 (0.56 to 1.56)^*,†^

* Calculated

† RR

‡ Median

ǁ (Reported as any MI

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis Trial; ASCVD = atherosclerotic cardiovascular disease; CG = control group; CI = confidence interval; CVA= cardiovascular accident; HR = hazard ratio; IG = intervention group; JUPITER = Justification for the Use of Statins in Prevention: an Intervention Trial Evaluating Rosuvastatin; N = population; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; RR = relative risk

Table 36 Age Subgroup Analyses for Primary Outcomes in Included Treatment Studies (KQ4)

Trial name Author, Year | Mean F/U, years | Type of analysis | Outcome | Age, years | IG N analyzed | IG N events (%) | CG N analyzed | CG N events(%) | IG vs. CG HR (95% CI) | P-Value for interaction
AAA Fowkes, 2010^122^ | 8.2 | A priori | Primary composite: Initial fatal or nonfatal coronary event, CVA or revascularization | <62 | NR | 57 (NR)^*^ | NR | 70 (NR)^†^ | 0.85 (0.60 to 1.20) | NR
AAA Fowkes, 2010^122^ | 8.2 | A priori | Primary composite: Initial fatal or nonfatal coronary event, CVA or revascularization | ≥62 | NR | 124 (NR)^‡^ | NR | 106 (NR)^§^ | 1.13 (0.87 to 1.47) | NR
POPADAD Belch, 2008^123^ | 6.7^ǁ^ | Specification unclear | Primary composite: death from CHD or CVA, nonfatal MI or CVA, or above Ankle amputation for critical limb ischemia | <60 | 297 | 38 (12.8%) | 315 | 36 (11.4%) | 1.11 (0.70 to 1.75) | 0.77
POPADAD Belch, 2008^123^ | 6.7^ǁ^ | Specification unclear | Primary composite: death from CHD or CVA, nonfatal MI or CVA, or above Ankle amputation for critical limb ischemia | ≥60 | 341 | 78 (22.9%) | 323 | 81 (25.1%) | 0.89 (0.65 to 1.21) | 0.77
JUPITER Ridker, 2008^120^ | 1.9^ǁ^ | A priori | Primary end point: MI, CVA, hospitalization for unstable angina, arterial revascularization, or CVD death | ≤65 | NR | NR | NR | NR | NR | 0.32
JUPITER Ridker, 2008^120^ | 1.9^ǁ^ | A priori | Primary end point: MI, CVA, hospitalization for unstable angina, arterial revascularization, or CVD death | >65 | NR | NR | NR’ | NR | NR | 0.32

* 8.6 per 1,000 p-y (95% CI, 6.5 to 11.2)

† 10.2 per 1,000 p-y (95% CI, 8.0 to 12.9)

‡ 18.8 per 1,000 p-y (95% CI, 15.6 to 22.4)

§ 16.6 per 1,000 p-y (95% CI, 13.6 to 20.1)

ǁ Median.

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis Trial; CG = control group; CI = confidence interval; CHD = coronary heart disease; CVA = cardiovascular accident; HR = hazard ratio; IG = intervention group; JUPITER = Justification for the Use of Statins in Prevention: an Intervention Trial Evaluating Rosuvastatin; MI = myocardial infarction; NR = not reported; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; p-y: person-years

JUPITER found a benefit for hsCRP-guided, high-intensity statin therapy (Tables 34 and 35). This trial reported 1.6 percent CVD events in the rosuvastatin group compared to 2.8 percent events in the placebo group (HR 0.56 [95% CI, 0.46 to 0.69]) at 1.9 years of followup. Benefits were statistically significant for both MI and CVA outcomes individually. Benefits were statistically significant for both men and women, as well as for people with a baseline FRS of ≤10 percent and >10 percent 10-year risk, in a priori specified analyses (i.e., there was no suggestion of effect modification based on interaction testing) (Table 37). This trial also found a statistically significant difference in all-cause mortality, with 2.2 percent deaths in the rosuvastatin group versus 2.8 percent deaths in the placebo group (HR 0.80 [95% CI 0.67 to 0.97]).

Table 37 Sex Subgroup Analyses for Primary Outcomes in Included Treatment Studies (KQ4)

Trial name Author, Year | Mean F/U, years | Type of analysis | Outcome | Sex | IG N analyzed | IG N events(%) | CG N analyzed | CG N events (%) | IG vs. CG HR (95% CI) | P-Value for interaction
AAA Fowkes, 2010^122^ | 8.2 | A priori | Primary composite: initial (earliest) fatal or nonfatal coronary event or CVA or revascularization | Men | 481 | 96 (20.0%) | 473 | 83 (17.5%) | 1.15 (0.86 to 1.54)^*,†^ | NR
AAA Fowkes, 2010^122^ | 8.2 | A priori | Primary composite: initial (earliest) fatal or nonfatal coronary event or CVA or revascularization | Women | 1,194 | 85 (7.1%) | 1,202 | 93 (7.7%) | 0.92 (0.68 to 1.23)^*,†^ | NR
AAA Fowkes, 2010^122^ | 8.2 | A priori | Primary composite: initial (earliest) fatal or nonfatal coronary event or CVA or revascularization | Women | 352 | 17 (4.8%) | 361 | 16 (4.4%) | 1.09 (0.55 to 2.16)
POPADAD Belch, 2008^123^ | 6.7^‡^ | Specification unclear | Primary composite: death from CHD or CVA, nonfatal MI or CVA, or above Ankle amputation for critical limb ischemia | Men | 286 | 68 (23.8%) | 277 | 62 (22.4%) | 1.04 (0.74 to 1.47) | 0.54
POPADAD Belch, 2008^123^ | 6.7^‡^ | Specification unclear | Primary composite: death from CHD or CVA, nonfatal MI or CVA, or above Ankle amputation for critical limb ischemia | Women | 352 | 48 (13.6%) | 361 | 55 (15.2%) | 0.89 (0.60 to 1.31) | 0.54
JUPITER Ridker, 2008^120,^ ^124^ | 1.9^‡^ | A priori | Primary end point: MI, CVA, hospitalization for unstable angina, arterial revascularization, or CVD death | Men | 5,475 | 103 (1.9%) | 5,526 | 181 (3.3%) | 0.58 (0.45 to 0.73) | 0.80
JUPITER Ridker, 2008^120,^ ^124^ | 1.9^‡^ | A priori | Primary end point: MI, CVA, hospitalization for unstable angina, arterial revascularization, or CVD death | Women | 3,426 | 39 (1.1%) | 3,375 | 70 (2.1%) | 0.54 (0.37 to 0.80) | 0.80

* Calculated

† RR

‡ Median

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis Trial; CG = control group; CI = confidence interval; CHD = coronary heart disease; CVA = cardiovascular accident; HR = hazard ratio; IG = intervention group; JUPITER = Justification for the Use of Statins in Prevention: an Intervention Trial Evaluating Rosuvastatin; MI = myocardial infarction; NR = not reported; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; p-y: person-years; RR = relative risk

The St. Francis Heart Study found no statistically significant benefit for CAC-guided moderate-intensity statin therapy but was not adequately powered (Tables 34 and 35).^121^ This trial reported 6.9 percent CVD events in the atorvastatin group compared to 9.9 percent events in the placebo group (RR 0.70 [95% CI 0.44 to 1.10]) at 4.3 years of followup. Among participants with baseline CAC greater than 400, there was a statistically significant reduction in CVD events in the atorvastatin group compared to the placebo group (8.7% with events versus 15.0%; p=0.046); it is not clear whether this was a prespecified subgroup analysis and interaction testing is not reported.

## KQ5 What Are the Harms of Treatment Guided by Nontraditional Risk Factors?

### Summary

Three of the four included RCTs for KQ4 reported harms of treatment (i.e., aspirin or statin) guided by nontraditional risk factor assessment.^120,^ ^122,^ ^123^ We found no other studies evaluating harms meeting our inclusion criteria. Neither aspirin trial (AAA and POPADAD) found evidence of increased major bleeding (including hemorrhagic CVA) for low-dose aspirin compared to placebo after approximately 7 to 8 years of followup. The JUPITER trial did find evidence of an increased incidence of diabetes in the high-intensity statin therapy group (3.0 percent) compared to placebo (2.4 percent), p=0.01 after approximately 2 years; however, it did not find evidence of increases in other serious adverse effects (including hemorrhagic CVA) or myopathic events for high-intensity statin therapy compared to placebo.

### Detailed Results

#### Description of Studies

Please refer to the KQ4 section (Tables 32 and 33).

#### Harms

AAA and POPADAD found no statistically significant difference between low-dose aspirin and placebo group in major bleeding events (Table 38). Overall the number of adverse events was low. The AAA trial reported 2.0 percent major bleeding events (e.g., major GI bleeding, hemorrhagic CVA, and intracranial bleeding) in the aspirin and 1.2 percent events in the placebo group (HR 1.71 [95% CI, 0.99 to 2.97]) at 8.2 years of followup. The POPADAD trial reported only on fatal hemorrhagic CVA. Event rates were low, with no statistically significant difference between the aspirin and placebo groups.

Table 38 Outcomes in Included Harms Studies (KQ5)

Trial name Author, Year | Mean F/U, years | Outcome | IG N analyzed | IG N events (%) | CG N analyzed | CG N events (%) | IG vs. CG HR (95% CI)
AAA Fowkes, 2010^122^ | 8.2 | Major Hemorrhage^*^ | 1,675 | 34 (2.0%) | 1,675 | 20 (1.2%) | 1.71 (0.99 to 2.97)
AAA Fowkes, 2010^122^ | 8.2 | Major GI Bleeding^†^ | 1,675 | 9 (0.5%)^†^ | 1,675 | 8 (0.5%)^‡^ | 1.13 (0.44 to 2.91)^‡,§^
AAA Fowkes, 2010^122^ | 8.2 | Total Hemorrhagic CVA | 1,675 | 5 (0.3%)^‡^ | 1,675 | 4 (0.2%)^‡^ | 1.25 (0.34 to 4.65)^‡,§^
AAA Fowkes, 2010^122^ | 8.2 | Fatal Hemorrhagic CVA | 1,675 | 3 (0.2%) | 1,675 | 3 (0.2%) | 1.00 (0.20 to 4.95)^‡,§^
AAA Fowkes, 2010^122^ | 8.2 | Nonfatal Hemorrhagic CVA | 1,675 | 2 (0.1%) | 1,675 | 1 (0.1%) | 2.00 (0.18 to 22.04)^‡,§^
AAA Fowkes, 2010^122^ | 8.2 | Intracranial Bleedingǁ | 1,675 | 6 (0.4%)^‡,§^ | 1,675 | 3 (0.2%)^‡,§^ | 2.00 (0.50 to 7.98)^‡,§^
POPADAD Belch, 2008^123^ | 6.7^¶^ | Fatal Hemorrhagic CVA | 638 | 2 (0.3%) | 638 | 3 (0.5%) | 0.67 (0.11 to 3.98)^‡,§^
JUPITER Ridker, 2008 ^120^ | 1.9^¶^ | Total Hemorrhagic CVA | 8,901 | 6 (0.1%) | 8,901 | 9 (0.1%) | 0.67 (0.20 to 2.10)^‡,§^; p=0.44
JUPITER Ridker, 2008 ^120^ | 1.9^¶^ | Serious adverse event | 8,901 | 1,352 (15.2%) | 8,901 | 1,377 (15.5%) | 0.98 (0.91 to 1.06)^‡,§^
JUPITER Ridker, 2008 ^120^ | 1.9^¶^ | Newly diagnosed diabetes (physician-reported) | 8,901 | 270 (3.0%) | 8,901 | 216 (2.4%) | 1.25 (1.04 to 1.50)^‡,§^

* Defined as nonfatal or fatal hemorrhagic CVA, fatal or nonfatal subarachnoid/subdural hemorrhage, GI bleed requiring admission, and other bleeding requiring hospital admission

† Defined as requiring admission to hospital to control bleeding; admission only to investigate bleeding not included

‡ Calculated.

§ RR

ǁ Defined as fatal or nonfatal subarachnoid/subdural hemorrhage

¶ Median

Abbreviations: AAA = Aspirin for Asymptomatic Atherosclerosis Trial; CG = control group; CI = confidence interval; CVA = cardiovascular accident; GI = gastrointestinal; IG = intervention group; JUPITER = Justification for the Use of Statins in Prevention: an Intervention Trial Evaluating Rosuvastatin; n = population; NR = not reported; POPADAD = Prevention of Progression of Arterial Disease and Diabetes; RR = relative risk; HR = Hazard Ratio

JUPITER found a statistically significant increase in physician-diagnosed diabetes, but not in other serious adverse events, in the rosuvastatin group compared to the placebo group (Table 38). This trial reported 3.0 percent incident diabetes in the rosuvastatin group compared to 2.4 percent in the placebo group (RR 1.25 [95% CI, 1.04 to 1.50]) at 1.9 years of followup. However, there was no difference in a composite outcome of serious adverse events between the rosuvastatin group (15.2 percent) versus the placebo group (15.5 percent) (RR 0.98 [95% CI, 0.91 to 1.06]) and no difference in hemorrhagic CVA between the two groups, but this outcome was rare (0.1%).