# 2 Methods

## Scope and Purpose

This systematic review examined the evidence for using nontraditional risk factors—ABI, hsCRP, and CAC—in cardiovascular risk assessment. For the purposes of this review, we use the terms “risk assessment” and “risk prediction” as synonyms. Our review focuses specifically on these three risk factors, and was informed by a scan of existing literature and guidelines, consultation with experts in the field, consultation with the USPSTF, and a period of public comments. These three nontraditional risk factors satisfied our a priori criteria for relevance; that is, a novel risk factor should:

1. Be easily and reliably measured (i.e., laboratory, radiographic, or clinical measurement should have accepted population reference values).
2. Have established predictive ability beyond traditional risk factor assessment (i.e., independently associated with CHD or CVD risk using measures of risk association including hazard ratios, rate ratios, or odds ratios).
3. Have data to describe the prevalence and distribution of nontraditional risk factor status by traditionally identified risk groups (i.e., adequate variation in the distribution of abnormal and normal values).

The USPSTF will use this review to update its 2009 recommendation statement on screening for coronary heart disease with nontraditional risk factors^45^ and its 2013 recommendation on CVD risk assessment with the ABI.^46^

## Key Questions and Analytic Framework

In consultation with members of the USPSTF, we developed an analytic framework (Figure 1) and five Key Questions (KQs) to guide our review.

Figure 1 Analytic Framework

Abbreviations: ABI = ankle-brachial index; CAC = coronary artery calcium; CVD = cardiovascular disease; hsCRP = high sensitivity C-reactive protein, KQ = key question; MI = myocardial infarction

Figure 1 is the analytic framework that depicts the five Key Questions addressed in the systematic review. The figure illustrates how nontraditional risk factor assessment may result in improved health outcomes, including cardiovascular morbidity and mortality (KQ1). Additionally, the figure illustrates how nontraditional risk factor assessment may improve measures of calibration, discrimination, and risk reclassification (KQ2) and how treatment based on nontraditional risk factor assessment may improve health outcomes (KQ4). Further, the figure depicts whether nontraditional risk factor assessment or treatment based on nontraditional risk factor assessment are associated with any adverse events (KQ3 and KQ5).

1. Compared with the Pooled Cohort Equations or Framingham risk factors alone, does risk assessment of asymptomatic adults using nontraditional risk factors—followed by treatment specific to risk level—lead to reduced incidence of cardiovascular events (e.g., myocardial infarction, cerebrovascular accident) and/or mortality?
2. Does use of nontraditional risk factors in addition to traditional risk factors to predict cardiovascular disease risk improve measures of calibration, discrimination, and risk reclassification?
3. What are the harms of nontraditional risk factor assessment?
4. Does treatment guided by nontraditional risk factors, in addition to traditional risk factors, lead to reduced incidence of cardiovascular events (e.g., myocardial infarction, cerebrovascular accident) and/or mortality?
5. What are the harms of treatment guided by nontraditional risk factors?

## Data Sources and Searches

We conducted a search to identify literature published since a set of previous reviews for the USPSTF through May 22, 2017. We worked with a research librarian to develop our search strategy, which included the following databases: MEDLINE, PubMed (published-supplied records only) and the Cochrane Central Register of Controlled Trials (Appendix B). For hsCRP, we bridged from the previous USPSTF review by Buckley and colleagues^47^ and searched from 2007; for CAC, we bridged from the previous review by Helfand and colleagues^48^ and searched from 2008. For ABI, we bridged from the review by Lin and colleagues^49^ and search from 2012. We evaluated all previously included studies from the prior reviews for the USPSTF as well as reference lists of other systematic reviews and meta-analyses to identify additional studies not identified in our literature searches. We also searched ClinicalTrials.gov and WHO International Clinical Trials Registry Platform (ICTRP), for relevant ongoing trials (Appendix B). We managed all literature search results using EndNoteTM version 7.3.1 (Thomson Reuters, New York, NY).

## Study Selection

One investigator independently prescreened titles and abstracts of a subset of studies that were electronically identified as having keywords pertaining to an excluded setting, population, or condition in the abstract or keyword fields of EndNote (Appendix B Table 1); abstracts deemed potentially relevant during single review were advanced for dual review. Of the 22,707 total citations screened, 8,013 were prescreened by a single reviewer; of these, 265 were identified as potentially relevant and moved forward for dual review. Two investigators independently reviewed 483 full-text articles against prespecified inclusion criteria (Appendix B Table 2).

Our review focuses on the benefit and harm of adding ABI, hsCRP, or CAC to the current standard of practice of CVD or CHD risk prediction using traditional risk factors (i.e., the PCE or the FRS). Specifically, eligible base models had to include age, sex, systolic blood pressure, antihypertensive medication use, total cholesterol, HDL, and current smoking status. Models were eligible with or without the inclusion of race/ethnicity and diabetes as these predictors are included in some but not all eligible base models.^7,18-20^ Studies with additional variables (e.g., measures of kidney function, family history, left ventricular hypertrophy) in their base models were excluded, as this would preclude us from isolating the effect of the nontraditional risk factor of interest. If we could not isolate the effect of newly added risk factors, we excluded extended models comprising multiple nontraditional risk factors. Thus, the Reynolds Risk Score, which includes hsCRP, family history, and HbA1c for individuals with diabetes (in the model for women but not men)^15,50^ was not evaluated in this review; information about its performance in external validation studies is described in the Discussion.

We included studies or cohorts of adults without known CVD in developed countries as defined using the Human Development Index by the United Nations Development Program. For KQ1, we included randomized or controlled clinical trials comparing traditional risk assessment to risk assessment including nontraditional risk factors that reported patient health outcomes. For KQ4, we included randomized or controlled clinical trials of treatment guided by nontraditional risk factor assessment in addition to traditional risk assessment versus no treatment or usual care that reported patient health outcomes. Patient health outcomes were defined as CVD events (e.g., MI, CVA) and/or mortality (e.g., CVD-specific or all-cause). For KQ2, we included individual participant data (IPD) meta-analyses, trials, or well-designed prospective cohort studies evaluating risk prediction in models with traditional risk factors (base model) compared to models additionally including ABI, hsCRP, or CAC (extended model). We included any measure of calibration, discrimination, or reclassification as risk assessment performance measures. For KQ3 and 5, studies examining the harms of risk assessment (or treatment guided by risk assessment), we included trials, prospective and retrospective cohort studies, and well-designed case-control studies examining harms. We defined harms as any serious adverse event (i.e., unexpected or unwanted medical attention) resulting from risk factor assessment itself or aggressive risk factor modification resulting from risk assessment. For CAC assessment, we also included radiation exposure from CT as a potential harm (i.e., studies included for other questions that reported radiation exposure or studies with the explicit aim to measures/evaluate radiation exposure). All KQs restricted inclusion to good- or fair-quality studies published in English.

## Quality Assessment and Data Abstraction

Two reviewers independently and critically appraised articles meeting inclusion criteria. For trials and cohort studies, we used the USPSTF’s design-specific quality criteria and items from the Newcastle-Ottawa Scale.^51,52^ For risk prediction studies, we adapted and tailored items from the Checklist for Critical Appraisal and Data Extraction for Systematic Review of Prediction Modelling Studies (CHARMS),^53^ and selected domains pertaining to IPD meta-analyses (if applicable)^54^ (Appendix B Table 3). We rated articles as good, fair, or poor quality. In general, a good-quality study met all criteria. A fair-quality study did not meet, or it was unclear whether it met, at least one criterion but had no known important limitations that could invalidate its results. A poor-quality study had a single fatal flaw or multiple important limitations. Two studies, both for KQ2, were excluded for poor quality.^55,56^ Both had multiple limitations, including nonrepresentative sampling of patients, self-reported outcomes, limited duration of followup, and/or very small number CVD events. We excluded poor-quality studies from this review. Disagreements about critical appraisal were resolved by consensus and, if needed, in consultation with a third independent reviewer.

One reviewer abstracted key elements of included studies using standardized evidence tables in DistillerSR (Evidence Partners, Ottawa, Canada). A second reviewer checked the data for accuracy. For each study, we abstracted general characteristics of the study (e.g., author, year, recruitment, study design, length of followup), clinical and demographic characteristics of the included population (e.g., age, race/ethnicity, means or proportions of traditional cardiovascular risk factors), characteristics of the base model (e.g., published coefficient vs model development, recalibration, outcome predicted by the model), treatment details (if applicable [KQ4]), and outcomes (e.g., CVD outcomes, mortality, risk prediction performance). The performance of risk prediction models, or the comparative performance of one model to another, can be described using a few key dimensions:^57-59^

- Calibration: Agreement between observed and predicted outcomes
- Discrimination: Ability to distinguish between individuals who will and will not have an event
- Reclassification: Ability to (correctly) reassign people into clinically meaningful risk strata

We abstracted any of these performance measures reported by the included studies. Descriptions of specific measures are provided in Table 3; additional measures to describe test performance exist, such as the Greenwood-Nam-D’Agostino calibration approach,^60^ but we only describe those reported in included studies. Studies reporting measures of association (e.g., hazard ratios) between ABI, hsCRP, or CAC and cardiovascular outcomes that did not also report one of the three risk prediction outcomes above were excluded.

Table 3 Examples of Types of Test Performance Measures for Comparing Risk Assessment or Prediction Models^59-61,^ ^63,^ ^64^

Purpose of outcome measure | Example measures of test performance | Description
Calibration | Calibration plot | Graphical assessment of calibration with predictions on the x-axis and outcome on the y-axis. Calibration in the large and calibration slope can be derived from calibration plots.
Calibration | O:E | The ratio of observed to expected events.
Calibration | Hosmer– Lemeshow X^2^ | Calculated by summing differences between observed and predicted probabilities in each group (a group being some parsing of the population, e.g., by decile, risk strata); a significant p-value signals poor fit. The test is sensitive to how groups are constructed and is sensitive to sample size, often being nonsignificant for small N and significant for large N.^59^ The Hosmer–Lemeshow X^2^ does not adjust for time-to-event, and several approaches have been developed to extend the test for survival data (but were not reported in included studies).^60^
Overall performance (captures both calibration and discrimination aspects)^57^ | Akaike information criterion (AIC) and Bayes information criterion (BIC) | The AIC and BIC are measures used during model development to aid in inclusion or exclusion of predictors in a model. The AIC is a function of log likelihood that adds a penalty for each added predictor. The BIC is similar, although it imposes a greater penalty than the AIC for added variables. Lower values of both measures indicate better model fit. A change of >10 in the AIC has been proposed to indicate strong evidence for a difference in models.^84^
Overall performance (captures both calibration and discrimination aspects)^57^ | Likelihood ratio X^2^ | Likelihood ratio X^2^ is a global test of model fit and a function of the number of terms in the model. Higher values for the ratio, or difference between models, indicate better fit (as do lower absolute log-likelihood values).^83^ A global X^2^ is generally the same as a likelihood X^2^ (twice the log likelihood ratio).
Overall performance (captures both calibration and discrimination aspects)^57^ | Brier score | The Brier score computes the sum of squared differences between observed outcomes and fitted probability, where lower values indicate that predicted probabilities are closer to observed outcomes.^83^
Overall performance (captures both calibration and discrimination aspects)^57^ | R^2^ | There are a number of ways to calculate an R^2^ for a logistic regression.^59^ Nagelkerke’s generalized R^2^, which is reported in included studies in this body of literature, is generally analogous to the percentage of variance explained in a linear model and is adjusted to a range of 0 to 1. Higher values indicate better fit.^83^ The R^2^ is more helpful than the Brier score because it can be compared across models/studies.
Discrimination | c-statistic or area under the curve (AUC); change in c-statistic or AUC | The probability that, for a randomly selected pair of individuals, one with disease and the other without, the person with disease will have the higher estimated disease probability according to the model.^83^ The c-statistic can be conceptualized as the area under the ROC curve (plots sensitivity against 1–specificity); as a rank order statistic it is insensitive to systematic errors in calibration.^57^ The Harrell’s c-statistic is an extension of the AUC for survival analysis allowing for right-censored data and variable time to followup.^158^ The change in c-statistic or AUC can be insensitive in assessing the impact of adding new predictors to a model, and the impact of a new predictor on c-statistics is lower when other strong predictors are in the model.^134^
Risk reclassification | Net reclassification index or improvement (NRI) | The sum of differences in proportions of individuals moving up a risk category minus those moving down a risk category with a cardiovascular disease outcome, plus the proportion moving down a risk category minus those moving up a risk category without an outcome. The NRI can be considered separately as the sum of the event NRI (P[up\|event] – P[down\|event]) and nonevent NRI (P[down\|nonevent] – P[up\|nonevent]). The NRI is not weighted for the prevalence of events or nonevents; some experts have advocated against combining event and nonevent NRI^67^ and others have commented that NRI is naturally weighted by event and nonevent categories serving as their own denominators.^159^ The NRI is of limited value in comparing models with different risk categories.
Risk reclassification | Integrated discrimination improvement (IDI) | Integrates the NRI over all possible cutoffs; equivalent to difference in discrimination slopes of the 2 models and to the difference in R^2^.^57^

For calibration, we preferred graphical representations because they are more intuitive and can indicate the direction of miscalibration. When reported, we extracted information on the total number of observed (O) and expected (E) events; the O:E ratio is a proxy for overall model calibration (i.e., strongly related to the calibration in the large measure) and can be compared across studies. However, both calibration plots and O:E ratio are rarely reported. The HosmerLemeshow test was the most commonly reported measure of calibration. Several measures, including R^2^ and the Brier score, are considered “overall performance measures” in that they are integrated measures of calibration and discrimination;^57,59^ we report these with calibration. We used the c-statistic (and change in the c-statistic) as our primary measures of discrimination. Although we recognize the difference between the area under the curve (AUC) and the c-statistic (Harrell’s C), we summarize these together. We used the net reclassification index (NRI) as our primary measure of reclassification, and report event and nonevent NRI separately where possible. IDI was included in the Appendix (Appendix E) but not discussed in detail due to the very sparse reporting of this measure.

## Data Synthesis and Analysis

Our analyses were organized by KQ. We address the clinical value of risk assessment hierarchically, meaning—does measurement of the nontraditional risk factor:

1. Demonstrate a clinical benefit on CVD or mortality outcomes to those reclassified using nontraditional risk factors (KQ1)?
2. Improve discrimination or calibration (KQ2)?
3. Correctly reclassify those with a predicted intermediate risk into higher or lower risk, or demonstrate the ability to correctly reclassify those whose risk has been over- or underestimated into a more accurate risk group (e.g., from a high-risk to lower-risk group) (KQ2)? or
4. Result in any serious harm (KQ3)?

We also summarized the evidence on the effectiveness (KQ4) and harms (KQ5) of various preventive treatments guided by the addition of nontraditional risk factors to traditional risk factor assessment.

For KQ2, we stratified our analyses based on a few important dimensions of heterogeneity: 1) choice of the FRS^18-20^ or the PCE^7^ as the base model; 2) prediction of CVD vs CHD outcomes; and 3) type of model design. In addition, studies used different CVD and CHD outcomes or events. The most severe of these outcomes (i.e., fatal or nonfatal MI or CVA) are commonly referred to as hard outcomes. Other studies include events of differing degrees of severity (e.g., angina, transient ischemic attack [TIA], claudication), and utilization outcomes (e.g., revascularization); these are commonly referred to as soft outcomes. Risk prediction studies evaluating the PCE as a base model used CVD outcomes; however, studies evaluating the FRS as a base model used both CHD and CVD outcomes, with varying events or endpoints included in these outcomes (Table 4).

Table 4 Cardiovascular Risk Prediction Base Models and Types of Outcomes (Events) Used

Outcomes | Fatal only | Hard^*^ | Soft
CVD | SCORE^†^ | PCE | D’Agostino 2008^20^
CHD | | ATP III | Wilson, 1998^18^

* Preferable analyses

† SCORE was not evaluated in this review

Abbreviations: ATP III = Adult Treatment Panel III; CHD = coronary heart disease; CVD = cardiovascular disease; PCE = Pooled Cohort Equations

We prioritize analyses using the PCE base model with hard CVD outcomes, and the FRS base model with hard CHD outcomes. While we included models predicting fatal outcomes only, we do not discuss these results, unless it was the only outcome reported/predicted.

Risk prediction studies evaluating the added prognostic value of ABI, hsCRP, or CAC were either pragmatic in design (i.e., preserved the coefficients from the published model) or model development studies. Studies that used the original published coefficients of the FRS^18-20^ or the PCE^7^ were considered preferable to model development studies on the basis that these studies are the most applicable to current practice; in these studies, nontraditional risk factors of interest were added to publicly available, externally validated models used in clinical practice. We refer to models with this design as published coefficient models. This term is used to designate the specific application of an externally validated model in which the original coefficients are preserved (with or without updating to a local population). We use the term external validation more broadly to refer to the generalizability or transportability of a clinical prediction model to other “plausibly related” populations;^61^ both the FRS and PCE as base models are externally validated. However, because the minority of included studies preserved the original published coefficients, we also discuss studies that included the same predictor variables in the FRS or PCE, but with locally developed coefficients from newly fitted models (e.g., full recalibration, de novo model development). We refer to models with this design as model development studies. Although such model development studies are less clinically relevant, they do serve the explanatory purpose of evaluating more generally whether an added nontraditional risk factor improves model performance. In this report, the terms FRS and PCE will refer to published coefficient models, and the terms “FRS variables” and “PCE variables” will be used to refer to model development studies.

In addition to these dimensions of heterogeneity (i.e., choice of base model, corresponding CVD or CHD outcomes, and type of model design), we a priori looked at other characteristics that might explain differences in findings across studies, including:

- Updating the model to the local/studied population (i.e., “recalibration” among published coefficient models). We considered such studies to more conservatively estimate the incremental value of ABI, hsCRP, or CAC.^62^
- Continuous versus dichotomized or categorized predictors. Treatment of continuous risk predictors as dichotomous or categorical variables results in loss of statistical power and compromises predictive performance.^63^
- Number of events or events per variable (EPV) (stratification with 100 event cut-off).^64^
- Length of followup/time horizon (i.e., longer followup preferred).
- Definition of low-, intermediate-, and high-risk strata (for risk reclassification).
- Sex (where subgroup analyses allow).
- Presence of diabetes (where subgroup analyses allow).
- Race/ethnicity (where subgroup analyses allow).

Often, we identified multiple publications for model development analyses for any given outcome from the same cohort. In these instances, we preferred analyses with the larger sample size (n) and/or the longest followup (largest number of events). For bodies of evidence where IPD meta-analyses were included,^65,66^ we used the IPD meta-analyses as the central piece of evidence and only analyzed separate studies from those included cohorts if different (and preferable) base models, outcomes, types of model design, or performance measures were reported in separate publications.

We did not quantitatively synthesize information because of the limited number of studies for most key questions as well as the clinical and methodological heterogeneity of included studies for KQ2 (i.e., differences in types of model design, populations, base models, CHD or CVD outcomes, definition of risk strata, and performance or statistical measures reported). If the change in discrimination between base and extended models was not reported (and it rarely was), we calculated a crude change by subtracting the base model discrimination from that of the extended model. However, confidence intervals for these differences could not be calculated.

As there is no guidance in existing literature about how to characterize the magnitude or clinical meaning of changes in discrimination (KQ2),^67^ we used the following definitions for practical reasons. For changes in the c-statistic, the term “large” is used to denote changes of 0.1 or greater, “moderate” for changes of 0.05-0.1, “small” for 0.025-0.05, and “very small” for changes less than 0.025. C-statistics range from 0.5 to 1.0; the 0.1 cutpoint for “large” was set because it represents 20 percent of the possible range. A change in c-statistic of 0.025 approximates a 5 percent higher sensitivity when specificity is 50 percent.^68^

When a reclassification table for an entire study population was available, we calculated the event NRI, nonevent NRI, and bias-corrected NRI for the immediate-risk group (NRI_INT_), if not reported.^69,70^ We abstracted uncorrected NRI_INT_ if a reclassification table was not provided; however, uncorrected NRI_INT_ can overestimate the reclassification effect.^71^ Details of the calculations for NRIs and confidence intervals are included in Appendix B.

## Grading the Strength of the Body of Evidence

We graded the strength of the overall body of evidence for each KQ. We adapted the Evidencebased Practice Center approach,^72^ which is based on a system developed by the Grading of Recommendations Assessment, Development and Evaluation (GRADE) Working Group.^73^ Our method explicitly addresses four of the five Evidence-based Practice Center-required domains: consistency (similarity of effect direction and size), precision (degree of certainty around an estimate), reporting bias (potential for bias related to publication, selective outcome reporting, or selective analysis reporting), and study quality (i.e., study limitations). We did not address the fifth required domain—directness—as it is implied in the structure of the KQs (i.e., pertains to whether the evidence links the interventions directly to a health outcome).

Consistency was rated as reasonably consistent, inconsistent, or not applicable (e.g., single study). Precision was rated as reasonably precise, imprecise, or not applicable (e.g., no evidence). Reporting bias was rated as suspected, undetected, or not applicable (e.g., when there is insufficient evidence for a particular outcome). Study quality reflects the quality ratings of the individual studies and indicates the degree to which the included studies for a given outcome have a high likelihood of adequate protection against bias. The body of evidence limitations field highlights important restrictions in answering the overall KQ.

We graded the overall strength of evidence as high, moderate, or low. “High” indicates high confidence that the evidence reflects the true effect and that further research is very unlikely to change our confidence in the estimate of effects. “Moderate” suggests moderate confidence that the evidence reflects the true effect and that further research may change our confidence in the estimate of effect and may change the estimate. “Low” indicates low confidence that the evidence reflects the true effect and that further research is likely to change our confidence in the estimate of effect and is likely to change the estimate. A grade of “insufficient” indicates that evidence is either unavailable or does not permit estimate of an effect. Two independent reviewers rated each KQ according to consistency, precision, reporting bias, and overall strength of evidence grade. We resolved discrepancies through consensus discussion involving more reviewers.

## Expert Review and Public Comment

A draft Research Plan for this review was available for public comment from June 11 to July 8, 2015. The draft version of this report was reviewed by six invited experts and two USPSTF Federal Partners. Experts were selected based on their expertise on fundamental methodologic and content aspects of the review (i.e., risk prediction, cardiovascular epidemiology, ABI, hsCRP, and CAC) and were selected to obtain diverse informed perspectives, including developers of included risk prediction models, researchers who have validated risk prediction models, guideline developers, trialists, specialists in cardiovascular imaging, and practicing clinicians. All expert comments were considered, and selected comments from experts were used to clarify and extend the synthesis of evidence to ensure accuracy and address scientifically relevant concerns. All comments were shared with members of the USPSTF and the Agency for Healthcare Research and Quality (AHRQ). Additionally, a draft of the full report was posted on the USPSTF Web site from January 16, 2018 to February 12, 2018. Based on the public comments received, we made a few minor revisions to the evidence report, including addition of background information about the distribution of 10-year CVD risk in the U.S. and additional clarification about included and discussed studies and analyses.

## USPSTF Involvement

This systematic review was funded by AHRQ under contract to support the USPSTF. We consulted with USPSTF liaisons at key points in the review including the development of the research plan (i.e., KQs, analytic framework, and inclusion and exclusion criteria) and the finalization of the systematic review. An AHRQ Medical Officer provided project oversight, reviewed the draft and final versions of the review, and assisted with public comment on the research plan and draft review. The USPSTF and AHRQ had no role in the study selection, quality assessment, or writing of the systematic review.