# 1 Introduction

## Condition Definition

Cardiovascular disease (CVD) is a broad term encompassing diseases of the heart, vascular diseases of the brain, and diseases of blood vessels.^1,^ ^2^ It generally refers to atherosclerosis, including but not limited to coronary heart disease (CHD; also called ischemic heart disease), cerebrovascular disease, and peripheral artery disease (PAD). CVD can also include other diseases in the heart or vascular system, such as heart failure, atrial fibrillation, congenital heart disease, cardiomyopathies, and rheumatic heart disease; these conditions are not addressed in this report.

## Prevalence and Burden of Cardiovascular Disease

CVD is the leading cause of death in the United States for both men and women, accounting for about one in three deaths.^3^ Although CVD mortality is decreasing over time in the United States, it remains a significant cause of morbidity and mortality. Despite a nearly 7 percent reduction in the number of CVD deaths per year between 2004 and 2014, an estimated 580,000 Americans have a first myocardial infarction (MI) each year and about 610,000 experience a first cerebrovascular accident (CVA).^3^

The burden of CVD varies by age, sex, and race/ethnicity. The prevalence of CVD increases dramatically with age. According to the most recent data from the Centers for Disease Control and Prevention (2006-2010), the prevalence of CHD among adults ages 65 or older was 19.8 percent, which was almost triple that of those ages 45 to 64 years (7.1%).^4^ Similarly, the CVA prevalence of 8.3 percent among those age 65 years or older was almost triple that of those ages 45 to 64 years (2.9%).^5^ Before age 75 years, men experience higher rates of CHD events as a proportion of cardiovascular events than women do, whereas women experience more CVA.^6^ Men tend to experience CHD events earlier in life. For example, the mean age of first MI is 65.3 years for men and 71.8 years for women.^3^ In addition to age and sex differences, certain racial/ethnic groups experience an increased burden of CVD. From 2006 to 2010, American Indians/Alaska Natives had the highest prevalence of both CHD and CVA (11.6% and 5.9%, respectively), followed by African Americans (6.5% and 3.9%), Latinos (6.1% and 2.5%), Whites (5.8% and 2.4%), and Asians/Native Hawaiians/other Pacific Islanders (3.9% and 1.5%).^4,^ ^5^

## Cardiovascular Disease Risk Assessment

CVD risk assessment integrates information about multiple risk factors with the aim of tailoring preventive treatment to maximize the potential benefit for the patient.^7,^ ^8^ Risk assessment also offers a platform for discussion between provider and patient, which may improve patients’ perception of risk and motivate initiation and adherence to medical or lifestyle therapy, as well as physician adherence to best clinical practices.^7,^ ^9-12^

In past decades, there has been a proliferation of CVD risk-assessment models, which are sometimes interchangeably referred to as equations, tools, calculators, algorithms, and scores. A 2016 systematic review of prediction models for CVD risk in the general population found 125 articles describing the development of 363 different models, only one-third of which (132 models) were externally validated.^13^ Several models have been externally validated, are publicly available as calculators or tools, and have been endorsed by clinical practice guidelines (Table 1). These risk assessment tools vary across several important dimensions. The biggest differences among models are the predicted outcomes, which may be CHD-specific or also include CVA. Additionally, there is variation in the severity of outcomes included (soft, hard, or fatal only). Risk assessment tools also vary in the included risk factors. The basic risk factors include measures of age, sex, blood pressure, total cholesterol and HDL-C, and smoking; some include diabetes (with or without hemoglobin A1c). Family history of premature CHD is included in selected tools but not those broadly recommended in the United States. Recent risk assessment tools have incorporated race/ethnicity. Last, risk assessment tools were developed in different derivation cohorts and have varying degrees of external validation. Notable limitations of these models may include nonrepresentative or historically dated populations, limited ethnic diversity in derivation and validation cohorts, and outcome endpoints with poor reliability.^7,^ ^14,^ ^15^

Table 1 Characteristics of Available and Externally Validated Cardiovascular and Coronary Risk Assessment Models

Risk score Recommending body | Risk factors included in the model | Time horizon and outcome | Derivation cohort(s)
ACC/AHA Pooled Cohort Equation, 2013^21^ ACC/AHA^7^ | - Age; - Sex; - Race/ethnicity; - Treated or untreated SBP; - TC; - HDL-C; - Current smoking; - Diabetes; Other CVD RF evaluated but not included^*^ | 10-year risk First hard CVD event (nonfatal MI, CHD death, fatal or nonfatal stroke) | ARIC, CHS, CARDIA, Framingham/Framingham Offspring
Framingham CVD, 2008^20^ Canadian Cardiovascular Society^22^ | - Age; - Sex; - TC; - HDL-C; - SBP; - Antihypertensive medication use; - Smoking; - Diabetes; - (Family history)^†^ | 10-year risk Any CVD event (coronary death, MI, coronary insufficiency, and angina, cerebrovascular events, peripheral artery disease [intermittent claudication], and CHF) | Framingham Heart Study
QRISK2, 2008^150^ NICE^36^ | - Age; - Sex; - Race/ethnicity; - Smoking status; - SBP; - Ratio of TC/HDL-C; - BMI; - Family history of CHD in first degree relative <60 years; - Townsend deprivation score; - Treated HTN; - Rheumatoid arthritis; - Chronic kidney disease; - Diabetes; - Atrial fibrillation | 10-year risk CVD event (angina, MI, stroke, TIA) | UK primary care database; 2/3 of participants randomly allocated to derivation dataset and 1/3 assigned to validation data set
Reynolds, men, 2008^50^ N/A | - Age; - SBP; - Smoking; - TC; - HDL-C; - hsCRP; - Parental history of MI <60 years | 10-year risk CVD event (CVD death, MI, stroke, coronary revascularization) | PHS
Reynolds, women, 2007^15^ N/A | - Age; - SBP; - Smoking; - TC; - HDL-C; - hsCRP; - Parental history of MI <60 years; - HbA1c if diabetic | 10-year risk CVD events (CVD death, MI, stroke, coronary revascularization) | WHS; 2/3 of participants assigned to model derivation data set and 1/3 assigned to validation data set
ASSIGN, 2007^151^ SIGN^42^ | - TC; - HDL-C; - SBP; - Smoking; - Cigarettes per day; - Family history; - Diabetes; - Index of social status/deprivation | 10-year risk CVD events (CVD death, hospitalization for CHD or cerebrovascular disease, revascularization) | SHHEC
ARIC, 2003^28^ N/A | - Sex; - Race; - Cigarette smoking; - TC; - HDL-C; - SBP; - Antihypertensive medication use; - Diabetes; Other CVD RF evaluated but not included^‡^ | 10-year risk CHD event (CHD death, MI, unrecognized MI defined by ECG readings, or coronary revascularization) | ARIC
SCORE 2003^152^ European Society of Cardiology^153^ | - Age; - Sex; - Smoking; - TC or TC/HDL ratio; - SBP; - Smoking; - High- and low-risk regions of Europe | 10-year risk Fatal CVD event (MI, stroke, aortic aneurysm) | Pooled data set of population-based and occupational cohort studies from 12 European countries
PROCAM, 2002^154^ N/A | - Age; - LDL-C; - HDL-C; - TG; - Smoking; - Diabetes; - Family history of MI <60 years; - SBP | 10-year risk CHD event (sudden cardiac death, definite MI) | Prospective German cohort of men
ATP III modification of Wilson Framingham model, 2002^§^,^19^ ATP III^19^ǁ | - Age; - Sex; - TC; - HDL-C; - SBP; - Treatment for HTN; - Smoking | 10-year risk Hard CHD (MI and CHD death) | Framingham Heart Study

* ACC/AHA recommends that if risk-based treatment is uncertain using this tool, then consider one or more of the following: family history, hsCRP, CAC score or ABI. Do not use CIMT for risk assessment. No recommendation for or against use of ApoB, CKD, microalbuminuria, and cardiorespiratory fitness.

† Canadian Cardiovascular Society recommends a modified version of the model that includes family history of premature CHD.^22^

‡ Other CVD RF explored: age, BMI, waist-hip ratio, sport activity index, forced expiratory volume, plasma fibrinogen, factor VII, factor VIII, von Willebrand factor, Lp(a), heart rate, Keys score, pack-years smoking, CIMT, fasting TG, ApoA, ApoB, albumin, white blood cell count, creatinine

§ There are additional Framingham-based risk assessment models with variations in outcomes predicted and risk factors included.^16-18,^ ^155^ In this table we have focused on models recommended by guideline bodies.^19,^ ^20^

ǁ Replaced by 2014 recommendations from the ACC/AHA^7^

Abbreviations: ACC: American College of Cardiology; AF: atrial fibrillation; AHA: American Heart Association; ApoA: apolipoprotein A; ApoB: apolipoprotein B; ARIC: Atherosclerosis Risk in Communities Study; ATP III: Adult Treatment Panel III; BMI: body mass index; BP: blood pressure; CARDIA: Coronary Artery Risk Development in Young Adults; CHD: coronary heart disease; CHF: congestive heart failure; CHS: Cardiovascular Health Study; CIMT: carotid intima-media thickness; CKD: chronic kidney disease; CVD: cardiovascular disease; DBP: diastolic blood pressure; ECG: electrocardiogram; HbA1c: glycated hemoglobin; HDL-C: low-density lipoprotein cholesterol; HHP: Honolulu Heart Program; hsCRP: high-sensitivity c-reactive protein; HTN: hypertension; LDL-C: low-density lipoprotein cholesterol; Lp(a): lipoprotein a; MESA: Multi-Ethnic Study of Atherosclerosis; MI: myocardial infarction; N/A: not applicable; NHLBI: National Heart, Lung, and Blood Institute; NICE: National Institute for Health and Care Excellence; PHS: Physician’s Health Study; PR: Puerto Rico Heart Health Program; PROCAM: Prospective Cardiovascular Münster; REGARDS: Reasons for Geographic and Racial Differences in Stroke study; RF: risk factors; SBP: systolic blood pressure; SCORE: Systematic Coronary Risk Evaluation; SES: socioeconomic status; SHHEC: Scottish Heart Health Extended Cohort; SHS: Strong Heart Study; SIGN; Scottish Intercollegiate Guidelines Network; T C: total cholesterol; T G triglycerides; TIA: transient ischemic attack; UK: United Kingdom; US: United States; WHI: Women’s Health Initiative; WHS: Women’s Health Study

The first widely used CVD risk prediction tool was the Framingham Risk Score (FRS), which was derived from the Framingham Heart Study and includes the “traditional” risk factors of: age, sex, total and high-density lipoprotein cholesterol [HDL-C], blood pressure, smoking, and diabetes. Externally validated Framingham-based models include those by Anderson, Wilson, D’Agostino, and the Adult Treatment Panel (ATP III).^16-21^ These models generally include the same risk factors (left ventricular hypertrophy as determined by electrocardiography was included in one older model but subsequently dropped^16,^ ^17^) but predict somewhat different composite CHD or CVD outcomes. Of note, the ATP III model was not intended for use in individuals with diabetes, which was considered a CHD risk equivalent.^22^ In 2013, the American College of Cardiology/American Heart Association (ACC/AHA) Guideline on the Assessment of Cardiovascular Risk released the Pooled Cohort Equations (PCE). The PCE is based on four population-based cohort studies and includes the same risk factors as the FRS, but inclusion of multi-ethnic populations in the derivation cohorts also enabled race- and sex-specific equations for African Americans and Whites. Included risk factors were selected based on their ability to improve the model and were not selected a priori to be the same as the FRS.^7^ The PCE predicts hard CVD outcomes (MI, CVA, CHD, or CVD mortality) and includes diabetes as a risk factor.^7^ U.S. population estimates of the distribution of 10-year CVD risk from the PCE using 2001-2010 NHANES data show that the vast majority of Americans aged 40 to 49 years have an estimated 10-year CVD risk of 10 percent or less (94% of women and 88% of men). For ages 50 to 59 years, 86 percent of women and 62 percent of men have estimated 10-year risk of 10 percent or less; at ages 60 to 69, 58 percent of women and 20 percent of men have estimated 10-year risk at this level.^23^

However, external validation studies of various risk assessment tools show that models can over-or under-predict risk and no model has “perfect” calibration or discrimination. In fact, there are tradeoffs between these two performance characteristics and a model cannot be perfect in both.^24^ The clinical importance of miscalibration (both over- and under-prediction) will depend on whether it is occurring above or below accepted treatment thresholds. Direct comparison across models is complicated due to the differences in outcomes predicted, definitions of risk categories, and the availability of external validation cohorts with sufficient years of followup and robust outcome surveillance; additionally, there may be various degrees of heterogeneity in population risk across derivation and validation cohorts.

A recent systematic review identified three trials comparing the use of CVD risk scores versus no use of risk scores or usual care and found that CVD risk scoring had little to no effect on CVD outcomes.^25^ This review found a larger body of evidence suggesting that CVD risk scoring is associated with small reductions in total cholesterol, systolic blood pressure, and CVD risk scores, and that CVD risk scoring is associated with new or intensified lipid or antihypertensive medication management. However, the quality of evidence for all outcomes was characterized as low, with study limitations including limited power, various sources of study bias, and heterogeneity. Therefore, the true benefit of implementing CVD risk assessment tools on patient outcomes is uncertain. Furthermore, the comparative benefit of using different tools has never been evaluated in a trial assessing the impact of using one versus another model on CVD outcomes. This type of trial may never be done due to the large sample and long followup needed to detect differences in CVD event rates.^26^

### Use of Nontraditional Risk Factors to Improve Risk Prediction

Given that current risk assessment tools can under- or overestimate CVD risk, it follows that nontraditional risk markers or factors may be helpful in improving the calibration in addition to the discrimination and risk reclassification of currently used risk assessment tools. Over 100 nontraditional risk markers have been proposed as candidates to improve CVD risk assessment; the most commonly investigated are markers of inflammation and atherosclerotic burden.^27^ Our review focuses on three of the most promising nontraditional risk factors: ankle-brachial index (ABI), high sensitivity C-reactive protein (hsCRP), and coronary artery calcium (CAC) score (Table 2).

Table 2 Description of Nontraditional Risk Factors Evaluated in This Review

Risk factor | Description
ABI | The ratio of the systolic blood pressure at the ankle to the systolic blood pressure at the brachial artery; an ABI of <0.9 is considered diagnostic for PAD.^156^
hsCRP | hsCRP is a serum protein involved in immune and inflammatory responses that can be readily measured in widely available lab tests.^47,^ ^48^ Several assays are available, including conventional, high-sensitivity, and cardiac hsCRP tests. High-sensitivity and cardiac hsCRP assays have a lower detection limit than conventional tests.^157^ Cutoff values of >2 and >3 mg/L have been proposed to define elevated hsCRP for the purposes of CVD risk assessment.^48,^ ^120^
CAC | Calcium content of the coronary arteries estimated from CT imaging using 1 of several scoring systems. Categories indicating elevated CAC vary across study, but are often compared with 0 CAC.^48^

Abbreviations: ABI = ankle-brachial index; CAC = coronary artery calcium; CT = computed tomography; hsCRP = high sensitivity C-reactive protein.

In developing the PCE, the ACC/AHA examined a number of promising nontraditional risk factors but did not include them because either: 1) there was no significant improvement in discrimination when included in the model (diastolic blood pressure, family history of CVD, moderate or severe kidney disease [defined as eGFR <60 mL/min/1.73 m^2^], and BMI) or 2) data were unavailable in the model development cohorts (hsCRP, apolipoprotein [apoB], microalbuminuria, cardiorespiratory fitness, CAC, carotid intima-media thickness [CIMT], and ABI). Based on expert opinion, the ACC/AHA guidelines did recommend that family history, hsCRP, CAC, and ABI be considered if risk-based treatment was uncertain after using the PCE. Per experts, family history did not improve discrimination but was free and easy to assess; while CAC appeared to be the most promising nontraditional risk factor, there was not enough data or followup to include it in the PCE (D. Lloyd-Jones, personal communication, 2015). The ACC/AHA guidelines recommended against using CIMT.

Likewise, several nontraditional risk factors were considered in alternate models of CHD or CVD risk prediction but not included in the final model of other recommended risk assessment tools.^28^ Currently only one U.S.-based tool, the Reynolds Risk Score (RRS), incorporates nontraditional risk factors (i.e., hsCRP, family history, and A1c if diabetes is present).

## Treatment Approaches Based on Risk

Risk assessment-guided therapy for the primary prevention of CVD includes statins, aspirin, and intensive lifestyle counseling.^7,^ ^29-32^ In the United States, recommendations for initiation of antihypertensive medications are not based on multivariate risk assessment.

Both the USPSTF and ACC/AHA have 10-year, risk-based recommendations for the use of statins, based on the PCE.^33,34^ The USPSTF has a B recommendation for a low- to moderate-dose statin to prevent CVD events in adults ages 40 to 75 years with no history of CVD, one or more CVD risk factors, and a calculated 10-year CVD event risk of 10 percent or greater; there is a C recommendation to individualize the decision (shared decisionmaking) for those at 7.5 to 10 percent risk.^19,^ ^33^ The ACC/AHA has a recommendation for moderate- to high-intensity statin treatment in adults 40 to 75 years of age with LDL-C 70 to 180 mg/dL, without diabetes or CVD, and with an estimated 10-year risk of 7.5 percent of higher (class of recommendation: I, level of evidence: A); there is also a recommendation for moderate-intensity statin treatment when 10-year risk is 5 percent to less than 7.5 percent (class of recommendation: IIa, level of evidence: B). This recommendation represents a lower treatment threshold than in previous guidelines.^19^ The lowered threshold for discussion or initiation of statin therapy has reinforced concern about calibration of the PCE.^34,35^ Recent U.K. guidelines similarly lowered the threshold for statin therapy to a 10 percent or greater 10-year risk for CVD as assessed with the QRISK2 tool.^36^ All of these recommendations explicitly indicate an informed clinician-patient discussion of benefits and harms prior to initiation of statin therapy.

In 2016, the USPSTF made a B recommendation for initiating low-dose aspirin for the primary prevention of CVD (and colorectal cancer) in adults ages 50 to 59 years who have a 10 percent or greater 10-year CVD risk, and a C recommendation to individualize the decision in adults ages 60 to 69 years with a 10 percent or greater 10-year CVD risk.^37^

Intensive lifestyle counseling to promote a healthful diet and regular physical activity is recommended for people at elevated risk for CVD. In 2014, the USPSTF made a B recommendation to offer or refer adults who are overweight or obese and have additional CVD risk factors (i.e., hypertension, dyslipidemia, impaired fasting glucose, or the metabolic syndrome) to intensive behavioral counseling interventions to promote a healthful diet and physical activity.^38^ This recommendation also includes people identified as high risk based on CVD risk assessment.

In the United States, recommendations for initiation of antihypertensive medications are not currently based on estimated 10-year CVD risk.^29,39^ Thresholds for initiation of blood pressure medication were raised in the most recent U.S. guidelines for patients at least 60 years old (from ≥140/90 mm Hg to ≥150/90 mm Hg) and adults with diabetes or chronic kidney disease (from ≥130/80 mm Hg to ≥140/90 mm Hg).^40^ U.K. blood pressure guidelines, however, recommend initiation of antihypertensive drugs to patients with a 10-year CVD risk of at least 20 percent when clinic blood pressure is higher than 140/90 mm Hg and elevated blood pressure is confirmed by ambulatory or home blood pressure monitoring.^41^

## Current Recommendations and Clinical Practice in the United States

CVD risk assessment, whether with traditional or nontraditional risk factors, intersects numerous current USPSTF recommendations (Appendix A). USPSTF recommendations exist for each of the traditional modifiable Framingham risk factors (cholesterol, blood pressure, diabetes, and smoking) as well as some nontraditional risk factors (ABI) and screening modalities related to nontraditional risk factors (carotid intima-media thickness, electrocardiography). Several recommendations provide discussions of risk assessment in the top-line recommendation or clinical considerations, including: screening for abnormal blood glucose and diabetes, PAD screening, CHD screening with electrocardiography, healthful diet and physical activity counseling, carotid artery stenosis screening, aspirin use to prevent CVD and colorectal cancer, and statin use for the primary prevention of CVD.

A wide range of CVD and CHD risk assessment models are recommended by international guideline bodies (Table 1). Some recommended models include nontraditional risk factors. Although the ACC/AHA did not formally include nontraditional risk factors, they did recommend considering family history, hsCRP, CAC, and ABI if risk-based treatment was still uncertain after a quantitative risk assessment was performed using the PCE. The Canadian Cardiovascular Society added family history to the Framingham global CVD risk tool.^22^ QRISK2, the risk tool recommended by NICE, includes chronic kidney disease, atrial fibrillation, and a measure of social deprivation.^36^ ASSIGN, the risk score recommended by the Scottish Intercollegiate Guideline Network (SIGN), also includes a measure of social deprivation.^42^

Despite recommendations for periodic risk assessment, a recent survey of U.S. physicians found that only 41 percent use cardiovascular risk assessment in practice even though awareness of available tools is high.^43^ The most commonly cited reason for not performing risk assessment is that it is too time consuming. Even when risk assessment is conducted, results are communicated to patients less than half the time, limiting its potential impact to motivate behavior change or adherence to therapy.^43^ A 2012 survey of European physicians found that over 90 percent of them felt that risk assessment tools miss important risk factors and over one-third felt that these tools overestimate risk.^44^ The uptake of cardiovascular risk assessment using nontraditional risk factors is largely unknown and likely varies across practice settings.

## Previous USPSTF Recommendation

In 2009, the USPSTF concluded that the evidence was insufficient to assess the benefits and harms of using nontraditional risk factors studied to screen asymptomatic men and women with no history of CHD to prevent CHD events (I Statement).^45^ The nontraditional risk factors included in this previous recommendation were: hsCRP, ABI, leukocyte count, fasting blood glucose level, periodontal disease, CIMT, CAC score on electron beam computed tomography [EBCT], homocysteine level, and Lp(a) level. In 2013, the USPSTF again concluded that there was insufficient evidence to assess the balance of benefits and harms of screening for PAD and CVD risk assessment with the ABI in adults (I statement).^46^