# Appendix F Ongoing Studies

Study Reference Trial Identifier | Study Name | Location | Estimated N | Description | 2017 Status
ISRCTN12157806 (http://www.isrctn.com/ISRCTN12157806) | The Danish Cardiovascular Screening Trial (DANCAVAS) | Denmark | 45,000 (men) | Population-based, randomized trial to evaluate the health benefits and cost-effectiveness of using noncontrast CT scans (to measure CAC and identify aortic/iliac aneurysms) and measurements of the ABI as part of a multicomponent screening and intervention program for CVD in men aged 65 to 74 years. | Ongoing: Est Interim Publication Date 2018; Completion Date Jan 2026
NCT03228459 (https://clinicaltrials.gov/show/NCT03228459) (Protocol (http://doi.org/10.1016/j.nefro.2016.02.008)) (project page (http://www.elbusdelasalut.cat/inici)) | Randomized intervention study to assess the prevalence of subclinical vascular disease and hidden kidney disease and its impact on morbidity and mortality: The ILERVAS project | Spain | 14,600 | Adults 45 to 70 years without previous history of CVD and with ≥1 CVD risk factor will be randomly selected from the primary health care centers across the province of Lérida. The following baseline tests will be given to the intervention group in a mobile screening unit: artery ultrasound (carotid, femoral, transcranial and abdominal aorta); ABI; spirometry; determination of advanced glycation end products; dried blood spot and urine spot tests. | Ongoing: Est Data Collection Completion Date 2017; Follow up through 2025
NR (Protocol (https://doi.org/10.1186/1471-2261-12-45)) (project page (https://ec.europa.eu/eip/ageing/commitments-tracker/a3/aragon-workers-health-study-awhs_en)) | Aragon Workers Health Study (AWHS) | Spain | 5,400 | Longitudinal cohort study based on the annual health exams of 5,400 workers of a car assembly plant in Spain. Study participants were recruited during a standardized clinical exam in 2009–2010 (participation rate 95.6%). Study participants will undergo annual clinical exams and laboratory assays, and baseline and triennial collection of biological materials for biobanking and cardiovascular imaging exams (carotid, femoral and abdominal ultrasonography, CAC, and ABI). Participants will be followed up for 10 years; specific cardiovascular events that will be monitored are not reported. | Ongoing: Est Completion Date Jan 2019
European Research Council Project ID: 294604 (http://cordis.europa.eu/project/rcn/105995_en.html) (project page (http://www.robinsca.nl/)) | Risk Or Benefit IN Screening for CArdiovascular disease (ROBINSCA)^132^ | The Netherlands | 39,000 | A large-scale, population-based RCT designed to investigate whether screening asymptomatic men and women for a high risk of cardiovascular disease by means of (1) the Systematic COronary Risk Evaluation (SCORE) model or (2) CAC is effective in reducing morbidity and mortality due to CHD. The trial is conducted in three regions of the Netherlands and planned followup is 5 years. | Ongoing: Est Completion Date 2019 (Mid-term Report Summary (http://cordis.europa.eu/result/rcn/178220_en.html))
NCT01428934 (https://www.clinicaltrials.gov/ct2/show/NCT01428934?term=NCT01428934&rank=1) | Improving Intermediate Risk Management. MARK Study (MARK)^162^ | Spain | 2,495 | The purpose of this study is to analyze if ABI, measures of arterial stiffness, postprandial glucose, glycosylated hemoglobin, self-measured blood pressure, and presence of comorbidity are independently associated to incidence of vascular events and whether they can improve the predictive capacity of current risk equations in the intermediate-risk population. Panned followup of 18 months, 5, and 10 years. | Ongoing as of 12/2017: Est Completion Date Dec 2016
NCT00143923 (https://www.clinicaltrials.gov/ct2/show/NCT00143923?term=NCT00143923&rank=1) | Novel Strategies for Reducing Heart Disease Risk Disparities | US | 2,000 | Prospective cohort study of 2,000 residents of the state of Pennsylvania with approximately equal representation of whites and African Americans. All participants will undergo assessments of traditional and nontraditional risk factors to identify and determine the mechanisms of population disparities in cardiovascular risk. 800 participants who are at intermediate or high risk of cardiovascular disease will be randomly assigned to either (1) usual care/“advice only”; or (2) a multidisciplinary behavioral modification program to determine the most effective approach to reduce or eliminate racial, socioeconomic and geographic disparities in cardiovascular risk. The primary outcome is CVD events at 20 years follow up. | Ongoing: Est Completion Date Dec 2024

Abbreviations: ABI = ankle-brachial index; CAC = coronary artery calcium; CHD; coronary heart disease; CT=computed tomography; CVD = cardiovascular disease; Dec = December; Est = estimated; Jan = January; Sept = September